# References

1 U.S. Preventive Services Task Force. Counseling to Prevent Dental and Periodontal Disease. In: Guide to Clinical Preventive Services: Report of the U.S. Preventive Services Task Force. 2nd Ed., Baltimore: Williams & Wilkins; 1996: Chapter 61.
2 U. S. Preventive Services Task Force. Screening and Interventions to Prevent Dental Caries in Children Younger Than 5 Years: U.S. Preventive Services Task Force Recommendation Statement. JAMA. 2021;326(21):2172–8. doi: 10.1001/jama.2021.20007.34874412
3 Final Recommendation Statement Oral Cancer: Screening. U.S. Preventive Services Task Force. 2013. https://www.uspreventiveservicestaskforce.org/uspstf/recommendation/oralcancer-screening. Accessed Oct 30 2020.
4 U.S. Preventive Services Task Force. Final Research Plan-- Oral Health: Screening, Referral, Behavioral Counseling, and Preventive Interventions. 2021. https://www.uspreventiveservicestaskforce.org/uspstf/document/final-research-plan/oral-health-screening-referral-behavioral-counseling-preventive-interventions. Accessed Jul 8 2022.
5 U.S. Preventive Services Task Force. Final Recommendation Statement - Dental Caries in Preschool Children: Screening. 2004. https://www.uspreventiveservicestaskforce.org/uspstf/document/RecommendationStatementFinal/dental-caries-in-preschool-children-screening-2004. Accessed Jul 12 2022.
6 Atchison KA, Rozier RG, Weintraub JA. Integration of Oral Health and Primary Care: Communication, Coordination and Referral. National Academy of Medicine; 2018. https://nam.edu/integration-of-oral-health-and-primary-care-communicationcoordination-and-referral/. Accessed Jul 8 2022.
7 Hummel J, Phillips KE, Holt B, Oral health: An essential component of primary care. Seattle, WA: Qualis Health. 2015:9–12. https://www.safetynetmedicalhome.org/sites/default/files/White-Paper-Oral-HealthPrimary-Care.pdf Accessed Aug 27 2023.
8 Primary Care Collaborative. Innovations in oral health and primary care integration: Alignment with the shared principles of primary care. 2021. https://thepcc.org/sites/default/files/resources/PCC_Oral_Health_Primary_Care_Integration.pdf Accessed Aug 27 2023.
9 National Institutes of Health. Oral health in America: advances and challenges. U.S. Department of Health and Human Services, National Institute of Dental and Craniofacial Research: Bethesda, MD, USA. 2021. https://www.nidcr.nih.gov/sites/default/files/2021-12/Oral-Health-in-America-Advances-and-Challenges.pdf Accessed Aug 27 2023.
10 Chou R, Pappas M, Dana T, Screening and Interventions to Prevent Dental Caries in Children Younger Than 5 Years: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2021;326(21):2179–92. doi: 10.1001/jama.2021.15658. PMID: 34874413.34874413
11 Olson CM, Burda BU, Beil T, Screening for Oral Cancer: A Targeted Evidence Update for the U.S. Preventive Services Task Force. Evidence Synthesis No. 102. AHRQ Publication No. 13–05186-EF-1. Rockville, MD: Agency for Healthcare Research and Quality; April 2013.
12 The Community Guide. Dental Caries (Cavities): School-Based Dental Sealant Delivery Programs. 2013. https://www.thecommunityguide.org/findings/dental-caries-cavities-school-based-dental-sealant-delivery-programs. Accessed Jul 12 2022.
13 The Community Guide. Dental Caries (Cavities): Community Water Fluoridation. 2013. https://www.thecommunityguide.org/findings/dental-caries-cavities-community-waterfluoridation. Accessed Jul 12 2022.
14 U.S. Department of Health and Human Services. Oral Health in America: A Report of the Surgeon General. Rockville, MD: US Department of Health and Human Services; 2000. https://www.nidcr.nih.gov/sites/default/files/2017-10/hck1ocv.%40www.surgeon.fullrpt.pdf. Accessed Aug 27 2023.
15 Basics of Oral Health. Centers for Disease Control and Prevention. https://www.cdc.gov/oralhealth/basics/index.html. Accessed Oct 30 2020.
16 Peres MA, Macpherson LM D, Weyant RJ, Oral diseases: a global public health challenge. Lancet. 2019;394(10194):249–60. doi: 10.1016/S0140-6736(19)31146-8. PMID: 31327369.31327369
17 Dye BA. The Global Burden of Oral Disease: Research and Public Health Significance. J Dent Res. 2017;96(4):361–3. doi: 10.1177/0022034517693567. PMID: 28318392.28318392
18 Naavaal S, Griffin SO, Jones JA. Impact of Making Dental Care Affordable on Quality of Life in Adults Aged 45 Years and Older. J Aging Health. 2020;32(7–8):861–70. doi: 10.1177/0898264319857967. PMID: 31258028.31258028
19 Alpert PT. Oral Health: The Oral-Systemic Health Connection. Home Health Care Manag Pract. 2017;29(1):56–9. doi: 10.1177/1084822316651658.
20 Centers for Disease Control and Prevention. Oral Health Surveillance Report: Trends in Dental Caries and Sealants, Tooth Retention, and Edentulism, United States, 1999–2004 to 2011–2016. Atlanta, GA: Centers for Disease Control and Prevention, U.S. Department of Health and Human Services; 2019. https://www.cdc.gov/oralhealth/publications/OHSR-2019-index.html. Accessed Aug 27 2023.
21 GBD 2017 Disease and Injury Incidence and Prevalence Collaborators. Global, regional, and national incidence, prevalence, and years lived with disability for 354 diseases and injuries for 195 countries and territories, 1990–2017: a systematic analysis for the Global Burden of Disease Study 2017. Lancet. 2018;392(10159):1789–858. doi: 10.1016/S0140-6736(18)32279-7. PMID: 30496104.30496104
22 Bader JD, Rozier RG, Lohr KN, Physicians' roles in preventing dental caries in preschool children: a summary of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2004;26(4):315–25. doi: 10.1016/j.amepre.2003.12.001. PMID: 15110059.15110059
23 Caufield PW, Griffen AL. Dental caries. An infectious and transmissible disease. Pediatr Clin North Am. 2000;47(5):1001–19, v. PMID: 11059347.11059347
24 Centers for Disease Control and Prevention. Recommendations for using fluoride to prevent and control dental caries in the United States. MMWR Recomm Rep. 2001;50(RR-14):1–42. PMID: 11521913.11521913
25 American Dental Association. Permanent Tooth Development. 2012. https://www.mouthhealthy.org/-/media/project/adaorganization/ada/mouthhealthy/files/activity-sheets/adapermanentteethdev_eng.pdf?rev=35dfa5e3807940188fd4d03869f14163&hash=134277D9D838A8A7BE4842000AFC1590. Accessed Aug 27 2023.
26 Bhat M. Periodontal health of 14–17-year-old U.S. schoolchildren. J Public Health Dent. 1991;51(1):5–11. doi: 10.1111/j.1752-7325.1991.tb02168.x. PMID: 2027103.2027103
27 Elias-Boneta AR, Ramirez K, Rivas-Tumanyan S, Prevalence of gingivitis and calculus in 12-year-old Puerto Ricans: a cross-sectional study. BMC Oral Health. 2018;18(1):13. doi: 10.1186/S12903-017-0471-5. PMID: 29351752.29351752
28 American Academy of Pediatric Dentistry. Policy on substance misuse in adolescent patients. The Reference Manual of Pediatric Dentistry. American Academy of Pediatric Dentistry. Chicago, Ill.: 2022. https://www.aapd.org/globalassets/media/policies_guidelines/p_substanceabuse.pdf. Accessed Aug 27 2023.
29 Bellocchio L, Inchingolo AD, Inchingolo AM, Cannabinoids Drugs and Oral Health-From Recreational Side-Effects to Medicinal Purposes: A Systematic Review. Int. 2021;22(15):03. doi: 10.3390/ijms22158329. PMID: 34361095.34361095
30 Leite FR M, Nascimento GG, Scheutz F, Effect of Smoking on Periodontitis: A Systematic Review and Meta-regression. Am J Prev Med. 2018;54(6):831–41. doi: 10.1016/j.amepre.2018.02.014. PMID: 29656920.29656920
31 Leite RS, Marlow NM, Fernandes JK, Oral health and type 2 diabetes. Am J Med Sci. 2013;345(4):271–3. doi: 10.1097/MAJ.0b013e31828bdedf. PMID: 23531957.23531957
32 American Dental Association. Dental care use among children: 2016. Health Policy Institute, ADA. 2016. https://www.ada.org/-/media/project/ada-organization/ada/ada-org/files/resources/research/hpi/hpigraphic_0718_1.pdf. Accessed Aug 27 2023.
33 Wall TP, Vujicic M, Nasseh K. Recent trends in the utilization of dental care in the United States. J Dent Educ. 2012;76(8):1020–7. PMID: 22855587.22855587
34 Adjaye-Gbewonyo D, Black L. Dental Care Utilization Among Children Aged 1–17 Years: United States, 2019 and 2020. NCHS Data Brief No. 424; 2021. https://www.cdc.gov/nchs/data/databriefs/db424.pdf. Accessed Sep 19 2022.
35 Lewis CW, Johnston BD, Lee HH, Income-Based Disparities in a Yearly Dental Visit in United States Adults and Children: Trend Analysis 1997 to 2016. Academic pediatrics. 2020;20(7):942–9. doi: 10.1016/j.acap.2020.06.003. PMID: 32544458.32544458
36 Lewis CW. Teeth: Small but Mighty and Mighty Important. A Comprehensive Review of Children's Dental Health for Primary Care Clinicians. Curr Pediatr Rev. 2020;16(3):215–31. doi: 10.2174/1573396316666200228093248. PMID: 32108010.32108010
37 Kranz AM, Preisser JS, Rozier RG. Effects of Physician-Based Preventive Oral Health Services on Dental Caries. Pediatrics. 2015;136(1):107–14. doi: 10.1542/peds.2014-2775. PMID: 26122805.26122805
38 Clark MB, Braun PA. Promotion of Oral Health and Prevention of Dental Caries Among Children in Primary Care. JAMA. 2021;326(21):2139–40. doi: 10.1001/jama.2021.20396. PMID: 34874439.34874439
39 U.S. Food & Drug Administration. The Selection of Patients for Dental Radiographic Examinations. 2012. https://www.fda.gov/radiation-emitting-products/medical-x-ray-imaging/selection-patients-dental-radiographic-examinations. Accessed Nov 20 2020.
40 Tinanoff N, Reisine S. Update on early childhood caries since the Surgeon General's Report. Acad Pediatr. 2009;9(6):396–403. doi: 10.1016/j.acap.2009.08.006. PMID: 19945074.19945074
41 Levy SM, Broffitt B, Marshall TA, Associations between fluorosis of permanent incisors and fluoride intake from infant formula, other dietary sources and dentifrice during early childhood. J Am Dent Assoc. 2010;141(10):1190–201. PMID: 20884921.20884921
42 Ismail AI, Bandekar RR. Fluoride supplements and fluorosis: a meta-analysis. Community Dent Oral Epidemiol. 1999;27(1):48–56. doi: 10.1111/j.1600-0528.1999.tb01991.x. PMID: 10086926.10086926
43 Beltran-Aguilar ED, Barker L, Dye BA. Prevalence and severity of dental fluorosis in the United States, 1999–2004. NCHS data brief. 2010;53:1–8. PMID: 21211168.21211168
44 Neurath C, Limeback H, Osmunson B, Dental Fluorosis Trends in U.S. Oral Health Surveys: 1986 to 2012. JDR Clin Trans Res. 2019;4(4):298–308. doi: 10.1177/2380084419830957. PMID: 30931722.30931722
45 American Dental Association Council on Scientific Affairs. Professionally applied topical fluoride: evidence-based clinical recommendations. J Am Dent Assoc. 2006;137(8):1151–9. doi: 10.14219/jada.archive.2006.0356. PMID: 16873333.16873333
46 Ekstrand J, Koch G, Lindgren LE, Pharmacokinetics of fluoride gels in children and adults. Caries Res. 1981;15(3):213–20. doi: 10.1159/000260517. PMID: 6938306.6938306
47 Ekstrand J, Koch G, Petersson LG. Plasma fluoride concentration and urinary fluoride excretion in children following application of the fluoride-containing varnish Duraphat. Caries Res. 1980;14(4):185–9. doi: 10.1159/000260452. PMID: 6929729.6929729
48 Garcia RI, Gregorich SE, Ramos-Gomez F, Absence of Fluoride Varnish-Related Adverse Events in Caries Prevention Trials in Young Children, United States. Prev Chronic Dis. 2017;14:E17. doi: 10.5888/pcd14.160372. PMID: 28207379.28207379
49 Crystal YO, Marghalani AA, Ureles SD, Use of silver diamine fluoride for dental caries management in children and adolescents, including those with special health care needs. Pediatr Dent. 2017;39(5):135–45. PMID: 29070149.29070149
50 Seifo N, Cassie H, Radford J, "Iťs really no more difficult than putting on fluoride varnish": a qualitative exploration of dental professionals' views of silver diamine fluoride for the management of carious lesions in children. BMC Oral Health. 2020;20(1):257. doi: 10.1186/S12903-020-01243-y. PMID: 32933507.32933507
51 Horst JA, Ellenikiotis H, Milgrom PL. UCSF protocol for caries arrest using silver diamine fluoride: rationale, indications and consent. J Calif Dent Assoc. 2016;44(1):16–28. PMID: 26897901.26897901
52 Gao SS, Zhao IS, Hiraishi N, Clinical trials of silver diamine fluoride in arresting caries among children: a systematic review. JDR Clin Trans Res. 2016;1(3):201–10. doi: 10.1177/2380084416661474. PMID: 30931743.30931743
53 Ruff RR, Niederman R. Comparative effectiveness of treatments to prevent dental caries given to rural children in school-based settings: protocol for a cluster randomised controlled trial. BMJ Open. 2018;8(4):e022646. doi: 10.1136/bmjopen-2018-022646. PMID: 29654053.29654053
54 American Academy of Pediatric Dentistry. Guideline on xylitol use in caries prevention. American Academy of Pediatric Dentistry Reference Manual. 2012/2013;34(6):166–9.
55 § 101.80 Health claims: dietary noncariogenic carbohydrate sweeteners and dental caries. https://ecfr.federalregister.gov/current/title-21/chapter-I/subchapter-B/part-101/subpart-E/section-101.80. Accessed Oct 15 2020.
56 Slayton RL, Urquhart O, Araujo MW B, Evidence-based clinical practice guideline on nonrestorative treatments for carious lesions: A report from the American Dental Association. J Am Dent Assoc. 2018;149(10):837–49.e19. doi: 10.1016/j.adaj.2018.07.002. PMID: 30261951.30261951
57 Naaman R, El-Housseiny AA, Alamoudi N. The Use of Pit and Fissure Sealants-A Literature Review. Dent J (Basel). 2017;5(4)doi: 10.3390/dj5040034. PMID: 29563440.29563440
58 Community Preventive Services Task Force. Preventing Dental Caries: School-based Dental Sealant Delivery Programs. Atlanta, GA: U.S. Department of Health and Human Services, Community Preventive Services Task Force; 2013. https://www.thecommunityguide.org/findings/dental-caries-cavities-school-based-dental-sealant-delivery-programs.html. Accessed Aug 27 2023.
59 Miloro MB, Vujicic M. Physicians dissatisfied with current referral process to dentists. American Dental Association. 2016. https://www.ada.org/-/media/project/ada-organization/ada/ada-org/files/resources/research/hpi/hpibrief_0316_5.pdf. Accessed Aug 27 2023.
60 Sudhanthar S, Lapinski J, Turner J, Improving oral health through dental fluoride varnish application in a primary care paediatric practice. BMJ Open Qual. 2019;8(2):e000589. doi: 10.1136/bmjoq-2018-000589. PMID: 31259286.31259286
61 Kram J, Baumgardner D, de Grandville C, Evaluation of fluoride varnish implementation for well child visits in a family practice residency clinic. Ann Fam Med. 2022;20(Supplement 1):2644. doi: 10.1370/afm.20.s1.2644.
62 Institute of Medicine. Advancing Oral Health in America. Washington, DC: The National Academies Press; 2011. https://nap.nationalacademies.org/catalog/13086/advancing-oral-health-in-america. Accessed Aug 27 2023.
63 Institute of Medicine and National Research Council. 2011. Improving access to oral health care for vulnerable and underserved populations. Washington, DC: The National Academies Press. https://www.hrsa.gov/sites/default/files/publichealth/clinical/oralhealth/improvingaccess.pdf. Accessed Aug 27 2023.
64 Health Resources and Services Administration. Integration of Oral Health and Primary Care Practice. 2014. https://www.hrsa.gov/sites/default/files/hrsa/oral-health/integrationoral-health.pdf. Accessed Aug 27 2023.
65 Clinical Practice Guidelines. ADA Center for Evidence-Based Dentistry. https://ebd.ada.org/en/evidence/guidelines. Accessed Oct 30 2020.
66 American Academy of Pediatric Dentistry. Policy on Oral Health Care Programs for Infants, Children, and Adolescents. The Reference Manual of Pediatric Dentistry. 2016. https://www.aapd.org/research/oral-health-policies--recommendations/. Accessed Nov 20 2020.
67 Oral Health. American Academy of Family Physicians. https://www.aafp.org/about/policies/all/oral-health.html. Accessed Oct 30 2020.
68 Hummel J, Phillips KE, Holt B, Oral Health: An Essential Component of Primary Care. Seattle, WA: Qualis Health; June 2015. http://www.safetynetmedicalhome.org/sites/default/files/White-Paper-Oral-HealthPrimary-Care.pdf. Accessed Aug 27 2023.
69 Sievers K, Clark MB, Douglass AB, Smiles for Life: A National Oral Health Curriculum. 4th Edition. Society of Teachers of Family Medicine; 2020. www.smilesforlifeoralhealth.com. Accessed Nov 20 2020.
70 Griffin SO, Griffin PM, Li CH, Changes in Older Adults' Oral Health and Disparities: 1999 to 2004 and 2011 to 2016. J Am Geriatr Soc. 2019;67(6):1152–7. doi: 10.1111/jgs.15777 PMID: 30698819.30698819
71 Disparities in Oral Health. Centers for Disease Control and Prevention. https://www.cdc.gov/oralhealth/oral_health_disparities/index.htm. Accessed Oct 30 2020.
72 U. S. Preventive Services Task Force. Procedure Manual. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual Accessed Aug 27 2023.
73 Anderson M, Dahllof G, Twetman S, Effectiveness of Early Preventive Intervention with Semiannual Fluoride Varnish Application in Toddlers Living in High-Risk Areas: a Stratified Cluster-Randomized Controlled Trial. Caries Res. 2016;50(1):17–23. PMID: CN-01411545.26795957
74 Slade GD, Bailie RS, Roberts-Thomson K, Effect of health promotion and fluoride varnish on dental caries among Australian Aboriginal children: results from a community-randomized controlled trial. Community Dent Oral Epidemiol. 2011;39(1):29–43. PMID: CN-00787853.20707872
75 Lawrence HP, Binguis D, Douglas J, A 2-year community-randomized controlled trial of fluoride varnish to prevent early childhood caries in Aboriginal children. Community Dent Oral Epidemiol. 2008;36(6):503–16. doi: 10.1111/j.1600-0528.2008.00427.x. PMID: CN-00686841.18422711
76 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539–58. doi: 10.1002/sim.1186. PMID: 12111919.12111919
77 Morton SC, Murad MH, O’Connor E, Quantitative Synthesis—An Update. Methods Guide for Comparative Effectiveness Reviews. (Prepared by the Scientific Resource Center under Contract No. 290–2012-0004-C). AHRQ Publication No. 18-EHC007-EF. Rockville, MD: Agency for Healthcare Research and Quality; February 2018. 10.23970/AHRQEPCMETHGUIDE3. https://effectivehealthcare.ahrq.gov/sites/default/files/pdf/methods-guide-quantitative-synthesis-update.pdf Accessed Aug 27 2023.
78 Sterne JA, Sutton AJ, Ioannidis JP, Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. doi: 10.1136/bmj.d4002. PMID: 21784880.21784880
79 Marinho CC V, Worthington HV, Walsh T, Fluoride gels for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2015;2015(6):CD002280. doi: 10.1002/14651858.CD002280.pub2. PMID: 26075879.26075879
80 Marinho VC, Worthington HV, Walsh T, Fluoride varnishes for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2013 Jul 11;(7):CD002279. doi: 10.1002/14651858.CD002279.pub2. PMID: 23846772.23846772
81 Ahovuo-Saloranta A, Forss H, Walsh T, Pit and fissure sealants for preventing dental decay in permanent teeth. Cochrane Database Syst Rev. 2017 Jul 31;7(7):CD001830. doi: 10.1002/14651858.CD001830.pub5. PMID: 28759120.28759120
82 Abadia S. Prevenção da cárie dentária através da aplicaçãotópica de gel de flúor fosfato ácido, utilizando-se isolamentorelativo e absoluto. Baurú (SP): Universidade de São Paulo. 1978.
83 Bijella M. Prevenção da cárie dentária através daaplicação tópica de gel e solução de fuor fosfato acidulado come sem profilaxia prévia. Bauru (SP): Universidadede São Paulo. 1981.
84 Bryan ET, Williams JE. The cariostatic effectiveness of a phosphate-fluoride gel administered annually to school children; final results. J Public Health Dent. 1970;30(1):13–6. doi: 10.1111/j.1752-7325.1970.tb00531.x. PMID: 4149070.4149070
85 Cobb HB, Rozier RG, Bawden JW. A clinical study of the caries preventive effects of an APF solution and APF thixotropic gel. Pediatr Dent. 1980;2(4):263–6. PMID: 6941001.6941001
86 Cons NC, Janerich DT, Senning RS. Albany topical fluoride study. J Am Dent Assoc. 1970;80(4):777–81. doi: 10.14219/jada.archive.1970.0113. PMID: 4392097.4392097
87 DePaola PF, Soparkar M, Van Leeuwen M, The anticaries effect of single and combined topical fluoride systems in school children. Arch Oral Biol. 1980;25(10):649–53. doi: 10.1016/0003-9969(80)90095-3. PMID: 7016089.7016089
88 Englander HR, Keyes PH, Gestwicki M, Clinical anticaries effect of repeated topical sodium fluoride applications by mouthpieces. J Am Dent Assoc. 1967;75(3):638–44. doi: 10.14219/jada.archive.1967.0266. PMID: 4382492.4382492
89 Englander HR, Sherrill LT, Miller BG, Incremental rates of dental caries after repeated topical sodium fluoride applications in children with lifelong consumption of fluoridated water. J Am Dent Assoc. 1971;82(2):354–8. doi: 10.14219/jada.archive.1971.0042. PMID: 4395303.4395303
90 Gisselsson H, Birkhed D, Emilson CG. Effect of professional flossing with NaF or SnF2 gel on approximal caries in 13–16-year-old schoolchildren. Acta Odontol Scand. 1999;57(2):121–5. doi: 10.1080/000163599429020. PMID: 10445367.10445367
91 Hagan PP, Rozier RG, Bawden JW. The caries-preventive effects of full- and half-strength topical acidulated phosphate fluoride. Pediatr Dent. 1985;7(3):185–91. PMID: 3865156.3865156
92 Heifetz SB, Horowitz HS, Driscoll WS. Two-year evaluation of a self-administered procedure for the topical application of acidulated phosphate-fluoride; final report. J Public Health Dent. 1970;30(1):7–12. doi: 10.1111/j.1752-7325.1970.tb00530.x. PMID: 4149071.4149071
93 Horowitz HS, Doyle J. The effect on dental caries of topically applied acidulated phosphate-fluoride: results after three years. J Am Dent Assoc. 1971;82(2):359–65. doi: 10.14219/jada.archive.1971.0063. PMID: 4395304.4395304
94 Horowitz HS, Heifetz SB, McClendon BJ, Evaluation of self-administered prophylaxis and supervised toothbrushing with acidulated phosphate fluoride. Caries Res. 1974;8(1):39–51. doi: 10.1159/000260092. PMID: 4151901.4151901
95 Ingraham RQ, Williams JE. An evaluation of the utility of application and cariostatic effectiveness of phosphate-fluorides in solution and gel states. J Tenn State Dent Assoc. 1970;50(1):5–12. PMID: 4391820.4391820
96 Jiang H, Tai B, Du M, Effect of professional application of APF foam on caries reduction in permanent first molars in 6–7-year-old children: 24-month clinical trial. J Dent. 2005;33(6):469–73. doi: 10.1016/j.jdent.2004.10.023. PMID: 15935266.15935266
97 Mainwaring PJ, Naylor MN. A three-year clinical study to determine the separate and combined caries-inhibiting effects of sodium monofluorophosphate toothpaste and an acidulated phosphate-fluoride gel. Caries Res. 1978;12(4):202–12. doi: 10.1159/000260334. PMID: 356989.356989
98 Marthaler TM, König KG, Mühlemann HR. The effect of a fluoride gel used for supervised toothbrushing 15 or 30 times per year. Helv Odontol Acta. 1970;14(2):67–77. PMID: 4395021.4395021
99 Mestrinho HD, Bijella M, Bijella VT, Prevention of dental caries through topical application of APF gel with plastic trays. Odontologo Moderno. 1983;10(1–2):29–32.
100 Olivier M, Brodeur JM, Simard PL. Efficacy of APF treatments without prior toothcleaning targeted to high-risk children. Community Dent Oral Epidemiol. 1992;20(1):38–42. doi: 10.1111/j.1600-0528.1992.tb00671.x. PMID: 1547611.1547611
101 Ran F, Gedalia I, Fried M, Effectiveness of fortnightly tooth brushing with amine fluorides in caries-prone subjects. J Oral Rehabil. 1991;18(4):311–6. doi: 10.1111/j.1365-2842.1991.tb00062.x. PMID: 1890532.1890532
102 Shern RJ, Duany LF, Senning RS, Clinical study of an amine fluoride gel and acidulated phosphate fluoride gel. Community Dent Oral Epidemiol. 1976;4(4):133–6. doi: 10.1111/j.1600-0528.1976.tb00969.x. PMID: 782777.782777
103 Szwejda LF. Fluorides in community programs; a study of four years of various fluorides applied topically to the teeth of children in fluoridated communities. J Public Health Dent. 1972;32(1):25–33. doi: 10.1111/j.1752-7325.1972.tb03938.x. PMID: 4400348.4400348
104 Trubman A, Crellin JA. Effect on dental caries of self-application of acidulated phosphate fluoride paste and gel. J Am Dent Assoc. 1973;86(1):153–7. doi: 10.1016/S0002-8177(73)61038-0. PMID: 4404788.4404788
105 Truin GJ, van ť Hof MA. Professionally applied fluoride gel in low-caries 10.5-year-olds. J Dent Res. 2005;84(5):418–21. doi: 10.1177/154405910508400504. PMID: CN-00515312.15840776
106 van Rijkom HM, Truin GJ, van ť Hof MA. Caries-inhibiting effect of professional fluoride gel application in low-caries children initially aged 4.5–6.5 years. Caries Res. 2004;38(2):115–23. doi: 10.1159/000075935. PMID: 14767168.14767168
107 Arruda AO, Senthamarai Kannan R, Inglehart MR, Effect of 5% fluoride varnish application on caries among school children in rural Brazil: a randomized controlled trial. Community Dent Oral Epidemiol. 2012;40(3):267–76. doi: 10.1111/j.1600-0528.2011.00656.x. PMID: 22150341.22150341
108 Borutta A, Kunzel W, Rubsam F. [The caries-protective efficacy of 2 fluoride varnishes in a 2-year controlled clinical trial]. Dtsch Zahn Mund Kieferheilkd Zentralbl. 1991;79(7):543–9. PMID: 1756217.1756217
109 Bravo M, Baca P, Llodra JC, A 24-month study comparing sealant and fluoride varnish in caries reduction on different permanent first molar surfaces. J Public Health Dent. 1997;57(3):184–6. doi: 10.1111/j.1752-7325.1997.tb02972.x. PMID: 9383759.9383759
110 Clark DC, Stamm JW, Robert G, Results of a 32-month fluoride varnish study in Sherbrooke and Lac-Megantic, Canada. J Am Dent Assoc. 1985;111(6):949–53. doi: 10.14219/jada.archive.1985.0211. PMID: 3905917.3905917
111 Gugwad SC, Shah P, Lodaya R, Caries prevention effect of intensive application of sodium fluoride varnish in molars in children between age 6 and 7 years. J Contemp Dent Pract. 2011;12(6):408–13. doi: 10.5005/jp-journals-10024-1068. PMID: 22269229.22269229
112 Hardman MC, Davies GM, Duxbury JT, A cluster randomised controlled trial to evaluate the effectiveness of fluoride varnish as a public health measure to reduce caries in children. Caries Res. 2007;41(5):371–6. doi: 10.1159/000104795. PMID: 17713337.17713337
113 Holm GB, Holst K, Mejare I. The caries-preventive effect of a fluoride varnish in the fissures of the first permanent molar. Acta Odontol Scand. 1984;42(4):193–7. doi: 10.3109/00016358408993871. PMID: 6594021.6594021
114 Koch G, Petersson LG. Caries preventive effect of a fluoride-containing varnish (Duraphat) after 1 year's study. Community Dent Oral Epidemiol. 1975;3(6):262–6. doi: 10.1111/j.1600-0528.1975.tb00321.x. PMID: 1059514.1059514
115 Liu BY, Lo EC, Chu CH, Randomized trial on fluorides and sealants for fissure caries prevention. J Dent Res. 2012;91(8):753–8. doi: 10.1177/0022034512452278. PMID: 22736448.22736448
116 Milsom KM, Blinkhorn AS, Walsh T, A cluster-randomized controlled trial: fluoride varnish in school children. J Dent Res. 2011;90(11):1306–11. doi: 10.1177/0022034511422063. PMID: 21921250.21921250
117 Moberg Skold U, Petersson LG, Lith A, Effect of school-based fluoride varnish programmes on approximal caries in adolescents from different caries risk areas. Caries Res. 2005;39(4):273–9. doi: 10.1159/000084833. PMID: 15942186.15942186
118 Modeer T, Twetman S, Bergstrand F. Three-year study of the effect of fluoride varnish (Duraphat) on proximal caries progression in teenagers. Scand J Dent Res. 1984;92(5):400–7. doi: 10.1111/j.1600-0722.1984.tb00908.x. PMID: 6593805.6593805
119 Tagliaferro EP, Pardi V, Ambrosano GM, Occlusal caries prevention in high and low risk schoolchildren. A clinical trial. Am J Dent. 2011;24(2):109–14. PMID: 21698991.21698991
120 Tewari A, Chawla HS, Utreja A. Comparative evaluation of the role of NaF, APF & Duraphat topical fluoride applications in the prevention of dental caries--a 2 1/2 years study. J Indian Soc Pedod Prev Dent. 1991;8(1):28–35. PMID: 2056344.2056344
121 Bojanini J, Garces H, McCune RJ, Effectiveness of pit and fissure sealants in the prevention of caries. J Prev Dent. 1976;3(6):31–4. PMID: 1069846.1069846
122 Bravo M, Montero J, Bravo JJ, Sealant and fluoride varnish in caries: a randomized trial. J Dent Res. 2005;84(12):1138–43. doi: 10.1177/154405910508401209. PMID: 16304443.16304443
123 Brooks JD, Mertz-Fairhurst EJ, Della-Giustina VE, A comparative study of two pit and fissure sealants: two-year results in Augusta, Ga. J Am Dent Assoc. 1979;98(5):722–5. doi: 10.14219/jada.archive.1979.0149. PMID: 374449.374449
124 Charbeneau GT, Dennison JB. Clinical success and potential failure after single application of a pit and fissure sealant: a four-year report. J Am Dent Assoc. 1979;98(4):559–64. doi: 10.14219/jada.archive.1979.0112. PMID: 372286.372286
125 Erdogan B, Alaçam T. Evaluation of a chemically polymerized pit and fissure sealant: results after 4.5 years. J Paediatr Dent. 1987;3:11–3.
126 Hunter PB. A study of pit and fissure sealing in the School Dental Service. N Z Dent J. 1988;84(375):10–2. PMID: 3133616.3133616
127 Liu Y, Rong W, Zhao X, [Caries prevention effect of resin based sealants and glass ionomor sealants]. Chung Hua Kou Chiang Hsueh Tsa Chih. 2014;49(4):199–203. PMID: 24969592.24969592
128 Muller-Bolla M, Lupi-Pegurier L, Bardakjian H, Effectiveness of school-based dental sealant programs among children from low-income backgrounds in France: a pragmatic randomized clinical trial. Community Dent Oral Epidemiol. 2013;41(3):232–41. doi: 10.1111/cdoe.12011. PMID: 23072366.23072366
129 Reisbick MH, Thanos CE, Berson RB, Benefit from sealants in a moderately fluoridated community. CDA J. 1982;10(1):53–6. PMID: 6213312.6213312
130 Richardson AS, Waldman R, Gibson GB, The effectiveness of a chemically polymerized sealant in preventing occlusal caries: two year results. Dent J. 1978;44(6):269–72. PMID: 277401.277401
131 Rock WP, Gordon PH, Bradnock G. The effect of operator variability and patient age on the retention of fissure sealant resin. Br Dent J. 1978;145(3):72–5. doi: 10.1038/sj.bdj.4804121. PMID: 278624.278624
132 Sheykholeslam Z, Houpt M. Clinical effectiveness of an autopolymerized fissure sealant after 2 years. Community Dent Oral Epidemiol. 1978;6(4):181–4. doi: 10.1111/j.1600-0528.1978.tb01146.x. PMID: 278700.278700
133 Songpaisan Y, Bratthall D, Phantumvanit P, Effects of glass ionomer cement, resin-based pit and fissure sealant and HF applications on occlusal caries in a developing country field trial. Community Dent Oral Epidemiol. 1995;23(1):25–9. doi: 10.1111/j.1600-0528.1995.tb00193.x. PMID: 7774173.7774173
134 Tang LH, Shi L, Yuan S, [Effectiveness of 3 different methods in prevention of dental caries in permanent teeth among children]. Shanghai Kou Qiang Yi Xue/Shanghai Journal of Stomatology. 2014;23(6):736–9. PMID: 25636293.25636293
135 Beltran ED, Malvitz DM, Eklund SA. Validity of two methods for assessing oral health status of populations. J Public Health Dent. 1997;57(4):206–14. doi: 10.1111/j.1752-7325.1997.tb02977.x. PMID: 9558624.9558624
136 Aasenden R, DePaola PF, Brudevold F. Effects of daily rinsing and ingestion of fluoride solutions upon dental caries and enamel fluoride. Arch Oral Biol. 1972;17(12):1705–14. doi: 10.1016/0003-9969(72)90233-6. PMID: 4405216.4405216
137 Blinkhorn AS, Downer MC, Mackie IC, Evaluation of a practice based preventive programme for adolescents. Community Dent Oral Epidemiol. 1981;9(6):275–9. doi: 10.1111/j.1600-0528.1981.tb00345.x. PMID: 6955127.6955127
138 DePaola PF, Lax M. The caries-inhibiting effect of acidulated phosphate-fluoride chewable tablets: a two-year double-blind study. J Am Dent Assoc. 1968;76(3):554–7. doi: 10.14219/jada.archive.1968.0065. PMID: 4865754.4865754
139 Driscoll WS, Heifetz SB, Korts DC. Effect of acidulated phosphate-fluoride chewable tablets on dental caries in schoolchildren: results after 30 months. J Am Dent Assoc. 1974;89(1):115–20. doi: 10.14219/jada.archive.1974.0338. PMID: 4151915.4151915
140 Liu HY, Hung HC, Hsiao SY, Impact of 24-month fluoride tablet program on children with disabilities in a non-fluoridated country. Res Dev Disabil. 2013;34(9):2598–605. doi: 10.1016/j.ridd.2013.05.006. PMID: 23747945.23747945
141 O'Rourke CA, Attrill M, Holloway PJ. Cost appraisal of a fluoride tablet programme to Manchester primary schoolchildren. Community Dent Oral Epidemiol. 1988;16(6):341–4. doi: 10.1111/j.1600-0528.1988.tb00578.x. PMID: 3144446.3144446
142 Stephen KW, Campbell D. Caries reduction and cost benefit after 3 years of sucking fluoride tablets daily at school. A double-blind trial. Br Dent J. 1978;144(7):202–6. doi: 10.1038/sj.bdj.4804066. PMID: 416842.416842
143 Rim KH, Jong MC, Hwang CJ, Preventive effect of subacidic 1% NaF-HF gel on dental caries in 6- to 7-year-old schoolchildren: a randomized controlled trial. Quintessence Int. 2021;0(0):318–26. doi: 10.3290/j.qi.b912653. PMID: 33491385.33491385
144 Wang Z, Rong W, Xu T. Effect of Fluoride Varnish in Caries Prevention on Permanent First Molars: a 36-Month Cluster Randomized Controlled Trial. Pediatr Dent. 2021;43(2):82–7. PMID: 33892830.33892830
145 Hesse D, Guglielmi CA B, Raggio DP, Atraumatic Restorative Treatment-Sealed versus Nonsealed First Permanent Molars: a 3-Year Split-Mouth Clinical Trial. Caries Res. 2021;55(1):12–20. doi: 10.1159/000506466. PMID: 33326970.33326970
146 Uzel I, Gurlek C, Kuter B, Caries-Preventive Effect and Retention of Glass-Ionomer and Resin-Based Sealants: a Randomized Clinical Comparative Evaluation. Biomed Res Int. 2022;7205692. doi: 10.1155/2022/7205692. PMID: 35769675.35769675
147 Llodra JC, Rodriguez A, Ferrer B, Efficacy of silver diamine fluoride for caries reduction in primary teeth and first permanent molars of schoolchildren: 36-month clinical trial. J Dent Res. 2005;84(8):721–4. doi: 10.1177/154405910508400807. PMID: 16040729.16040729
148 Alanen P, Isokangas P, Gutmann K. Xylitol candies in caries prevention: results of a field study in Estonian children. Community Dent Oral Epidemiol. 2000;28(3):218–24. doi: 10.1034/j.1600-0528.2000.280308.x. PMID: 10830649.10830649
149 Isokangas P, Alanen P, Tiekso J, Xylitol chewing gum in caries prevention: a field study in children. J Am Dent Assoc. 1988;117(2):315–20. doi: 10.1016/S0002-8177(88)72017-6. PMID: 3166474.3166474
150 Kandelman D, Gagnon G. A 24-month clinical study of the incidence and progression of dental caries in relation to consumption of chewing gum containing xylitol in school preventive programs. J Dent Res. 1990;69(11):1771–5. doi: 10.1177/00220345900690111201. PMID: 2229617.2229617
151 Lee W, Spiekerman C, Heima M, The effectiveness of xylitol in a school-based cluster-randomized clinical trial. Caries Res. 2015;49(1):41–9. doi: 10.1159/000360869. PMID: 25428785.25428785
152 Lenkkeri AM, Pienihakkinen K, Hurme S, The caries-preventive effect of xylitol/maltitol and erythritol/maltitol lozenges: results of a double-blinded, cluster-randomized clinical trial in an area of natural fluoridation. Int J Paediatr Dent. 2012;22(3):180–90. doi: 10.1111/j.1365-263X.2011.01182.x. PMID: 21951305.21951305
153 Machiulskiene V, Nyvad B, Baelum V. Caries preventive effect of sugar-substituted chewing gum. Community Dent Oral Epidemiol. 2001;29(4):278–88. doi: 10.1034/j.1600-0528.2001.290407.x. PMID: 11515642.11515642
154 Scheinin A, Banoczy J. Xylitol and caries: the collaborative WHO oral disease preventive programme in Hungary. Int Dent J. 1985;35(1):50–7. PMID: 3858229.3858229
155 Honkala E, Honkala S, Shyama M, Field trial on caries prevention with xylitol candies among disabled school students. Caries Res. 2006;40(6):508–13. doi: 10.1159/000095650. PMID: 17063022.17063022
156 Kandelman D, Bär A, Hefti A. Collaborative WHO xylitol field study in French Polynesia. I. Baseline prevalence and 32-month caries increment. Caries Res. 1988;22(1):55–62. doi: 10.1159/000261084. PMID: 3422062.3422062
157 Makinen KK, Bennett CA, Hujoel PP, Xylitol chewing gums and caries rates: a 40-month cohort study. J Dent Res. 1995;74(12):1904–13. doi: 10.1177/00220345950740121501. PMID: 8600188.8600188
158 Driscoll WS, Heifetz SB, Korts DC. Effect of chewable fluoride tablets on dental caries in schoolchildren: results after six years of use. J Am Dent Assoc. 1978;97(5):820–4. doi: 10.14219/jada.archive.1978.0402. PMID: 102674.102674
159 Muller-Bolla M, Pierre A, Lupi-Pegurier L, Effectiveness of school-based dental sealant programs among children from low-income backgrounds: a pragmatic randomized clinical trial with a follow-up of 3 years. Community Dent Oral Epidemiol. 2016;44(5):504–11. doi: 10.1111/cdoe.12241. PMID: 27349618.27349618
160 Scheinin A, Bánóczy J, Szöke J, Collaborative WHO xylitol field studies in Hungary. I. Three-year caries activity in institutionalized children. Acta Odontol Scand. 1985;43(6):327–47. doi: 10.3109/00016358509046517. PMID: 3879082.3879082
161 Scheinin A, Pienihakkinen K, Tiekso J, Collaborative WHO xylitol field studies in Hungary. VII. Two-year caries incidence in 976 institutionalized children. Acta Odontol Scand. 1985;43(6):381–7. doi: 10.3109/00016358509046523. PMID: 3879087.3879087
162 Oliveira LM, Pazinatto J, Zanatta FB. Are oral hygiene instructions with aid of plaque-disclosing methods effective in improving self-performed dental plaque control? A systematic review of randomized controlled trials. Int J Dent Hyg. 2021;19(3):239–54. doi: 10.1111/idh.12491. PMID: 33638295.33638295
163 de Silva AM, Hegde S, Akudo Nwagbara B, Community-based population-level interventions for promoting child oral health. Cochrane Database Syst Rev. 2016;9(9):CD009837. doi: 10.1002/14651858.CD009837.pub2. PMID: 27629283.27629283
164 Tsai C, Raphael S, Agnew C, Health promotion interventions to improve oral health of adolescents: A systematic review and meta-analysis. Community Dent Oral Epidemiol. 2020;48(6):549–60. doi: 10.1111/cdoe.12567. PMID: 32767825.32767825
165 Englander HR, Mellberg JR, Engler WO. Observations on dental caries in primary teeth after frequent fluoride toplications in a program involving other preventives. J Dent Res. 1978;57(9–10):855–60. doi: 10.1177/00220345780570090101. PMID: 281356.281356
166 Treide A, Treide B. The anticaries effectiveness of newly developed fluoride-containing gels following 3 years of clinical use in preschool children. Stomatol DDR. 1988;38(10):708–12. PMID: 3269091.3269091
167 Alvarez-Azaustre MP, Greco R, Llena C. Oral Health-Related Quality of Life in Adolescents as Measured with the Child-OIDP Questionnaire: A Systematic Review. Int J Environ Res Public Health. 2021;18(24)doi: 10.3390/ijerph182412995. PMID: 34948611.34948611
168 Moghaddam LF, Vettore MV, Bayani A, The Association of Oral Health Status, demographic characteristics and socioeconomic determinants with Oral health-related quality of life among children: a systematic review and Meta-analysis. BMC Pediatr. 2020;20(1):489. doi: 10.1186/s12887-020-02371-8. PMID: 33092562.33092562
169 Santos PS, Barasuol JC, Moccelini BS, Prevalence of toothache and associated factors in children and adolescents: a systematic review and meta-analysis. Clin Oral Investig. 2022;26(2):1105–19. doi: 10.1007/S00784-021-04255-2. PMID: 34791550.34791550
170 Rebelo MA B, Rebelo Vieira JM, Pereira JV, Does oral health influence school performance and school attendance? A systematic review and meta-analysis. Int J Paediatr Dent. 2018;doi: 10.1111/ipd.12441. PMID: 30367538.30367538
171 Ruff RR, Senthi S, Susser SR, Oral health, academic performance, and school absenteeism in children and adolescents: A systematic review and meta-analysis. J Am Dent Assoc. 2019;150(2):111–21.e4. doi: 10.1016/j.adaj.2018.09.023. PMID: 30473200.30473200
172 Mejare I, Axelsson S, Dahlen G, Caries risk assessment. A systematic review. Acta Odontol Scand. 2014;72(2):81–91. doi: 10.3109/00016357.2013.822548. PMID: 23998481.23998481
173 Ruiz B, Broadbent JM, Murray Thomson W, Is childhood oral health the 'canary in the coal mine' for poor adult general health? Findings from two New Zealand birth cohort studies. Community Dent Oral Epidemiol. 2022. doi: 10.1111/cdoe.12772. PMID: 36000812.36000812
174 Jordan AR, Becker N, Johren HP, Early Childhood Caries and Caries Experience in Permanent Dentition: a 15-year Cohort Study. Swiss Dent J. 2016;126(2):114–9. PMID: CN-01157656.26915485
175 Sathiyakumar T, Vasireddy D, Mondal S. Impact of Sociodemographic Factors on Dental Caries in Children and Availing Fluoride Treatment: A Study Based on National Survey of Children's Health (NSCH) Data 2016–2019. Cureus. 2021;13(9):e18395. doi: 10.7759/cureus.18395. PMID: 34729273.34729273
176 Phipps KR, Ricks TL. Indian Health Service Data Brief: The Oral Health of American Indian and Alaska Native Children Aged 6–9 Years: Results of the 2016–2017 IHS Oral Health Survey. Indian Health Service, April 2017. https://www.ihs.gov/doh/documents/surveillance/Data%20Brief%20IHS%206-9%20Year%20Olds%2003-30-2017.pdf. Accessed Sep 9 2022.
177 Phipps KR, Ricks TL, Mork NP, Indian Health Service Data Brief: The Oral Health of 13–15 Year Old American Indian and Alaska Native (AI/AN) Dental Clinic Patients – A Follow-Up Report to the 2013 Survey Indian Health Service May 2020. https://www.ihs.gov/doh/documents/surveillance/IHS_Data_Brief_Oral_Health_13-15_Year_Old_Follow-Up_to_2013_Survey.pdf. Accessed Sept 9 2022.
178 Maserejian NN, Trachtenberg F, Hayes C, Oral health disparities in children of immigrants: dental caries experience at enrollment and during follow-up in the New England Children's Amalgam Trial. J Public Health Dent. 2008;68(1):14–21. doi: 10.1111/j.1752-7325.2007.00060.x. PMID: 18179466.18179466
179 Nicolau B, Marcenes W, Allison P, The life course approach: explaining the association between height and dental caries in Brazilian adolescents. Community Dent Oral Epidemiol. 2005;33(2):93–8. doi: 10.1111/j.1600-0528.2005.00213.x. PMID: 15725171.15725171
180 Peres MA, de Oliveira Latorre Mdo R, Sheiham A, Social and biological early life influences on severity of dental caries in children aged 6 years. Community Dent Oral Epidemiol. 2005;33(1):53–63. doi: 10.1111/j.1600-0528.2004.00197.x. PMID: 15642047.15642047
181 Whitlock EP, Lin JS, Chou R, Using existing systematic reviews in complex systematic reviews. Ann Intern Med. 2008;148(10):776–82. doi: 10.7326/0003-4819-148-10-200805200-00010. PMID: 18490690.18490690
182 Kashbour W, Gupta P, Worthington HV, Pit and fissure sealants versus fluoride varnishes for preventing dental decay in the permanent teeth of children and adolescents. Cochrane Database Syst Rev. 2020;11(11):Cd003067. doi: 10.1002/14651858.CD003067.pub5. PMID: 33142363.33142363
183 Ruff RR, Niederman R. Silver diamine fluoride versus therapeutic sealants for the arrest and prevention of dental caries in low-income minority children: Study protocol for a cluster randomized controlled trial. Trials. 2018;19(1):523. doi: 10.1186/S13063-018-2891-1. PMID: 30257696.30257696
184 Lewis C, Quinonez R, Sisk B, Incorporating Oral Health into Pediatric Practice: National Trends 2008, 2012, 2018. Acad Pediatr. 2022;22(8):1443–1451. doi: 10.1016/j.acap.2022.06.008. PMID: 35732259.35732259
185 Bernstein RS, Johnston B, Mackay K, Implementation of a primary care physician-led Cavity Clinic using silver diamine fluoride. J Public Health Dent. 2019;79(3):193–7. doi: 10.1111/jphd.12331. PMID: 31389017.31389017
186 Community Preventive Services Task Force. Findings for Oral Health. The Community Guide. 2013. https://www.thecommunityguide.org/content/task-force-findings-oralhealth. Accessed Aug 27 2023.