# Acknowledgements

The authors acknowledge the EPC Research Librarian, Tracy Dana, MLS, for performing the literature searches. The authors also thank the AHRQ Medical Officer, Sheena Harris, MD, MPH; as well as the U.S. Preventive Services Task Force.