# Chapter 4 Discussion

## Summary of Review Findings

Table 5 summarizes the evidence reviewed for this report. Dental caries is common in U.S. children and adolescents 5 to 17 years of age and is often untreated, potentially resulting in adverse oral and other health outcomes. Disparities in oral health, related in part to social determinants, including inadequate access to dental services, suggest a potential role for primary care providers in oral health screening and prevention in this age group. This report updates and expands upon a 1996 USPSTF recommendation on oral health counseling by focusing on oral health screening and prevention in children and adolescents 5 to 17 years of age. It complements other USPSTF reviews on oral health topics, including a concurrent review on oral health screening and prevention in adults^4^ and prior USPSTF reviews on dental caries screening and prevention in children less than 5 years of age ^10^ and on screening for oral cancer.^11^

Table 5 Summary of Evidence - Oral Health in Children and Adolescents Ages 5 to 17 Years

Analytic Framework | Key question | Number of studies (k) participants (n); Study design | Summary of findings by outcome | Consistency/precision Reporting bias | Overall quality | Body of evidence limitations | Strength of evidence | Applicability
Screening | KQ 1; Screening effectiveness | No studies | -- | -- | -- | -- | -- | --
Screening | KQ 2; Screening accuracy; a. In persons who have oral health issues; b. In persons who are at increased risk for future oral health issues | a. k=1 cross-sectional study n=305; b. No studies | Visual screen by registered nurse: sensitivity 0.92 (95% CI 0.84 to 0.97) and specificity 0.993 (95% CI 0.96 to 0.9998) for untreated caries; 17-item questionnaire: sensitivity 0.69 (95% CI 0.60 to 0.77) and specificity 0.88 (95% CI 0.83 to 0.93) for untreated caries | Unable to assess consistency (1 study); Reasonably precise; Reporting bias: Not detected | Fair | Single study with methodological limitations; results unvalidated | Low | Nurses received 5 hours of training; questionnaire based on report by children’s parents or guardians; study conducted in rural setting with high prevalence of untreated caries (35%)
Screening | KQ 3; Screening harms | No studies | -- | -- | -- | -- | -- | --
Prevention | KQ 1; Screening accuracy^*^ (identification of persons at risk for future caries) | No studies | -- | -- | -- | -- | -- | --
Prevention | KQ 2; Behavioral counseling | No studies | -- | -- | -- | -- | -- | --
Prevention | KQ 3 Referral | No studies | -- | -- | -- | -- | -- | --
Prevention | KQ 4; Preventive interventions; Supplements | k=7 trials; N=3,382 | Fluoride supplements were associated with decreased DMFT/DFT increment at 1.5 to 3 years (mean difference −0.73, 95% CI −1.30 to −0.19; 6 trials) when administered in schools under supervision; however, the only trial in which fluoride supplements were administered at home reported low adherence and no benefit (mean difference 0.13, 95% CI −0.38 to 0.64). | Serious inconsistency; No imprecision; Reporting bias: Not suspected | Fair | All trials had methodological limitations; substantial statistical heterogeneity | Low | Supplements administered in school under supervision in all trials except 1; all trials published prior to 1990 except for 1; no trial of adolescents an all trials but 1 focused on children <10 years of age; trials conducted in high caries burden, low socioeconomic status, or low fluoridation settings; six trials conducted in the U.S. or U.K. and 1 trial conducted in Taiwan
Prevention | KQ 4; Preventive interventions; Fluoride gel | k=1 SR (26 trials) and 1 subsequent RCT; N=8,619 (SR) + 986 (subsequent RCT) | A SR found fluoride gels associated DMFT/DFT prevented fraction at outcomes closest to 3 years of 0.32 (95% CI 0.19 to 0.46; I^2^=91% [10 trials, N=3,198]; based on 4 placebo-controlled trials [N=1,525], the prevented fraction was 0.18, 95% CI, 0.09 to 0.27; I^2^=6%). One subsequent trial reported consistent results. | Consistent (based on placebo-controlled trials); No imprecision; Reporting bias: Not suspected | Fair | Most trials had methodological limitations; statistical heterogeneity when all (placebo- and non-placebo-controlled) trials pooled; few placebo-controlled trials | Moderate | 18 trials conducted in the United States, Europe, or Canada; only 1 trial focused on adolescents; gels were applied by dental professional or under supervision and applied in dental clinics or schools; limited reporting of water fluoridation levels and socioeconomic status; most trials conducted in high caries burden settings; 22 trials published prior to 1990
Prevention | KQ 4; Preventive interventions; Fluoride varnish | k=1 SR (14 trials) and 1 subsequent RCT; N=6,965 (SR) + 5,397 (subsequent RCT) | A SR found fluoride varnish associated with DMFS/DFS prevented fraction of 0.43 (95% CI 0.30 to 0.57; 14 trials), DMFT/DFT prevented fraction of 0.44 (95% CI 0.11 to 0.76; 5 trials); and reduced risk of developing ≥1 caries (RR 0.75, 95% CI 0.53 to 1.05; I^2^=89.2%; 5 trials). One subsequent trial reported results consistent with the SR. | Some inconsistency present; No imprecision; Reporting bias: Not suspected | Fair | Most trials had methodological limitations; statistical heterogeneity present | Moderate | 9 trials conducted in Europe (no trials conducted in the United states); no trial focused on adolescents; varnish applied by dental professionals at school or in dental clinics; limited reporting of water fluoridation levels and socioeconomic status; 7 trials published prior to 1998
Prevention | KQ 4; Preventive interventions; Sealants | Resin-based sealant: k=1 SR (15 RCTs); N=4,195 (15 RCTs) and 1 supplemental RCT, n=50; Glass ionomer sealant: k=1 SR (3 RCTs) and 2 subsequent RCTs; N=905 (SR) + 237 (RCTs) | Resin-based sealants: A SR found resin-based sealants associated with decreased risk of carious first molars at 24 months (7 trials, OR 0.12, 95% CI 0.08 to 0.19), 36 months (7 trials, OR 0.17, 95% CI 0.11 to 0.27, I^2^=90%) and 48 to 54 months (4 trials, OR 0.21, 95% CI 0.16 to 0.28, I^2^=45%).; Glass ionomer sealants: A SR (2 trials) and 1 subsequent trial found inconsistent effects of glass ionomer sealants versus no sealants on caries outcomes. | Resin-based sealants: No inconsistency; No imprecision; Glass ionomer sealants: Serious inconsistency; Serious imprecision; Reporting bias (all sealants): Not suspected | Fair | Open-label design; few trials of glass ionomer sealants | Moderate | 9 trials conducted in the U.S., Europe, Canada, or New Zealand; limited information on socioeconomic status and fluoridation levels; higher caries burden settings; variability in sealants evaluated; 10 trials published prior to 1996; sealants applied by dental professionals
Prevention | KQ 4; Preventive interventions; SDF | k=1 RCT; n=452 | SDF associated with fewer new surfaces with active caries in deciduous dentition (mean 0.3 vs. 1.4, p<0.001) and first permanent molars (mean 0.4 vs. 1.1, p<0.001), and decreased likelihood of ≥1 new decayed or filled teeth (26.1% vs. 49.7%, RR 0.52, 95% CI 0.40 to 0.70) | Unable to assess consistency (1 trial); No imprecision; Reporting bias: Not suspected | Fair | One trial with methodological limitations | Low | Trial conducted in Cuba in high caries burden setting in children 6 years of age; training of person administering SDF not reported; children received oral health education and performed fluoride mouth rinses
Prevention | KQ 4; Preventive interventions; Xylitol | k=10 trials; N=4,267 | 1 fair-quality trial found no difference between xylitol versus no xylitol in caries outcomes at 4 years, and one fair-quality trial found no difference between xylitol versus placebo in DMFS increment at 3 years, but decreased DMFS increment versus no xylitol 8 other trials found xylitol associated with reduced DMFS increment versus no xylitol (mean difference −2.38, 95% CI −3.66 to −1.15), but had serious methodological limitations and were rated poor-quality | Some inconsistency; No imprecision; Reporting bias: Not suspected | Fair (based on fair-quality trials) | Only 2 fair-quality trials; potential differences in outcomes based on control type | Low | 6 trials conducted in Europe (no trials in the United States); no trial focused on adolescents; xylitol administered under supervision at school in all trials except 1; four trials published in or prior to 1991; fluoride exposure varied information on SES not provided
Prevention | KQ 5 Harms of preventive interventions | Supplements:; k=1 trial; N=349; Gel:; k=2 trials; N=490; Varnish:; k=6 trials; N=8,574; Sealants:; k=3 trials; N=775; SDF:; k=1 trial; N=452; Xylitol:; k=1 trial; N=296 | Supplements: 1 trial reported no AEs; Gels: No difference between gel versus placebo or no treatment in acute toxicity (nausea, gagging, or vomiting): absolute risk difference 0.01 (95% CI −0.01 to 0.02); Varnish: 5 trials reported no AEs and 1 trial reported 0.04% of children allocated to varnish reported a self-limited AE (most commonly, nausea), with 4 withdrawals due to mild AEs; Sealants: 3 trials of resin-based sealants reported no AEs; SDF: SDF associated with increased likelihood of inactive caries and black stain in deciduous teeth (97% vs. 48%, p<0.001) and first permanent molars (86% vs. 67%, p<0.001); Xylitol: 1 trial reported one withdrawal from xylitol due to diarrhea | Consistency uncertain, due to sparse data; Serious imprecision; Potential reporting bias, as few trials reported harms | Poor | Few trials reported harms or harms reporting was suboptimal | Low | Evidence on harms was very sparse, limiting assessments of applicability

* This is the same as KQ 2b from the screening framework.

Abbreviations: AE = adverse events; CI = confidence interval; DFS = Decayed and Filled Surfaces; DMFS = Decayed, Missing, and Filled Surfaces; DFT = Decayed and Filled Teeth; DMFT = Decayed, Missing, and Filled Teeth; OR = odds ratio; RCT = randomized controlled trial; RR = relative risk; SDF = silver diamine fluoride; SES = socioeconomic status; SR = systematic review; U.K. = United Kingdom; U.S. = United States.

Evidence on screening was very limited. No study compared outcomes of primary care screening versus no screening in this age group. One study^135^ found oral health visual screening by a nurse following 5 hours of training associated with high sensitivity and specificity for untreated caries and a 17-item parent- or guardian-reported questionnaire associated with moderate sensitivity and high specificity for untreated caries, but requires validation. No study evaluated the diagnostic accuracy of primary care screening for identifying children at risk of future oral health issues.

Several oral health preventive interventions improved caries outcomes when administered in school or dental settings. However, evidence demonstrating effectiveness with home or primary care administration was lacking. Fluoride supplements were associated with a small decrease in the DMFT/DFT increment (mean difference <1 affected tooth) in low socioeconomic, non-fluoridated water, or high caries burden settings. However, fluoride supplements were administered in school under supervision in all trials except for one that evaluated home self-administration in older (mean 12.5 years) children that reported low adherence with no benefit.^137^ Fluoride gels, fluoride varnish, and sealants were each associated with improved caries outcomes when administered in schools or in dental clinics. Gels were administered by dental professionals or were self-administered with supervision by a dental or non-dental professional and varnish, and sealants were administered by dental professionals. The prevented caries fraction (defined as the difference in caries increment between intervention and control, divided by control increment) was larger for varnish (0.44^80^) than for gels (0.32 based on all trials and 0.18 based on placebo-controlled trials^79^). Resin-based sealants, which are placed on the occlusive surfaces of permanent molars, strongly reduced the likelihood of developing carious first molars (ORs ranged from 0.12 to 0.21).^81^ Few trials evaluated glass ionomer sealants and results were inconsistent.^81^ One trial found SDF for prevention associated with decreased active caries surfaces in deciduous dentition (mean difference 1.1) and first permanent molars (mean difference 0.7), and decreased likelihood of 1 or more new caries (RR 0.52, 95% CI 0.40 to 0.70);^147^ SDF has primarily been utilized to arrest existing caries.^52^ Evidence on xylitol was difficult to interpret. Although most trials found xylitol improved caries outcomes, six of eight trials were rated poor-quality due to serious methodological limitations (including open-label design, non-randomized design, unclear randomization and allocation concealment, and high attrition). Two fair-quality trials of xylitol either found no benefit of xylitol (versus no xylitol^152^) or reported results that varied depending on the control type (large benefit versus no xylitol but no benefit versus xylitol^153^).

Assessment and reporting of harms of preventive interventions was sparse, although serious harms were not reported. Trials that did report harms typically stated that there were no adverse events, but did not describe methods used to assess harms. No study evaluated the association between exposure to fluoride via oral health preventive interventions in children older than 5 years of age and adolescents and risk of fluorosis. Studies on risks of fluoride exposure have primarily focused on exposure during early childhood, at earlier stages of enamel and neurocognitive development. A challenge in evaluating harms associated with exposure to fluoride is separating outcomes related to fluoride in preventive interventions from other (e.g., environmental, food) sources.

No study compared primary care counseling versus no counseling or primary care referral to a dental professional versus no referral.

## Limitations

There were important limitations in the evidence available to address the benefits and harms of primary care oral health screening and prevention in children and adolescents 5 to 17 years of age. As noted above, there was almost no evidence to assess benefits and harms of oral health screening in this age group. For prevention, there were no studies of primary care counseling versus no counseling or primary care referral to a dental professional versus no referral. Trials of oral health primary care intervention focused on caries outcomes, with no trials reporting effects on quality of life or function (including school performance), or other health outcomes. Trials of oral health primary care interventions had serious methodological limitations, and reporting of harms was very poor. Importantly, several factors may reduce applicability of the available evidence to U.S. primary care practice. First, the preventive interventions were administered by dental professionals or in supervised school settings in almost all trials. One trial of fluoride supplements administered at home (rather than at school under supervision) reported low adherence and no benefit^137^; the effectiveness and feasibility of other oral health preventive interventions administered in primary care settings or without supervision in school is unknown. Second, with the exception of fluoride varnish, few trials of oral health preventive interventions have been published since 2000, which could reduce applicability to current practice, due to differences in oral health behaviors and epidemiology of caries over time. Third, reporting of factors that could affect the effectiveness of oral health preventive interventions such as water fluoridation status, oral health behaviors, and provision of oral health education was suboptimal and inconsistent, making it difficult to understand the context under which trials were conducted.

There were also potential limitations in the review methods. First, we excluded non-English language primary articles, which could result in language bias. However, we did not identify non-English language articles that appeared likely to impact conclusions, and we included systematic reviews that did not have an English language restriction. Second, we did not search for studies published only as abstracts. Third, we were unable to assess for publication bias with graphical or statistical methods for small sample effects, due to small numbers of studies with serious methodological limitations.^78^ Fourth, we utilized previously published systematic reviews, rather than relying exclusively on primary studies. However, the systematic reviews were only utilized if they were assessed as good-quality and the reviews were supplemented with subsequently published primary studies.^181^ Fifth, we did not evaluate the effectiveness of tooth brushing or flossing, as these are performed outside the primary care setting and are routinely recommended. Rather, the review addressed the effectiveness of counseling on oral health, including tooth brushing, flossing and diet. Sixth, meta-analyses conducted on fluoride supplements and xylitol had substantial statistical heterogeneity and the analysis for xylitol included trials with serious methodological limitations. To address statistical heterogeneity, we utilized a random effects model and conducted stratified analyses on study-level factors potentially associated with heterogeneity, including study setting, duration of followup, age category, control type, and baseline caries burden. For xylitol, we focused on the findings of the fair-quality trials and described how they differed from the poor-quality trials. Seventh, we focused on trials comparing oral health preventive interventions versus placebo or no treatment. Head-to-head trials could also be informative, particularly if they compare interventions administered in primary care settings. However, a recent systematic review found insufficient evidence to determine the comparative effectiveness of varnish and sealants administered by dental professionals^182^ and another systematic review found insufficient evidence to determine the comparative effectiveness of resin-based versus glass ionomer sealants.^81^

## Emerging Issues/Next Steps

SDF was cleared for U.S. marketing by the FDA in 2014 as a desensitizing agent in adults.^51^ Although it has been used to arrest existing caries, this use is off-label. Similarly, use of SDF for prevention of caries is also off-label. Two U.S. trials in elementary children older than 5 years of age with SDF for prevention are ongoing; both are designed as head-to-head trials of SDF versus sealants or varnish without a placebo or no treatment control group.^53,183^ A potential disadvantage of SDF is permanent dark discoloration of active caries lesions by the silver component, which may affect acceptability. However, active caries lesions themselves may be discolored, and may result in other cosmetic consequences.

There are also barriers to administration of oral health preventive interventions such as varnish, sealants, or SDF in primary care settings, including the need for additional training and equipment. Even if such interventions are effective in dental settings, the effectiveness, feasibility, acceptability and uptake (by clinicians and patients) for school-age children and adolescents in primary care settings is unknown. There is some evidence of increased uptake in 2018 compared to 2008 of primary care administration of fluoride varnish in younger (<5 years) children,^184^ suggesting feasibility in primary care settings with older children and adolescents. Applying SDF is considered similar technically to applying varnish^50^ and limited evidence indicates that applying SDF in primary care settings is feasible.^185^ Application of sealants is more technically challenging than application of varnish and evidence on implementation by non-dental professionals in primary care settings is lacking. Prior to implementation, it would be important for payers and other stakeholders to clarify reimbursement of primary care clinicians for provision of oral health preventive interventions.

## Relevance for Priority Populations

Disparities among children and adolescents 5 to 17 years of age in oral health have been described with regard to age, race/ethnicity, socioeconomic status, insurance status, health literacy, immigration status, educational level, pregnancy status, and living in rural and urban underserved areas.^20,63,71^ Understanding the independent contribution of these factors to disparities is complicated by marked intersectionality. Limited evidence from subgroup analyses indicated no statistically significant differences in effects of fluoride supplements or fluoride gels based on age (greater or less than 10 years of age) or in effects of fluoride varnish based on time since permanent teeth eruption (greater or less than 2 years),^80^ a proxy for age. Few trials enrolled adolescents (13 to 17 years of age) and there was insufficient evidence to determine how effectiveness of oral health preventive interventions differed in adolescents versus children 5 to 12 years of age. No trial evaluated how effects of oral health preventive interventions varied according to race/ethnicity, socioeconomic status, educational level, insurance status, and other social determinants. Although some trials of oral health preventive interventions were conducted in low socioeconomic status or other under-resourced settings, details regarding socioeconomic status were reported by few trials. A key rationale for primary care oral health screening and prevention is the potential to reduce disparities in oral health outcomes related to access to care or other factors; however, no trial evaluated effects of screening or provision of preventive services in primary care settings.

## Future Research

Research is needed on benefits and harms of primary care screening versus no screening, primary care counseling versus no counseling, and primary care referral to a dental professional versus no referral. Research is needed to determine whether benefits of fluoride gels, fluoride varnish, and sealants observed in dental and school settings are attainable and feasible in current primary care practice. Studies showing effectiveness of SDF for prevention in dental or school settings would support subsequent research of SDF for prevention in primary care settings. Importantly, trials of gels, varnish, sealants, and SDF should describe the training and equipment utilized when they are administered in primary care settings and studies on primary care referral should describe approaches to facilitate coordination between primary care and dentistry, in order to facilitate potential future implementation efforts. Well-conducted trials are needed to clarify effectiveness of fluoride supplements and xylitol, particularly when administered outside of supervised school settings. Trials should report water fluoridation levels, oral health behaviors (e.g., tooth brushing, use of fluoridated toothpaste), provision of oral health education, and baseline oral health status, so that the context in which effective interventions are delivered is better understood. Studies should enroll representative populations, including those disproportionately impacted by poor oral health, and focus on higher prevalence settings (e.g., low socioeconomic status, high oral health burdens, and rural and urban underserved settings). Research is needed on the accuracy of questionnaires that can be used for screening in primary care settings to identify children more likely to have or develop dental caries or periodontal disease. In addition to outcomes related to oral health such as caries burden, trials should assess and report outcomes related to quality of life, social and school performance, function, and other health outcomes, as well as harms.

## Conclusions

Supervised administration of fluoride supplements in schools and administration of fluoride gels, varnish, and sealants in dental or school settings improved caries outcomes. Research is needed on the effectiveness of these oral health preventive interventions when administered at home or in primary care settings, and to determine the accuracy of primary care screening, and the benefits and harms of screening, as well as the effectiveness of primary care counseling, dental referral, and other oral health preventive interventions.