# Chapter 3 Results

A total of 8,677 references from electronic database searches and manual searches of recently published studies were reviewed and 531 full-text papers were evaluated for inclusion. Across all key questions, 3 systematic reviews^79–81^ (total 20,684 participants; of 54 trials [53 publications])^82–134^ and 23 additional studies (in 27 publications)^135–161^; total 15,026 participants) were included (Appendix A3). One study accessed diagnostic accuracy of screening^135^; the systematic reviews^79–81^ and other 22 studies (19 RCTs^136–154^ and three non-randomized trials^155–157^) addressed preventive interventions. Included studies and quality ratings are described in Appendix B.

## Screening Key Questions

### Key Question 1 How Effective Is Screening for Oral Health Performed by a Primary Care Clinician in Preventing Negative Oral Health Outcomes?

No study evaluated the effectiveness of screening versus no screening on oral health outcomes.

### Key Question 2a How Accurate Is Screening for Oral Health Performed by a Primary Care Clinician in Identifying Children and Adolescents Who Have Oral Health Issues?

#### Summary

- For identification of untreated caries in children 5 to 12 years of age, one study found visual screening by a registered nurse (n=219) associated with sensitivity of 0.92 (95% confidence interval [CI] 0.84 to 0.97) and specificity of 0.993 (95% CI 0.96 to 0.9998) and a 17-item questionnaire (n=305) associated with sensitivity of 0.69 (95% CI 0.60 to 0.77) and specificity of 0.88 (95% CI 0.83 to 0.93).
- No study evaluated the diagnostic accuracy of screening for identifying children and adolescents at increased risk for future oral health issues.

#### Evidence

Evidence on the diagnostic accuracy of primary care screening in children and adolescents 5 to 17 years of age was very limited. One study assessed the diagnostic accuracy of screening by a registered nurse for untreated dental caries in children 5 to 12 years of age with high caries burden in a rural setting using a visual screening algorithm or a 17-item questionnaire completed by children’s parents or guardians (Appendix B Table 1).^135^ The reference standard was a full (visual and tactile) examination by a dentist. Nurses received 5 hours of training in addition to written material on the screening procedure and diagnostic criteria. The visual screening algorithm was based on an assessment of the 4 quadrants of the mouth for decayed or restored teeth and associated with a sensitivity of 0.92 (95% CI 0.84 to 0.97) and specificity of 0.993 (95% CI 0.96 to 0.9998) for untreated caries (n=219, prevalence 35.2%) and sensitivity of 0.95 (95% CI 0.91 to 0.98) and specificity of 0.986 (95% CI 0.95 to 0.998) for treated or untreated carious lesions (n=323, prevalence 55.7%). The questionnaire included 17 items on conditions in the child’s mouth, demographic characteristics, and socioeconomic status and was associated with a sensitivity of 0.69 (95% CI 0.60 to 0.77) and specificity of 0.88 (95% CI 0.83 to 0.93) for untreated caries (n=305, prevalence 40.9%). The study was rated fair-quality; methodological limitations include unclear blinding of the reference standard to screening results and unclear use of pre-defined thresholds for the screening questionnaire; in addition, diagnostic accuracy estimates were based on smaller numbers of participants than enrolled, for unclear reasons, and the study did not provide detailed questionnaire items (Appendix B Table 2).

### Key Question 2b How Accurate Is Screening for Oral Health Performed by a Primary Care Clinician in Identifying Children and Adolescents Who Are at Increased Risk for Future Oral Health Issues?

No study evaluated the diagnostic accuracy of primary care screening for identifying children and adolescents 5 to 17 years of age at risk for future oral health issues.

### Key Question 3 What Are the Harms of Screening for Oral Health Performed by a Primary Care Clinician?

No study evaluated harms of primary care screening versus no screening.

## Prevention Key Questions

### Key Question 1 How Accurate Is Screening Performed by a Primary Care Clinician in Identifying Children and Adolescents Who Are at Increased Risk of Future Oral Health Issues?

As described above (prevention Key Question 2b), no study evaluated the accuracy of primary care screening for identifying children at increased risk of future oral health issues.

### Key Question 2 How Effective Is Oral Health Behavioral Counseling Provided by a Primary Care Clinician in Preventing Oral Health Issues?

No study examined the effect of oral health behavioral counseling provided by a primary care clinician on oral health outcomes. While numerous systematic reviews examined oral health counseling or education, the interventions were either provided by dental professionals,^162^ were school-based,^163,164^ were combined with other interventions (such as supervised tooth brushing), were not feasible for a primary care setting (included tests or procedures not utilized in primary care), or reported intermediate outcomes (such as effects on beliefs about oral health and behaviors).

### Key Question 3 How Effective Is Referral by Aa Primary Care Clinician to a Dental Health Care Provider in Preventing Oral Health Issues?

No study evaluated the effect of referral versus no referral to a dental care provider on oral health outcomes.

### Key Question 4 How Effective Are Preventive Interventions in Preventing Oral Health Issues?

#### Summary

##### Supplements

- Fluoride supplements were associated with decreased caries increment in permanent teeth at 1.5 to 3 years based on the DMFT or DFT (six trials, effective N=1,395; mean difference -0.73, 95% CI -1.30 to -0.19) in low socioeconomic, nonfluoridated water, or high caries burden settings, though statistical heterogeneity was substantial (I^2^=80%) and the only trial in which fluoride supplements were self-administered at home (rather than supervised school administration) reported low adherence and no benefit (n=438, mean difference 0.13, 95% CI -0.38 to 0.64).
- One other trial found fluoride supplements associated with decreased caries increment in permanent teeth at 6 years based on the DMFS (n=438, mean difference -2.07, 95% CI -3.16 to -0.97).

##### Fluoride Gel

- A systematic review (26 trials) found application of topical fluoride gels associated with decreased caries burden in permanent teeth at outcomes closest to 3 years (DMFT/DFT prevented fraction based on all trials 0.32, 95% CI 0.19 to 0.46; I^2^=91% [10 trials, N=3,198]; based on four placebo-controlled trials [N=1,525], prevented fraction 0.18, 95% CI, 0.09 to 0.27; I^2^=6%). One subsequent trial reported results consistent with the systematic review.

##### Fluoride Varnish

- A systematic review found fluoride varnish administered by dental professionals associated with decreased caries burden at 1 to 4.5 years based on the DMFS or DFS (14 trials, N=3,419, prevented fraction 0.43, 95% CI 0.30 to 0.57; I^2^=75.2%) or DMFT or DFT (five trials, N=3,902, prevented fraction 0.44, 95% CI 0.11 to 0.76, I^2^=86%), and reduced risk of developing one or more caries that was not statistically significant (five trials, N=3,253; RR 0.75, 95% CI 0.53 to 1.05; I^2^=89.2%). One subsequent trial (n=5,397) reported results consistent with the systematic review.

##### Sealants

- A systematic review found resin-based sealants administered by dental professionals in children 5 to 10 years of age associated with decreased risk of carious first molars at 24 months (seven trials, N=1,322, odds ratio [OR] 0.12, 95% CI 0.08 to 0.19), 36 months (7 trials, N=1,410 children, OR 0.17, 95% CI 0.11 to 0.27, I^2^=90%) and 48 to 54 months (4 trials, N=440 children, OR 0.21, 95% CI 0.16 to 0.28, I^2^=45%). At 24 months, the absolute risk difference ranged from 11 percent to 59 percent. Evidence at longer-term (5 to 9 years) followup was limited but also indicated decreased risk (ORs ranged from 0.31 to 0.45), based on one trial at each time point.
- A systematic review (two trials) and one subsequent trial found inconsistent effects of glass ionomer sealants versus no sealants on caries outcomes.

##### Silver Diamine Fluoride

- One trial (n=452) found SDF administered by dental professionals associated with fewer new surfaces with active caries in the deciduous dentition (mean 0.3 vs. 1.4, p<0.001) and first permanent molars (mean 0.4 vs. 1.1, p<0.001), and decreased likelihood of ≥1 new decayed or filled teeth (26.1% vs. 49.7%, relative risk [RR] 0.52, 95% CI 0.40 to 0.70) in a low fluoridation, high baseline caries burden setting.

##### Xylitol

- One fair-quality trial (n=496) in a low caries burden setting found no difference between xylitol versus no xylitol at 4 years in D_3_MFS increment (mean 2.75 for xylitol for 1 year vs. 3.02 for 2 years vs. 2.74 for no xylitol, p>0.05) or likelihood of D_3_MFS >0. Another fair-quality trial (n=432) in a high baseline caries burden setting found no difference between xylitol versus placebo in DMFS increment at 3 years (mean 8.1 vs. 8.3, p>0.05), but decreased DMFS increment versus no xylitol (mean increment 8.1 vs. 12.4, p<0.05). Xylitol was administered under supervision at school in both trials.
- Eight other trials (effective N=1,646) found xylitol associated with reduced DMFS increment versus no xylitol (mean difference -2.38, 95% CI -3.66 to -1.15), but had serious methodological limitations and were rated poor-quality.

#### Evidence

##### Supplements

Seven trials (reported in eight publications) evaluated dietary fluoride supplements versus placebo or no fluoride supplement in children 5 years of age or older (Appendix B Table 3).^136–142,158^ The number of participants in the trials ranged from 116 to 1,034 (total N=3,382). Three trials were conducted in the United States, three trials in the United Kingdom, and one trial in Taiwan. All trials recruited children from schools and were published prior to 1990 except for one,^140^ which was published in 2013. Four trials were conducted in communities without water fluoridation.^136,138,139^ The other three trials did not report water fluoridation status; of these, two trials^137,142^ were conducted in low socioeconomic status settings and the third^140^ focused on children with disabilities. The mean age of participants was 10 years in one trial and 12.5 years in one trial; in the other trials, the mean age was less than 10 years (range 5.3 to 9.2 years). At baseline, caries prevalence ranged from DMFT or DFT of 1.19 to 4.62, DMFS of 1.07 to 8.58, or dmfs of 3.32 to 3.66 in studies that provided this information. In one trial,^136^ 100 percent of participants were White; otherwise, race or ethnicity was not reported. In three trials, the proportion of participants who were women ranged from 35 percent to 59 percent; gender and sex were otherwise unreported. Fluoride supplements were administered daily as acidulated phosphate fluoride or sodium fluoride tablets. In one trial of older (mean age 12.5 years) children,^137^ fluoride supplements were taken at home; in all other trials fluoride supplements were administered at school under supervision. The duration of followup ranged from 1.5 to 6 years.

All trials had unclear randomization and allocation concealment methods and were rated fair-quality (Appendix B Table 4). Other methodological limitations included open-label design (trials of fluoride versus no fluoride) and high attrition. Two trials were cluster randomized but had no adjustment for clustering.^140,141^

Fluoride supplements were associated with a decreased caries increment compared with placebo or supplement in permanent teeth at 1.5 to 3 years, based on the DMFT or DFT (6 trials, effective N=1,395; mean difference -0.73, 95% CI -1.30 to -0.19; Figure 3); however, statistical heterogeneity was substantial (I^2^=80%).^136–142,158^ Results were similar when one trial^140^ that focused on children with disabilities was excluded (five trials, effective N=1,270; mean difference -0.75, 95% CI -1.47 to -0.09, I^2^=84%). This trial was also published much more recently (2013) than the other trials (published in or before 1988), but reported an estimate for reduction in DMFT increment (one trial, n=125, mean difference -0.63, 95% CI -1.27 to 0.01) that was very similar to the older trials. In a stratified analysis (Table 2), fluoride supplements were not associated with reduced DMFT/DFT increment in one trial^137^ in which fluoride was administered at home (n=178, mean difference 0.13, 95% CI -0.38 to 0.64), whereas all trials in which fluoride supplement were administered at school reported reduced DMFT/DFT increment (five trials, effective N=1,217; range in mean differences -0.38 to -1.64, pooled mean difference -0.88, 95% CI -1.43 to -0.40; I^2^=74%; p for interaction by administration setting=0.15; Figure 4). The trial in which fluoride supplements were administered at home also enrolled the oldest children (mean age 12.5 years, compared with 5.3 to 10 years in the other trials) and reported low adherence, with 15 percent of children randomized to fluoride supplements obtaining scheduled refills during the study. The reduction in DMFT/DFT increment was larger in trials that used a placebo control (four trials, effective N=855; mean difference -0.97, 95% CI -1.69 to -0.32, I^2^=79%)^136,138–140,142,158^ than those that used a no fluoride supplement control (two trials, effective N=540, mean difference -0.32, 95% CI -1.20 to 0.67, I^2^=85%; p for interaction=0.24; Figure 5),^137,141^ and in trials with longer (≥3 years) duration of followup (three trials, effective N=826; mean difference -1.15, 95% CI -1.97 to -0.48, I^2^=81%)^136,141,142^ versus shorter (<3 years) followup (3 trials, effective N=574; mean difference -0.26, 95% CI -0.77 to 0.20, I^2^=48%; p for interaction=0.09; Figure 6).^137,138,140^ However, there was no statistically significant interaction for any of these factors, though stratified analyses were limited by small numbers of trials. There was no difference in estimates when trials were stratified according to mean age 10 years or older (two trials, N=540; mean difference -0.68, 95% CI -2.87 to 1.38, I^2^=92%)^136,137^ or less than 10 years (four trials, effective N=855, mean difference -0.77, 95% CI -1.30 to -0.26, I^2^=73%; p for interaction=0.85).^138,140–142^

Figure 3 Fluoride Supplement vs. No Supplement or Placebo, Caries Increment in Permanent Teeth at 1.5 to 3 Years

Abbreviations: CI = confidence interval; DFT = Decayed and Filled Teeth; DMFS = Decayed, Missing, and Filled Surfaces; DMFT = Decayed, Missing, and Filled Teeth; PL = profile likelihood; SD = standard deviation; UK = United Kingdom; USA = United States of America.

Figure 3 is a forest plot examining fluoride supplement versus no supplement or placebo on caries increment in permanent teeth at 1.5 to 3 years. There are 7 studies, 6 of which are in the DFT/DMFT subgroup and one that is in the DMFS subgroup. The mean difference for the studies in the DFT/DMFT subgroup is -0.73 (95% CI -1.30 to -0.19) with an I-squared value of 80.5%. The mean difference for the study in the DMFS group is -2.07 (95% CI -3.16 to -0.97) with an I-squared value of 0.0%.

Table 2 Fluoride Supplements vs. Placebo or No Supplement, DMFT or DFT Increment

Analysis | Number of trials (effective N)^*^ | Mean difference in DMFT or DFT increment (95% CI) | I^2^ | p for interaction
All trials | 6 (1,395) | −0.73 (−1.30 to −0.19) | 80% | --
Control type | | | | 0.24
• Placebo | 4 (855) | −0.97 (−1.69 to −0.32) | 79% | --
• No fluoride | 2 (540) | −0.32 (−1.20 to 0.67) | 85% | --
Administration setting | | | | 0.15
• School | 5 (1,217) | −0.88 (−1.43 to −0.40) | 74% | --
• Home | 1 (178) | 0.13 (−0.38 to 0.64) | -- | --
Age category | | | | 0.85
• Mean <10 years | 4 (855) | −0.77 (−1.30 to −0.26) | 73% | --
• Mean ≥10 years | 2 (540) | −0.68 (−2.87 to 1.38) | 92% | --
Duration of follow-up | | | | 0.09
• <3 years | 3 (569) | −0.26 (−0.77 to 0.20) | 48% | --
• ≥3 years | 3 (826) | −1.15 (−1.97 to −0.48) | 81% | --

* After adjustment for clustering (assuming intracluster correlation=0.02).

Abbreviations: CI = confidence interval; DFT = Decayed, Filled Teeth; DMFT = Decayed, Missing, and Filled Teeth.

Figure 4 Fluoride Supplement vs. No Supplement or Placebo, DMFT/DFT Increment, Stratified by Administration Setting

Abbreviations: CI = confidence interval; DFT = Decayed and Filled Teeth; DMFT = Decayed, Missing, and Filled Teeth; PL = profile likelihood; SD = standard deviation; UK = United Kingdom; USA = United States of America.

Figure 4 is a forest plot examining fluoride supplement versus no supplement or placebo on DMFT/DFT increment, stratified by administration setting. There are 6 studies, 5 of which are in the School subgroup and one in the Home subgroup. The mean difference for the studies in the School subgroup is -0.88 (95% CI -1.43 to -0.40) with an I-squared value of 73.7%. The mean difference for the study in the Home subgroup is 0.13 (95% CI -0.38 to 0.64) with an I-squared value of 0.0%. The overall mean difference is -0.73 (95% CI -1.30 to -0.19) with an I-squared value of 80.5%.

Figure 5 Fluoride Supplement vs. No Supplement or Placebo, DMFT/DFT Increment, Stratified by Control Type

Abbreviations: CI = confidence interval; DFT = Decayed and Filled Teeth; DMFT = Decayed, Missing, and Filled Teeth; PL = profile likelihood; SD = standard deviation; UK = United Kingdom; USA = United States of America.

Figure 5 is a forest plot examining fluoride supplement versus no supplement or placebo on DMFT/DFT increment, stratified by control type. There are 6 studies, 4 of which are in the Placebo subgroup and two in the No fluoride subgroup. The mean difference for the studies in the Placebo subgroup is -0.97 (95% CI -1.69 to -0.32) with an I-squared value of 78.7%. The mean difference for the studies in the No fluoride subgroup is -0.32 (95% CI -1.20 to 0.67) with an I-squared value of 85.3%. The overall mean difference is -0.73 (95% CI -1.30 to -0.19) with an I-squared value of 80.5%.

Figure 6 Fluoride Supplement vs. No Supplement or Placebo, DMFT/DFT Increment, Stratified by Duration of Followup

Abbreviations: CI = confidence interval; DFT = Decayed and Filled Teeth; DMFT = Decayed, Missing, and Filled Teeth; PL = profile likelihood; SD = standard deviation; UK = United Kingdom; USA = United States of America.

Figure 6 is a forest plot examining fluoride supplement versus no supplement or placebo on DMFT/DFT increment, stratified by duration of followup. There are 6 studies, 3 of which are in the less than 3 years subgroup and 3 in the greater than or equal to 3 years subgroup. The mean difference for the studies in the less than 3 years subgroup is -0.26 (95% CI -0.77 to 0.20) with an I-squared value of 48.4%. The mean difference for the studies in the greater than or equal to 3 years subgroup is -1.15 (95% CI -1.97 to -0.48) with an I-squared value of 80.7%. The overall mean difference is -0.73 (95% CI -1.30 to -0.19) with an I-squared value of 80.5%.

One trial reported caries burden based on the number of affected tooth surfaces and was not pooled with the others, which reported caries burden based on number of affected teeth. It found fluoride supplements associated with reduced DMFS increment (n=438, mean difference -2.07, 95% CI -3.16 to -0.97).^139^

##### Fluoride Gel

One systematic review^79^ and one subsequent trial^143^ (not included in the systematic review) evaluated fluoride gels versus placebo or no gel in children 5 years of age or older.

The systematic review (searches conducted through November 2014) was rated good-quality (Appendix B Table 5) and included 26 randomized or quasi-randomized trials^82–106^ (in 25 publications; one publication was considered two studies^98^) of fluoride gels versus placebo or no treatment in children 5 years of age or older. Two other trials in the review evaluated children under 5 years of age and are not discussed further.^165,166^ Across the trials, sample sizes ranged from 41 to 732 (total N=8,619; Appendix B Table 6). Fluoride gel was administered as acidulated phosphate fluoride (APF; 12,300 parts per million F) in 20 trials; other formulations were sodium fluoride (NaF, 12,500 parts per million F), amine fluoride (AmF, 12,500 parts per million [ppm] F) or stannous fluoride (SnF_2_, 2,425 ppm F). Gels were applied using a tray (19 trials), brush (6 trials), or floss (1 trial). Fluoride gels were compared against placebo in 16 trials and against no gel in 10 trials. In 15 trials, fluoride gels were applied by a dental professional (frequency 1 to 4 times per year); in 11 trials, gels were self-applied (mostly 5 times per year) with supervision by a dental hygienist or other (non-dental professional) adult. In seven trials, gels were applied at a dental clinic (including school dental clinics); nineteen trials reported administration of the gel at school. Ages at enrollment ranged from 5 to 15 years. Twelve trials focused primarily on children less than 10 years of age and 12 trials focused on children 10 years of age or older; one trial included children with an average age of 10.5 years,^105^ and one trial included children exclusively 13 years of age or older.^90^ In the trials with self-applied fluoride gels, mean ages ranged from 7 to 13 years. In 24 trials that provided baseline information on caries burden in permanent teeth, mean DMFS or ranged from 0 to 12.2, with 11 trials reporting DMFS of 3 or less. Twelve trials were conducted in the United States, six trials in Europe, four in Brazil, and one each in Canada, Israel, China and Venezuela. Two trials^105,106^ exclusively recruited participants from clinics; all other trials recruited participants from schools. Five trials were published from 1990 to 2005 (three in or after 2000); the other trials were published between 1967 and 1988. Two trials reported adequate exposure of children to fluoride through drinking water at 1.0 ppm fluoride^89^ or an undefined level,^103^ nine trials reported exposure to fluoride toothpaste, and two trials reported that children received fluoride tablets. One trial reported that all children received oral health education;^106^ otherwise provision of oral health education was not described. Among trials that described socioeconomic status, one trial in the United States^87^ and one trial in Israel^101^ evaluated a low socioeconomic status population, two trials reported low socioeconomic status in 20 to 30 percent of participants,^96,106^ and one trial was conducted in a high socioeconomic status population.^98^

Of the trials in the systematic review, one^96^ was cluster randomized (by school class) and the others were individually randomized. One trial was assessed as having unclear risk of reporting bias, but was otherwise assessed as being at low risk of bias.^105^ In the other trials, common methodological limitations included use of a quasi-randomized design (seven trials),^82,83,90,92–94,99^ unclear randomization or allocation concealment methods (19 trials), open-label (including trials that utilized a no treatment control) design (10 trials), and high attrition (14 trials).

One additional trial (n=986) not included in the systematic review evaluated 1% sodium fluoride and hydrofluoric acid (NaF-HF) gel versus placebo administered by dental hygienists via trays in school settings in children 6 to 7 years of age at baseline in a nonfluoridated setting in North Korea (drinking water fluoride concentration <0.1 ppm F) (Appendix B Table 7).^143^ All children received oral health education. The trial was rated good-quality (Appendix B Table 8).

The systematic review found fluoride gels associated with decreased risk of caries burden in permanent teeth at outcomes reported closest to 3 years, based on the DFT or DMFT (10 trials, N=3,198, prevented fraction 0.32, 95% CI 0.19 to 0.46 [prevented fraction is the difference in increment between the control and intervention groups, divided by the control group increment]). There was marked statistical heterogeneity (I^2^=91%), which could be explained by control type. The prevented fraction was lower in four trials that used a placebo control (N=1,525, prevented fraction 0.18, 95% CI, 0.09 to 0.27) with very low statistical heterogeneity (I^2^=6%). In six trials (N=1,673) that utilized a no treatment control, the prevented fraction was 0.43 (95% CI 0.29 to 0.57, I^2^=90%). Findings were similar in analyses for caries burden on affected permanent tooth surfaces at outcomes closest to 3 years, based on the DFS or DMFS (overall: 25 trials, N=8,479, prevented fraction 0.28, 95% CI 0.19 to 0.36, I^2^=82%; placebo control: 15 trials, N=5,671, prevented fraction 0.21, 95% CI 0.15 to 0.28, I^2^=38%; no treatment control: 10 trials, N=2,808, prevented fraction 0.38, 95% CI 0.24 to 0.52, I^2^=86%). The prevented fraction of 0.28 corresponded to a difference in DMF/DMFS increment of 0.27 (95% CI 0.18 to 0.37). The systematic review did not perform an analysis stratified by age; we conducted a supplemental analysis of data reported in the systematic review that found pooled estimates were similar when placebo-controlled trials were stratified according to mean age 10 years of age and older (six trials, N=2,039; DMFS or DFS prevented fraction 0.19, 95% CI 0.07 to 0.30, I^2^=53%) or younger than 10 years of age (nine trials, N=3,632; DMFS or DFS prevented fraction 0.23, 95% CI 0.13 to 0.33, I^2^=31%; Figure 7). One trial of children 13 years or older (n=280) reported a prevented DMFS fraction at 3 years of 0.12 (95% CI -0.32 to 0.56); fluoride gel was associated with decreased likelihood of developing one or more new carious lesions (RR 0.82, 95% CI 0.68 to 0.99).^90^

Figure 7 Fluoride Gel vs. Placebo, DMFS/DFS Prevented Fraction, Stratified by Age ≥10 Years vs. <10 Years

Abbreviations: CI = confidence interval; DFS = Decayed and Filled Surfaces; DMFS = Decayed, Missing, and Filled Surfaces; PL = profile likelihood

Figure 7 is a forest plot examining fluoride gel versus placebo on DMFS/DFS prevented fraction, stratified by age greater than or equal to 10 years versus less than 10 years. There are 15 studies, 6 of which are in the greater than or equal to age 10 years subgroup and 9 in the less than age 10 years subgroup. The mean difference for the studies in the greater than or equal to age 10 years subgroup is 0.19 (95% CI 0.07 to 0.30) with an I-squared value of 53.2%. The mean difference for the studies in the less than age 10 years subgroup is 0.23 (95% CI 0.13 to 0.33) with an I-squared value of 31.1%. The overall mean difference is 0.21 (95% CI 0.14 to 0.28) with an I-squared value of 38.1%.

The systematic review found no subgroup differences in effects of fluoride gels on DFS/DMFS prevented fraction (the most commonly reported outcome) according to baseline levels of caries (p for interaction=0.27); exposure to fluoridated water (p for interaction=0.68), fluoride toothpaste (p for interaction=0.23), or any background fluoride (p for interaction=0.16); whether gels were professionally or self-applied (p for interaction=0.31); method of administration (tray, paint/brush or floss; p for interaction=0.71); frequency of gel applications (greater or less than twice yearly; p for interaction=0.42); fluoride gel concentration (greater or less than 10,000 ppm F); duration of followup (years; p=0.65); receipt of prior prophylaxis (p for interaction=0.75); and dropout rate (p for interaction=0.82).

A sensitivity analysis in which trials at high risk of bias due to allocation concealment were excluded provided results similar to the overall pooled estimate for prevented DMS/DMFS fraction; however, the prevented DMS/DMFS fraction was lower than the overall pooled estimate (and similar to the estimate for placebo-controlled trials) in a sensitivity analysis in which trials at high or unclear risk for blinding of outcome assessment were excluded (prevented fraction 0.22, 95% CI 0.16 to 0.29; I^2^=75%).

A subsequent randomized trial (n=986) reported results consistent with the systematic review (Appendix B Table 7).^143^ The trial found a newly developed subacidic fluoride gel (1% NaF-HF) associated with decreased caries burden in the first permanent molar (D_1_MFT) or second permanent molar (D_2_MFT) in children 6 to 7 years of age when administered as a single application, two applications 7 days apart, or two applications 6 months apart. At 1 year, the prevented fraction was 0.34 to 0.64 for D_1_MFT and 0.56 to 0.88 for D_2_MFT (p<0.001 for all fluoride gel groups versus placebo for both outcomes). The caries increment in the third molars (D_3_MFT) was very small (0.08 in the placebo group, compared with 0.56 for D_1_MFT and 0.50 for D_2_MFT), with no difference between fluoride gel versus placebo (p=0.20).

##### Fluoride Varnish

A systematic review^80^ and one subsequent trial^144^ (not included in the systematic review) evaluated fluoride varnish versus placebo or no varnish in children 5 years of age or older. The systematic review (searches conducted through May 2013) was rated good-quality (Appendix B Table 9) and included 22 trials of fluoride varnish versus placebo or no varnish; however, eight trials evaluated children under 5 years of age and are outside the scope this report. Across the remaining 14 trials, sample sizes ranged from 95 to 2,604 (total N=6,965, Appendix B Table 10). Children were 5 to 12 years of age at baseline in nine trials, and 12 to 15 years of age in four trials^108,114,117,118^; one study^107^ included children from 7 to 14 years of age. Children were recruited from schools in nine trials^107–110,112,115–117,119^; recruitment settings were not described in five trials.^111,113,114,118,120^ The duration of followup ranged from 1 to 4.5 years. Four trials were conducted in Sweden,^113,114,117,118^ two trials each in Brazil,^107,119^ India,^111,120^ and the United Kingdom.,^112,116^ and one trial each in Canada,^110^ China,^115^ Germany,^108^ and Spain.^109^ Mean DMFS ranged from 0.37 to 2.44 (five trials) and mean DMFT ranged from 0.3 to 1.93 (five trials) among children 12 and under. In children over 12 years, two trials reported mean DMFS of 6.15 and 29.2. Two trials focused on children in low socioeconomic status settings^107,112^ and the other trials included children from various socioeconomic status settings or did not report socioeconomic status. Information on race/ethnicity was not reported. Four trials were published prior to 1990,^110,113,114,118^ three between 1990 and 1997,^108,109,120^ and seven^107,111,112,115–117,119^ between 2005 and 2012.

Fluoride varnish was most commonly administered as 5 percent sodium fluoride varnish (22,600 parts per million) every six months. One trial applied varnish as either 22,600 or 56,300 ppm fluoride two or four times per year,^108^ one trial applied either 7,000 or 22,600 ppm fluoride every six months, one trial applied 22,600 ppm fluoride three times in one week,^111^ and one trial administered 22,600 ppm fluoride two, three, or eight times^117^ per year. In all trials, fluoride varnish was applied by dentists, dental nurses, or dental hygienists in school or at local clinics. Fluoride varnish was compared against placebo in four trials^108,110,115,120^ and against no treatment in ten trials. One trial^108^ reported that children had no background fluoride exposure; seven trials reported exposure to fluoridated drinking water ranging from 0.24 ppm to 0.9 ppm, with 3 trials at least 0.07 ppm, and nine reported fluoride exposure through toothpaste, or a community fluoride rinsing program. Four trials^107,111,115,119^ provided oral health education to all children in the experimental and control groups; otherwise, information on oral health education was not reported. Four trials blinded fluoride providers and participants to treatment^107,108,110,120^ and the others were open-label or did not provide information on blinding. Three trials were cluster-randomized at the school level,^109,112,116^ four were adequately randomized at the individual participant level,^111,112,115,116,118,120^ and eight trials did not adequately randomize participants or randomization methods were unclear.^107,108,110,113,114,117,119^ Other methodological limitations in the trials noted by the systematic review included unclear or inadequate allocation concealment methods (79% of trials) and important between-group baseline differences (21% of trials).

One additional cluster-randomized trial^144^ (n=5,397) published after the systematic review compared 5 percent fluoride varnish every six months to no treatment in 6 and 7 year old children in rural China (Appendix B Table 11). Community water contained less than 0.2 mg/L fluoride. Fluoride was applied by dentists in a school setting. All children and their parents in both treatment and control groups received oral health education annually, and children received toothbrushes and fluoride toothpaste. The proportion of children with caries in primary teeth was high (86%); the caries burden in permanent teeth at baseline was low (mean DFS 0.035), due to the young age of children in the trial. The trial used an open-label design and was rated fair-quality (Appendix B Table 12).

Among children 5 years of age or older, the systematic review found fluoride varnish associated with reduced caries burden in permanent teeth at one to 4.5 years, based on the number of affected surfaces (14 trials, N=3,419, prevented DMFS/DFS fraction 0.43, 95% CI 0.30 to 0.57), though statistical heterogeneity was present (I^2^=75.2%). Based on the range of caries increments observed in the control groups, the pooled prevented fraction would correspond to an absolute reduction in DMFS or DFS increment of 0.07 to 3.32. There was no interaction between baseline caries severity (p for interaction=0.18); background exposure to fluoridated water (p for interaction=0.22), fluoride toothpaste (p for interaction=0.41), or any fluoride source (p for interaction 0.66); fluoride varnish concentration 5% or greater (p for interaction=0.28); followup duration (p for interaction=0.42); prior varnish exposure (p for interaction=0.18); application more than 2 times per year (p for interaction=0.59); time since permanent teeth eruption (less or greater than 2 years; p for interaction=0.82); control type (placebo or no varnish; p for interaction=0.76); or use of individual versus cluster randomization (p for interaction=0.13) and effects of fluoride varnish on caries increment. Fluoride varnish was also associated with reduced caries burden in permanent teeth at 1 to 3 years, based on the number of affected teeth (five trials, N=3,902, DMFT or DFT prevented fraction 0.44, 95% CI 0.11 to 0.76, I^2^=86%), and with a non-statistically significant reduced risk of developing one or more caries (five trials, N=3,253; RR 0.75, 95% CI 0.53 to 1.05; I^2^=89.2%).

The systematic review also included three trials of children 6 to 8 years of age that reported the association between use of fluoride varnish and caries burden in primary teeth. Two trials found fluoride varnish associated with reduced caries burden in primary teeth (prevented dmfs or dfs fraction 0.2, 95% CI 0.02 to 0.38^110^ and 2.12, 95% CI 0.23 to 4.01^111^), and one trial found no association (prevented dmfs fraction –0.02, 95% CI –0.39 to 0.35^112^). The latter trial^112^ also found no association between use of fluoride varnish and likelihood of developing one or more carious lesions in primary teeth (n=282; RR 1.06, 95% CI 0.84 to 1.33).

One cluster-randomized trial^144^ published subsequent to the systematic review compared 5 percent fluoride varnish every six months to no treatment in 6 and 7 year old children not exposed to fluoridated water in rural China (n=5,397). Results were consistent with the systematic review in finding fluoride varnish associated with reduced caries burden of permanent teeth at three years (DFS in first molar 0.41 vs. 0.64 at 24 months, p<0.001 and 0.67 vs. 1.03 at 36 months, p<0.001).

##### Sealants

A systematic review^81^ and two subsequent trials^145,146^ (not included in the systematic review) evaluated sealants versus no sealants in children 5 years of age or older. One additional study^159^ not in the review reported longer duration followup for a trial included in the systematic review. The systematic review (searches conducted through August 2016) was rated good-quality (Appendix B Table 13) and included 16 trials of a sealant versus no sealant^81^ (Appendix B Table 14). Fifteen trials (N=4,195 participants) evaluated a resin-based sealant, and three trials (N=905 participants) evaluated a glass ionomer sealant (two trials evaluated both a resin-based and glass ionomer sealant). For resin-based sealants, the systematic review included 10 trials of an autopolymerized sealant, one trial of a light-polymerized resin sealant without fluoride, and four trials of a light-polymerized resin sealant with fluoride (first-generation resin based sealants were excluded). For glass ionomer sealants, the systematic review included one trial each of an autopolymerized low viscosity sealant, a light-cured low-viscosity sealant, and a resin-modified sealant. In all trials, children were recruited from schools. Children were 6 to 10 years of age at baseline in all trials except for one,^133^ in which baseline age was 12 to 13 years. In six studies that provided information on baseline caries prevalence, mean dft or dmft ranged from 2.24 to 5.38 in five trials of children 5 to 10 years of age^115,119,122,127,128^ and one trial^133^ reported a mean DMFT of 1.81 in children 12 to 13 years of age. Four trials were conducted in the United States or Canada, three trials in China, four trials in Europe, and one trial each in Brazil, Colombia, New Zealand, and Thailand. Two trials focused on children in low socioeconomic status settings;^128,133^ the other trials did not focus on low socioeconomic status settings or did not report socioeconomic status. Five trials were published between 2011 and 2014, one trial was published in 2005, and 10 trials were published between 1976 and 1995.

In all trials, sealants were applied to occlusal surfaces of permanent premolar or molar teeth by dentists or other dental professionals, except for one trial^133^ in which sealants were administered by dentists or schoolteachers with 3 days of training. Sealants were applied to sound surfaces or on enamel lesions (e.g., ICDAS II scale 0 to 3). Settings for sealant administration were school dental clinics, office-based dental clinics, or mobile dental settings (e.g., vans). One trial^119^ was conducted in a setting with tap water fluoridation level of 0.7 ppm F, three trials reported that they were conducted in settings with fluoridated tap water but did not report the level,^121,123,132^ one trial reported mixed fluoridation status (five schools in fluoridated towns and five in non-fluoridated towns),^126^ and the other trials reported community fluoridation levels <0.7 ppm or did not provide information regarding fluoridation levels. Two trials reported that all children received oral health education^128,134^; information on oral health education was otherwise not reported. The trials were unable to effectively blind outcome assessors because sealant materials are visible; other methodological limitations in the trials noted by the systematic review included unclear or inadequate randomization (33% of trials) and unclear allocation concealment methods (37% of trials). Attrition was unclear or high in one of seven trials at 12 months followup, one of nine trials at 24 months, two of seven trials at 36 months, and three of five trials at 48 to 54 months. One trial with 60 months of followup reported low attrition and the only trials that reported outcomes at 72 and 84 months had high attrition.

Two additional trials were not included in the systematic review (Appendix B Tables 15 and 16).^145,146^ One trial (n=187) evaluated an autopolymerized glass ionomer sealant versus no sealant administered by a dentist to children 6 to 8 years of age in a low-income, fluoridated water (to 0.7 mg/L) setting in Brazil.^145^ The trial was rated fair-quality; in addition to open-label design, it also had unclear allocation concealment methods. Another trial conducted in a pediatric dentistry clinic in Turkey (n=50 children, 200 molars) utilized a randomized, split mouth technique comparing two types of resin fissure sealants versus a glass-ionomer cement sealant versus no sealant to children between 7 and 12 years of age with a baseline mean DMFT of 0.08.^146^ The trial was rated fair-quality. One additional publication^159^ reported 3-year followup of a trial of a light-polymerized resin-based sealant with fluoride, for which 1-year data were included in the systematic review.

Among children 5 to 10 years of age, the systematic review found resin-based sealants associated with decreased risk of carious first molars at 24 months (seven trials, N=1,322, OR 0.12, 95% CI 0.08 to 0.19, I^2^=72%). Although statistical heterogeneity was present, estimates favored sealants in all trials; ORs ranged from 0.06 to 0.32 in the trials. The proportion of patients that developed carious first lesions in the no sealant arms of the trials ranged from 16 percent to 70 percent in the trials; based on the pooled estimate, the absolute risk difference ranged from 11 percent to 51 percent. There was no interaction between study design (parallel-group versus split-mouth) and effects on likelihood of caries. Findings were similar at 36 months (seven trials, N=1,410, OR 0.17, 95% CI 0.11 to 0.27, I^2^=90%) and at 48 to 54 months (four trials, N=440, OR 0.21, 95% CI 0.16 to 0.28, I^2^=45%). The subsequent study^159^ reporting longer duration (3-year) followup for a trial included in the systematic review reported results consistent with the review’s 3-year pooled estimate (adjusted hazard ratio [HR] 0.33, 95% CI 0.24 to 0.46). An additional, subsequent study also found consistent results with fewer caries in those who received the resin-based sealant (3.0% to 9.4%) than those without sealants (25.7%) after 18 months (RR 0.24, 95% CI 0.08 to 0.72).^146^

Evidence on risk of caries at longer-term followup was limited, with one trial finding a resin-based sealant associated with decreased risk of caries at 5 years (n=165, OR 0.31, 95% CI 0.23 to 0.43),^130^ 7 years (n=67, OR 0.45, 95% 0.34 to 0.59),^123^ and 9 years (n=120, OR 0.35, 95% CI 0.22 to 0.55).^122^ One trial found resin-based sealants associated with reduction in caries burden at 24 months based on the DFS increment (n=671, mean difference -0.65, 95% CI -0.83 to -0.47).^133^

Evidence on effectiveness of resin-based sealants among children >10 years of age was limited to one trial that found resin-based sealants compared with no treatment associated with decreased change from baseline in DMFS index among children 12 to 13 years of age at baseline (n=671, mean difference -0.24, 95% CI -0.36 to -0.12).^133^ There was insufficient evidence to determine how effects of sealants varied according to sex, race/ethnicity, socioeconomic status and other social determinants, because studies did not report analyses stratified according to these factors. There was also insufficient evidence to determine how community water fluoridation levels or use of oral health education impacted effectiveness of sealants, because most trials did not report these factors.

Evidence on the effectiveness of glass ionomer sealants versus placebo was limited and somewhat inconsistent. At 24 months, the systematic review included one trial that found a glass ionomer sealant associated with decreased likelihood of carious first molars (n=372, OR 0.46, 95% CI 0.23 to 0.91)^127^; however, another trial in the systematic review found a very small, non-statistically significant difference in DFS increment (n=404, mean difference -0.18, 95% CI -0.39 to 0.03).^133^ In the latter trial, effects of glass ionomer sealants were very similar when administered by a dentist or by a schoolteacher with 3 hours of training. One subsequent trial also found no difference between a glass ionomer sealant versus no sealant in risk of carious first molars at 3 years (n=187, HR 0.90, 95% CI 0.55 to 1.49).^145^ However, another subsequent trial found fewer caries associated with glass ionomer cement sealants versus no sealants (3.0% versus 25.7%) after 18 months (RR 0.12, 95% CI 0.02 to 0.88).^146^

##### Silver Diamine Fluoride

One trial (n=452) evaluated SDF solution for prevention of caries in children older than 5 years of age (Appendix B Table 17).^147^ The trial enrolled 6 year old schoolchildren (mean age 6.3 years) in a low community fluoridation setting (0.09 ppm F) with high baseline caries burden (mean dmfs 3.6) in Cuba. Children were randomized to 38 percent SDF solution applied to primary canines and occlusal surfaces of molars and first permanent molars every 6 months for 36 months versus no SDF. The trial did not report how persons administering SDF were trained; all children received oral health education (tooth brushing instruction and dietary recommendations) and received mouth rinses every 2 weeks with 0.2 percent sodium fluoride. The trial was rated fair-quality; methodological limitations included unclear randomization and allocation concealment methods and unclear blinding of persons administering SDF (Appendix B Table 18).

At 36 months, SDF was associated with fewer new surfaces with active caries in the deciduous dentition (mean 0.3 vs. 1.4, p<0.001), fewer surfaces with active caries (decayed or filled surfaces) in first permanent molars (mean 0.4 vs. 1.1, p<0.001), and decreased likelihood of experiencing at least 1 new decayed or filled tooth (26.1% vs. 49.7%, RR 0.52, 95% CI 0.40 to 0.70).

##### Xylitol

Ten trials evaluated xylitol versus no xylitol in children five years of age or older (Appendix B Table 19).^148–157,160,161^ Sample sizes ranged from 145 to 976 (total N=4,267).Two trials were conducted in Finland and one each in Lithuania, Estonia, Hungary, Kuwait, French Polynesia, Canada, Belize, and the United States. At baseline, mean age was under 10 years in four trials^150,151,154,156^ and 10 years of age or older in five trials.^148,149,152,153,155,157^ No trial reported mean age of participants of 13 years or older; one trial included participants up to 27 years, with 12 percent between 19 and 27 years of age (mean age not reported).^155^ Two trials evaluated children with low baseline caries burden (based on mean DMFS 2.10 or 82.7% with D3MFS=0).^148,152^ One trial^154^ recruited children from an institutional children’s home and one trial^155^ recruited children from a school for those with physical disabilities; all other trials recruited children through local schools. Xylitol was administered as a candy, gum, lozenge, or lollipop in concentrations that ranged from 49 percent to 64.7 percent xylitol; xylitol was typically administered three to five times per day^148–150,155^ and total daily xylitol dose ranged from 4.3 to 20 grams.^151,154,156^ One trial compared xylitol candy versus placebo (non-xylitol) candy^151^ and one trial compared xylitol versus no xylitol or a placebo gum^153^; in all other trials the control was no xylitol (without placebo). Xylitol was distributed and administered under supervision at school or in the child’s institution by teachers or school nurses in all trials; in three trials parents also administered xylitol when children were at home.^149,153,156^ One trial was conducted in a community with fluoridated drinking water (concentration <1.5 mg/mL),^152^ three trials^149,153,157^ were conducted in nonfluoridated settings (<0.02 ppm fluoride [F] concentrations), and fluoridated water status was not reported in six trials. Six trials^149–152,154,156^ provided fluoride rinses, toothpastes, or varnishes to all participants and three trials^150,151,156^ included children participating in caries prevention programs of oral health instruction and other oral health preventive interventions (e.g., varnish and/or sealants). One U.S. trial reported that 96 percent of participants were Black children and 94 percent of participants had access to a federal reduced cost/free school lunch program^151^; information regarding race/ethnicity and socioeconomic status was otherwise not described. Five trials were published between 1985 and 1995, and five trials were published between 2000 and 2015.

One trial individually allocated children to interventions^155^; in all other trials, children were allocated to interventions in clusters based on school, classroom, institution, or geographic setting. All trials had methodological limitations (Appendix B Table 20). Three trials^155–157^ were non-randomized and all other trials had unclear randomization methods. Only two trials reported adequate allocation concealment.^152,153^ Among the cluster trials, the number of clusters ranged from three to 21; none of the cluster trials except for one^151^ reported analyses adjusted for clustering. Only two trials utilized a placebo (non-xylitol gum or candy) control^151,153^; all other trials used a no xylitol control and were open-label. Other methodological limitations were baseline between-group differences and high attrition. Two trials were rated fair-quality^152,153^ and the others were rated poor-quality. Due to the lack of higher-quality trials, poor-quality trials were included, though results are described separately for the fair-quality trials.

The two fair-quality trials found no benefit of xylitol or reported results that varied depending on control type.^152,153^ One cluster trial^152^ enrolled 10-year old children (n=496) in Finland in an area with natural fluoridation and low baseline caries burden (82.7% of children had D_3_MFS=0; D_3_MFS indicates caries lesions that extend into the dentin). It found no difference between xylitol lozenges versus no xylitol in caries burden (based on clinical or radiological findings) at 4 years based on the D_3_MFS increment (mean 2.75 for xylitol for 1 year vs. 3.02 for 2 years vs. 2.74 for no xylitol, p>0.05) or likelihood of D_3_MFS >0 (versus placebo, adjusted OR 1.12, 95% CO 0.44 to 2.86 for xylitol 1 year and OR 1.01, 95% CI 0.40 to 2.56 for xylitol 2 years), though estimates were imprecise. Another cluster trial (n=432)^153^ evaluated children (mean age 11.6 years) with high baseline caries burden (mean DMFS 13.2 to 15.3) in a non-fluoridated setting in Lithuania. Results differed depending on the control intervention evaluated. The trial found no difference between xylitol gum five times daily versus placebo (non-xylitol) gum in caries burden in permanent teeth based on the DMFS [all stages] at 3 years (mean increment 8.1 vs. 8.3, p>0.05). However, xylitol gum was associated with decreased DMFS increment versus no xylitol (mean 8.1 vs. 12.4, p<0.05). Xylitol and placebo gum were also associated with similar likelihood of experiencing a DMFS increment ≥14 (versus reference of sorbitol/carbamide gum, adjusted OR 0.2, 95% CI 0.1 to 0.5 for xylitol gum and 0.3 (95% CI 0.27 to 0.7 for placebo gum).

When all trials (fair-quality or poor-quality) were pooled, xylitol was associated with decreased caries burden in permanent teeth versus no xylitol or placebo at 2 to 4 years, based on the DMFS increment (10 trials, effective [after adjustment for clustering] N=1,955; mean difference -2.38, 95% CI -3.66 to -1.15, I^2^=94%; Figure 8).^148–157^ Two poor-quality trials also evaluated the association between xylitol versus no xylitol and caries burden based on the DMFT increment and reported similar findings, though the difference was not statistically significant (two trials, effective N=387, mean difference -1.52, 95% CI -3.36 to 0.26, I^2^=92%; Figure 8).^154,155,160,161^ In an analysis stratified by control type, there was no difference in DMFS increment between xylitol versus placebo (two trials, effective N=328, mean difference 0.23, 95% CI -0.90 to 1.21, I^2^=0%^151,153^), but xylitol was associated with reduced DMFS increment versus no xylitol (nine trials, effective N=1,661, mean difference -2.84, 95% CI -4.15 to -1.63, I^2^=92%)^148–150,152–157^; however, there was no statistically significant interaction with control type (p for interaction=0.08). When trials were stratified by quality, xylitol was associated with reduced DMFS increment in the poor-quality trials (eight trials, effective N=1,646, mean difference -2.38, 95% CI -3.66 to -1.15, I^2^=94%; Figure 9).^148–151,154–157^ There was no difference between xylitol versus no xylitol or placebo in the fair-quality trials (two trials, effective N=344, mean difference -0.04, 95% -2.56 to 1.12, I^2^=51%),^152,153^ though the pooled estimate is difficult to interpret due to inconsistency in the two trials and differences in settings (low^152^ versus high^153^ caries burden) and control types evaluated (no xylitol in one trial^152^ and no xylitol or placebo in one trial^153^) with no statistically significant interaction between trial quality and effects of xylitol on DMFS increment (p for interaction=0.22). Limiting the analysis of fair-quality trials to no xylitol controls did not resolve the inconsistency (mean DMFS increment difference 0.15, 95% CI -0.73 to 1.02^152^ versus -4.30, 95% CI -7.87 to -0.73).^153^ Xylitol was associated with reduced DMFS increment versus no xylitol or placebo in analyses stratified by age (<10 versus ≥10 years), setting (school versus institutional home), geographic region (Europe, North America, or other), duration of followup (<3 vs. ≥3 years), and baseline caries burden (low [based on 83% of children with D_3_MFS=0 or mean DMFS=2.01 at baseline^148,152^] versus not low) (Table 3). However, stratified analyses were limited by small numbers of trials, with serious methodological limitations.

Figure 8 Xylitol vs. No Xylitol or Placebo, DMFS Increment at 2 to 4 Years

*Original sample size, trial reported an estimate that adjusted for clustering; the estimate also adjusted for gender, baseline caries burden, surface-years at risk, and study cohort.

Abbreviations: CI = confidence interval; DMFS = Decayed, Missing, and Filled Surfaces; DMFT = Decayed, Missing, and Filled Teeth; PL= profile likelihood; PYF = French Polynesia; SD = standard deviation.

Figure 8 is a forest plot examining xylitol versus no xylitol or placebo on DMFS increment at 2 to 4 years. There are 12 studies, 2 of which are in the DMFT subgroup and 10 in the DMFS subgroup. The mean difference for the studies in the DMFT subgroup is -1.52 (95% CI -3.36 to 0.26) with an I-squared value of 91.9%. The mean difference for the studies in the DMFS subgroup is -2.38 (95% CI -3.66 to -1.15) with an I-squared value of 93.6%.

Figure 9 Xylitol vs. No Xylitol or Placebo, DMFS Increment at 2 to 4 years, Stratified by Trial Quality

*Original sample size; trial reported an estimate that adjusted for clustering.

Abbreviations: CI = confidence interval; DMFS = Decayed, Missing, and Filled Surfaces; PL= profile likelihood; PYF = French Polynesia; SD = standard deviation.

Figure 9 is a forest plot examining xylitol versus no xylitol or placebo on DMFS increment at 2 to 4 years stratified by trial quality. There are 10 studies, 2 of which are in the Fair subgroup and 8 in the Poor subgroup. The mean difference for the studies in the Fair subgroup is -0.04 (95% CI -2.56 to 1.12) with an I-squared value of 51.1%. The mean difference for the studies in the Poor subgroup is -2.73 (95% CI -4.13 to -1.41) with an I-squared value of 94.3%. The overall mean difference is -2.38 (95% CI -3.66 to -1.15) with an I-squared value of 93.6%.

Table 3 Xylitol vs. Placebo or No Xylitol, DMFS Increment

Analysis | Number of trials (effective N)^#^ | Mean difference in DMFS increment (95% CI) | I^2^ | p for interaction
All trials | 10 (1,955) | −2.38 (−3.66 to −1.15) | 94% | --
Control type | | | | 0.36
• Placebo | 2 (328) | 0.23 (−0.90 to 1.21) | 0% | --
• No xylitol | 9 (1,661) | −2.84 (−4.15 to −1.63) | 92% | --
Setting | | | | 0.57
• School | 9 (1,713) | −2.26 (−3.66 to −0.91) | 94% | --
• Institutional home | 1 (242) | −3.50 (−4.82 to −2.18) | -- | --
Age category | | | | 0.99
• Mean <10 years | 4 (813) | −2.39 (−4.57 to −0.28) | 96% | --
• Mean ≥10 years | 6 (1,142) | −2.37 (−4.24 to −0.60) | 91% | --
Geographic region | | | | 0.93
• Europe | 5 (1,081) | −1.60 (−3.11 to −0.22) | 85% | --
• North America | 2 (578) | −1.79 (−6.69 to 3.11) | 99% | --
• Other^*^ | 3 (418) | −4.23 (−5.70 to −2.58) | 48% | --
Duration of follow-up | | | | 0.88
• <3 years | 5 (951) | −2.29 (−3.66 to −1.15) | 96% | --
• ≥3 years | 5 (1004) | −2.48 (−4.44 to −0.59) | 90% | --
Quality | | | | 0.22
• Fair | 2 (309) | −0.04 (−2.56 to 1.12) | 51% | --
• Poor | 8 (1,646) | −2.38 (−3.66 to −1.15) | 94% | --
Baseline caries burden | | | | 0.29
• Low^^^ | 2 (506) | −1.06 (−4.06 to 1.90) | 92% | --
• Not low | 8 (925) | −2.74 (−4.19 to −1.34) | 94% | --

* Kuwait, Belize, and French Polynesia.

^ D3MFS=0 in 83% of children or mean DMFS=2.01 at baseline.

# After adjustment for clustering (assuming intracluster correlation=0.02).

Abbreviations: CI = confidence interval; DMFS = Decayed, Missing, and Filled Surfaces.

### Key Question 5 What Are the Harms of Specific Interventions (Behavioral Counseling, Referral, and Preventive Interventions) to Prevent Oral Health Issues?

#### Summary

##### Supplements

- One trial reported no adverse events; harms were otherwise not reported.

##### Fluoride Gel

- Evidence on adverse events was very limited, with two trials finding no association between use of fluoride gels and acute toxicity (nausea, gagging, vomiting; N=490, absolute risk difference 0.01, 95% CI -0.01 to 0.02, I^2^=0%).

##### Fluoride Varnish

- Evidence on harms was very limited; five trials reported no adverse events and one trial reported 12 of 1,473 children reported adverse events (the most commonly nausea). All adverse events were described as self-limiting, although four children were withdrawn due to mild adverse events.

##### Sealants

- Reporting of harms was limited, with three trials of resin-based sealants reporting no harms.

##### Silver Diamine Fluoride

- In one trial, SDF was associated with increased likelihood of inactive caries and black stain in deciduous teeth (97% vs. 48%, p<0.001) and in first permanent molars (86% vs. 67%, p<0.001).

##### Xylitol

- Evidence on harms of xylitol was very limited; one trial reported one withdrawal from xylitol due to diarrhea.

#### Evidence

##### Supplements

Evidence on harms of fluoride supplements was very limited. One trial (n=349), which enrolled children with disabilities, reported no adverse events.^140^ Harms were otherwise not reported.

##### Fluoride Gel

Data on adverse events associated with fluoride gels was very limited. None of 26 trials included in the systematic review^79^ reported on staining of tooth surfaces. Two trials included in the systematic review reported on acute toxicity (nausea, gagging, or vomiting), with one trial reporting no events and a pooled analysis finding no difference between gel versus placebo or no treatment (N=490, absolute risk difference 0.01, 95% CI -0.01 to 0.02, I^2^=0%^91,99^). The systematic review found no difference between fluoride gel versus placebo in risk of study withdrawal (19 trials, N=8,695, RR 1.03, 95% CI 0.89 to 1.19); the trials did not report risk of withdrawal specifically for adverse events.

One subsequent trial (n=986) of fluoride gels versus placebo reported no harms except for a slightly sour taste soon after gel application in most children (data not provided).^143^

##### Fluoride Varnish

Five of 16 trials included in a good-quality systematic review of varnish^80^ reported adverse events. Four trials^107,115,117,119^ (N=1,704) reported no adverse events, and one trial (n=2,967^116^) reported 12 of 1,473 children assigned to varnish reported adverse events (the most common adverse event was nausea, occurring in seven children). All adverse events were described as self-limited, although four children were withdrawn due to mild adverse events. Adverse events were not described in the no varnish group. One subsequent trial of varnish (n=5,397) reported no adverse events.^144^

##### Sealants

Only three^115,122,128^ of the 16 trials of sealants versus no sealants included in the systematic review reported harms. All (N=775) evaluated a resin-based sealant and reported no adverse events. The trial of a glass ionomer sealant published subsequent to the systematic review did not report harms.^145^

##### Silver Diamine Fluoride

One trial (n=452) found SDF associated with increased likelihood of black stained inactive caries in deciduous teeth (97% vs. 48%, p<0.001) and in first permanent molars (86% vs. 67%, p<0.001).^147^

##### Xylitol

Evidence on harms of xylitol was very limited. One trial (n=296) reported one withdrawal from xylitol due to diarrhea.^152^ Nine other trials of xylitol did not report harms.^148–151,153–157^

## Contextual Questions

### Contextual Question 1a What Is the Association Between Presence or Severity of Dental Caries of Deciduous or Permanent Teeth and Pain, Quality of Life, Function, and Tooth Loss?

No study evaluated the longitudinal association between improvements in measures of dental caries in children 5 to 18 years of age and health outcomes such as pain, quality of life, function, or tooth loss. However, observational studies indicate a negative cross-sectional association between presence of caries or higher caries burden and worse quality of life and school performance. Evidence also indicates an association between presence or severity of dental caries and dental pain.

A systematic review^167^ of 23 cross-sectional studies (N=12,604) of adolescents 11 to 18 years of age found previous caries experience, DMFT index, and presence of caries in primary teeth associated with a lower level of oral health-related quality of life (measured using the Child Oral Impact on Daily Performances instrument [Child-OIDP]), based on qualitative synthesis. The most frequently affected dimensions on the Child-OIDP were eating, teeth brushing, and emotional status. Another systematic review included 11 observational studies of children 3 to 12 years of age (N=6,293).^168^ The systematic review found presence of dental caries (six studies, OR 1.66, 95% CI 1.43 to 1.88, I^2^=83.5%) or periodontal disease (three studies, OR 1.66, 95% CI 1.12 to 1.18, I^2^=0%) each associated with increased likelihood of having poor oral health-related quality of life.

Regarding dental pain, a systematic review found presence of dental caries associated with increased likelihood of tooth pain among children and adolescents (OR 3.49, 95% CI 2.70 to 4.51), based on 19 studies.^169^ The prevalence of tooth pain was 48.1 percent among children with dental caries lesion, compared with 27.3 percent among those without caries.

Dental caries was also associated with negative impacts on school performance and attendance. One systematic review found having one or more decayed teeth was associated with increased likelihood of poor school performance (five studies, N=3,205; OR 1.44, 95% CI 1.24 to 1.64) and poor school attendance (five studies, N=4,416; OR 1.57, 95% CI 1.08 to 2.05).^170^ Another systematic review reported similar findings, with poor oral health (based on high caries burden, presence of untreated caries, or presence of other unmet dental needs) associated with increased likelihood of poor academic performance (five studies; OR 1.52, 95% CI 1.20 to 1.83) and absenteeism (four studies; OR 1.43; 95% confidence interval, 1.24 to 1.63).^171^ Results should be interpreted with caution given potential confounding related to socioeconomic status or other factors associated with both dental caries and lower school performance or attendance.

### Contextual Question 1b What Is the Association Between Presence or Burden of Dental Caries of Deciduous Teeth and Subsequent Presence or Severity of Dental Caries of Permanent Teeth?

One systematic review of prospective longitudinal cohorts or randomized controlled trials found that baseline caries prevalence was the best single predictor of future caries in schoolchildren and adolescents; though diagnostic accuracy was limited (nine studies, N=8,234, sensitivity 0.54 to 0.59, specificity 0.72 to 0.73, RR 1.03 to 4.9, and OR 3.0 to 13).^172^ The review did not specifically evaluate the association between dental caries in primary teeth and subsequent dental caries in permanent teeth, but noted that the first few years after tooth eruption was the period of highest risk for caries incidence in permanent teeth.

Long-term longitudinal studies on the association between dental caries in primary teeth and caries in permanent teeth or other long-term outcomes are very limited. A longitudinal study of two New Zealand birth cohorts (n=922 and 931) that followed participants from 5 to 40 or 45 years of age each found high dental caries experience as children associated with decreased likelihood of “excellent” self-rated health as adults (incidence rate ratios 0.76, 95% CI 0.50 to 1.14 and 0.69, 95% CI 0.47 to 1.00).^173^ A small (n=25), prospective, longitudinal (15-year) German cohort study found that children 3 to 5 years of age who underwent dental treatment under general anesthesia for severe caries had markedly higher caries burden 15 years later when compared against children 3 to 5 years of age with no caries (mean difference in DMFS 14.8; p=0.001).^174^

### Contextual Question 2 What Factors (e.g., Race/Ethnicity, Age, Socioeconomic Status, Cultural Factors, Educational Attainment, or Health Literacy) Are Associated With Oral Health Care Disparities in Children and Adolescents?

Based on NHANES 2011 to 2016 data (Table 4),^20^ the overall prevalence of dental caries in primary teeth in children ages 6 to 8 years was 52 percent; for permanent teeth, the prevalence of dental caries was 17 percent among children 6 to 11 years of age (when permanent teeth start to erupt) and 57 percent among those 12 to 19 years of age. A number of factors have been associated with oral health care disparities in U.S. children and adolescents, likely related to decreased access to dental care and presence of other negative social determinants of health. The prevalence of dental caries was generally higher in non-Hispanic Black and Mexican American children and adolescents compared with non-Hispanic White children and adolescents. For children 6 to 8 years of age, the prevalence of caries in primary teeth was 54 percent for non-Hispanic Black youth and 73 percent for Mexican American youth, compared with 44 percent for non-Hispanic White youth, with a prevalence of untreated caries of 22.4, 20.0, and 13.2 percent, respectively. For those 12 to 19 years of age, the prevalence of caries in permanent teeth was 57, 66, and 54 percent, respectively, with a prevalence of untreated caries of 20.4, 20.8, and 15.6 percent, respectively. Data from the National Survey of Children’s Health also indicated disparities by race/ethnicity.^175^ In 2018 to 2019, among children 6 to 11 years of age, the proportion with dental caries in the last year was 9.3 percent for non-Hispanic White youth and ranged from 11.1 to 12.2 percent for Hispanic youth and non-Hispanic Black, Asian, or other youth. The proportion that received fluoride treatment was 55 percent for non-Hispanic White youth and ranged from 37.8 to 44.3 percent for Hispanic youth and non-Hispanic Black or Asian youth.

Table 4 NHANES Oral Health Data, Years 2011–2016

Outcome | Results
Dental Caries | [underlined: Prevalence of dental caries in primary teeth in children ages 6–8 years]: 52.1%; By gender: male vs female: 55.4% vs 48.1%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 43.9% vs 53.8%^*^ vs 72.8%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 64.4%^*^ vs 60.1%^*^ vs 40.4%; [underlined: Prevalence of dental caries in permanent teeth (DMFT>or=1) in children ages 6–11 years]: 17.4%; By age: 6–8 vs 9–11: 9.6% vs 24.7%^*^; By gender: male vs female: 15.6% vs 19.0%^*^; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 13.4% vs 21.6%^*^ vs 24.5%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 24.6%^*^ vs 19.3%^*^ vs 12.0%; [underlined: Prevalence of dental caries in permanent teeth (DMFT>or=1) in adolescents ages 12–19 years]: 56.8%; By age: 12–15 vs 16–19: 47.6% vs 65.9%^*^; By gender: male vs female: 55.9% vs 57.7%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 54.3% vs 57.1% vs 68.9%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 64.9%^*^ vs 65.3%^*^ vs 48.7%
Untreated Tooth Decay | [underlined: Prevalence of untreated tooth decay in primary teeth (dft>or=1) in children ages 6–8 years]: 16.4%; By gender: male vs female: 17.4% vs 15.2%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 13.2% vs 22.4%^*^ vs 20.0%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 22.3%^*^ vs 20.9%^*^ vs 11.1%; [underlined: Prevalence of untreated tooth decay in permanent teeth (DT>or=1) in children ages 6–11 years]: 5.2%; By age: 6–8 vs 9–11: 2.7% vs 7.6%^*^; By gender: male vs female: 4.9% vs 5.5%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 4.3% vs 7.1%^*^ vs 7.5%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 8.1% vs 5.6% vs 3.5%; [underlined: Prevalence of untreated tooth decay in permanent teeth (DT>or=1) in adolescents ages 12–19 years]: 16.6%; By age: 12–15 vs 16–19: 12.7% vs 20.4%^*^; By gender: male vs female: 17.7% vs 15.4%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 15.6% vs 0.4%^*^ vs 20.8%^*^; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 22.7%^*^ vs 20.9%^*^ vs 11.1%
Dental Sealants | [underlined: Prevalence of dental sealants on permanent teeth in children ages 6–11 years]: 41.7%; By age: 6–8 vs 9–11: 32.1% vs 50.7%; By gender: male vs female: 40.4% vs 42.9%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 43.6% vs 31.7%^*^ vs 44.4%; By poverty status (federal poverty level): <100% FPL vs 100–199% FPL vs >or=200% FPL: 37.8%^*^ vs 40.0% vs 44.9%; [underlined: Prevalence of dental sealants on permanent teeth in adolescents ages 12–19 years]: 48.1%; By age: 12–15 vs 16–19: 51.7% vs 44.5%^*^; By gender: male vs female: 46.8% vs 49.1%; By race and ethnicity: Non-Hispanic White vs Non-Hispanic Black vs Mexican American: 53.2% vs 37.2%^*^ vs 45.0%^*^; By poverty status: <100% FPL vs 100–199% FPL vs >or=200% FPL: 42.7%^*^ vs 48.4% 51.1%

Source: CDC Oral Health Surveillance Report 2019^20^

Abbreviations: dft = decayed, filled (primary) teeth; DMFT = Decayed, Missing, and Filled Teeth; DT = decayed teeth; FPL = Federal poverty level; NHANES = National Health Nutrition and Examination Survey.

* p<0.05 based on t-test for differences between two periods or two groups within each characteristic.

There was also an association between socioeconomic status and prevalence of dental caries and untreated caries (Table 4). Among children 6 to 8 years of age, the prevalence of dental caries in primary teeth was 64.4 percent among those at <100 percent of the Federal poverty level (FDL), 60.1 percent among those at 100 to 199 percent of FDL, and 40.4 percent among those at ≥200 percent of FDL; the prevalence of untreated caries was 22.3, 20.9, and 11.1 percent, respectively. Among those 12 to 19 years of age, the prevalence of dental caries in permanent teeth was 64.9 percent among those at <100 percent FPL, 65.3 percent among those 100 to 199 percent FPL, and 48.7 percent among those at ≥200 percent FPL; the prevalence of untreated caries was 22.7, 20.9, and 11.1 percent, respectively.

Data also indicate some disparities in receipt of preventive treatments by race/ethnicity and socioeconomic status. Among those 12 to 19 years of age, the proportion with dental sealants on permanent teeth was 37 percent for non-Hispanic Black youth, compared with 45 percent for Mexican American youth and 53 percent for non-Hispanic youth. The proportion with dental sealants on permanent teeth was 43 percent for those at less than 100 percent of the FPL, 48 percent for those at 100 to 200 percent of the FPL, and 51 percent for those at 200 percent or greater of the FPL.

High oral health burdens have been reported in American Indian and Alaska Native Children. According to the 2016–2017 Indian Health Service Oral Health Survey, among children 6 to 9 years of age, 87 percent had dental caries (all teeth), 47 percent had untreated caries, and 44 percent had received dental sealants.^176^ In the 2019 to 2020 Indian Health Service Oral Health Survey, 74 percent of American Indian and Alaska Native adolescents 13 to 15 years of age had caries experience and 45 percent had untreated caries.^177^

Evidence on the association between social determinants of health other than socioeconomic status and disparities in oral health in children has tended to focus on children less than 5 years of age, rather than those 5 to 19 years of age. A study of 283 Boston-area children 6 to 10 years of age found that children of immigrant caregivers had higher baseline caries burden than children of U.S.-born caregivers (mean number of carious surfaces 11.5 versus 9.4, adjusted for race/ethnicity, age, gender, and caregiver smoking status).^178^ Children of immigrant caregivers who preferred to speak non-English languages had higher caries burden than children of immigrant caregivers who preferred to speak English. Other factors that have been associated with caries in children and adolescents include lower level of parental education and living in rural areas.^179,180^

### Contextual Question 3 What Is the Effectiveness of Primary Care Interventions to Reduce Oral Health Care Disparities in Children and Adolescents?

No study evaluated the effectiveness of primary care interventions to reduce oral health disparities in children and adolescents.