# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^72^ the USPSTF and the Agency for Healthcare Research and Quality (AHRQ) determined the scope and key questions for this review. Investigators created an analytic framework with the key questions and the patient populations, interventions, and outcomes reviewed for both screening (Figure 1) and prevention (Figure 2).

Figure 1 Analytic Framework and Key Questions - Screening for Oral Health in Children and Adolescents Ages 5 to 17 Years

Key Questions

1. How effective is screening for oral health performed by a primary care clinician in preventing negative oral health outcomes?
2. How accurate is screening for oral health performed by a primary care clinician in identifying children and adolescents who:
  a. Have oral health issues?
  b. Are at increased risk of future oral health issues?
3. What are the harms of screening for oral health performed by a primary care clinician?

The analytic framework depicts the relationship between the population, screening, interventions, outcomes, and potential harms of screening for oral health. The far left of the framework shows the target population for screening as children and adolescents ages 5 to 17 years at a clinician office visit. To the right of the population is an arrow corresponding to key question 2 which represents the accuracy of screening and risk factor assessment, identifying those at average or increased risk for oral health issues. This step may lead to harms, which corresponds to key question 3. Arrows show that children at either risk level with oral health issues may receive interventions, with the aim of decreased dental caries and tooth loss and improved quality of life, functional status, and morbidity. These outcomes are represented in a box at the end of the pathway. An overarching arrow representing key question 1 represents the effect of screening on these outcomes of interest.

Figure 2 Analytic Framework and Key Questions - Interventions to Prevent Oral Health Issues in Children and Adolescents Ages 5 to 17 Years

Key Questions

1. How accurate is screening for oral health performed by a primary care clinician in identifying children and adolescents who are at increased risk of future oral health issues?*
2. How effective is oral health behavioral counseling provided by a primary care clinician in preventing oral health issues?
3. How effective is referral by a primary care clinician to a dental health care provider in preventing oral health issues?
4. How effective are preventive interventions in preventing oral health issues?
5. What are the harms of specific interventions (behavioral counseling, referral, and preventive interventions) to prevent oral health issues?

*This is the same as Key Question 2b from the previous Analytic Framework.

The analytic framework depicts the relationship between the population, preventive interventions, outcomes, and potential harms of interventions to prevent oral health issues. The far left of the framework describes the target population as children and adolescents ages 5 to 17 years at a clinician office visit. To the right of the population is an arrow corresponding to key question 1 which represents accuracy of risk factor assessment, identifying those at average or increased risk for oral health issues. Arrows show that children at either risk level without oral health issues would receive preventive interventions of behavioral counseling, referral to a dental health care provider, and preventive intervention, representing key questions 2, 3, and 4 respectively, with the aim of decreased dental caries and tooth loss, and improved quality of life, functional status, and morbidity. These outcomes are represented in a box at the end of the pathway. Preventive interventions may lead to harms, which are represented by an arrow for key question 5.

### Screening Key Questions

1. How effective is screening for oral health performed by a primary care clinician in preventing negative oral health outcomes?
2. How accurate is screening for oral health performed by a primary care clinician in identifying children and adolescents who:
  a. Have oral health issues?
  b. Are at increased risk of future oral health issues?
3. What are the harms of screening for oral health performed by a primary care clinician?

### Prevention Key Questions

1. How accurate is screening for oral health performed by a primary care clinician in identifying children and adolescents who are at increased risk of future oral health issues?*
2. How effective is oral health behavioral counseling provided by a primary care clinician in preventing oral health issues?
3. How effective is referral by a primary care clinician to a dental health care provider in preventing oral health issues?
4. How effective are preventive interventions in preventing oral health issues?
5. What are the harms of specific interventions (behavioral counseling, referral, and preventive interventions) to prevent oral health issues?

*This is the same as Key Question 2b from the previous Analytic Framework.

### Contextual Questions

Three Contextual Question were also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. a. What is the association between presence or severity of dental caries of deciduous or permanent teeth and pain, quality of life, function, and tooth loss?
  b. What is the association between presence or burden of dental caries of deciduous teeth and subsequent presence or severity of dental caries of permanent teeth?
2. What factors (e.g., race/ethnicity, age, socioeconomic status, cultural factors, educational attainment, or health literacy) are associated with oral health care disparities in children and adolescents?
3. What is the effectiveness of primary care interventions to reduce oral health care disparities in children and adolescents?

## Search Strategies

We searched the Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews, and Ovid MEDLINE from database inception through October 3, 2022 for relevant studies and systematic reviews. Search strategies are available in Appendix A1. We also reviewed reference lists of relevant articles. Ongoing surveillance was conducted to identify major studies published since October 3, 2022 that could affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on July 21, 2023 and identified no studies affecting review conclusions.

## Study Selection

At least two reviewers independently evaluated each study to determine inclusion eligibility. We selected studies on the basis of inclusion and exclusion criteria developed for each key question (Appendix A2). Disagreements were resolved by consensus. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists included studies, and Appendix A5 lists excluded studies with reasons for exclusion.

This review addresses screening, risk assessment, and preventive interventions for oral health in children 5 to 17 years of age. Separate Analytic Frameworks address screening for oral health conditions and prevention of oral health conditions, to more clearly distinguish treatment of children with existing dental caries identified by screening (screening Analytic Framework) from treatment of those without dental caries to prevent the development of future caries (prevention Analytic Framework).

For both Analytic Frameworks, the population was asymptomatic children and adolescents 5 to 17 years of age, including pregnant persons. Groups of interest were defined by age (<13 vs. ≥13 years, based on the average age at which all permanent teeth have erupted, with the exception of the third molars), sex, gender, socioeconomic status, race/ethnicity, educational attainment, and health literacy. Studies that selected children and adolescents based on presence of caries were ineligible; however, given the very high prevalence of caries in U.S. children and adolescents, we did not exclude studies of patients based on high baseline mean caries prevalence, if they were not required to have caries to be enrolled. Screening interventions were oral examination or clinical assessment by a primary care provider, or risk assessment by a primary care provider for dental caries using a standardized risk assessment instrument. Preventive interventions were behavioral counseling on oral health, preventive medications (topical fluoride [varnish, foam, or gel], silver diamine fluoride, dental sealants, or xylitol), or referral of persons deemed at high risk for oral disease by a primary care provider to a dental professional. Comparisons were against placebo or no screening/treatment/referral. Dental x-rays were not addressed because they are not typically obtained in primary care settings or ordered by primary care clinicians. The most commonly reported outcomes were presence of and severity of caries (likelihood of developing caries [dichotomous outcome] or caries burden [continuous outcome, often measured based on the number of decayed, missing, or filled teeth [DMFT index] or surfaces [DMFS index]), morbidity, quality of life, functional status, and harms of screening and treatment. The preventive interventions selected for review were assessed as potentially primary care feasible (defined as not requiring extensive training to administer); studies of such interventions were considered potentially primary care applicable even if the intervention was administered in a dental care or school setting or by a dental health professional. Randomized trials were included for screening and preventive interventions; we also included cohort studies of screening and large cohort studies for dental fluorosis and studies on diagnostic accuracy of oral examination/clinical assessment and risk assessment instruments. In accordance with USPSTF procedures,^72^ poor-quality studies were excluded unless higher quality evidence was unavailable or very limited.

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we created data abstraction forms to summarize characteristics of study populations, interventions (including the specific drug, formulation or material used; dose; frequency; duration; and professional background or training of persons administering the intervention), comparators, outcomes study designs, settings (including clinical setting, geographic status, and fluoridation status, if available), and methods. One investigator conducted data abstraction, which was reviewed for completeness and accuracy by another team member.

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies by using criteria developed by the USPSTF; studies were rated as “good,” “fair,” or “poor” per USPSTF criteria, depending on the seriousness of the methodological shortcomings (Appendix A6).^72^ For each study, quality assessment was performed by two team members. Disagreements were resolved by consensus.

## Data Synthesis

Meta-analyses of oral health preventive interventions from high quality systematic review (fluoride gels, fluoride varnish, and dental sealants) were utilized when available and supplemented by subsequently published trials. For fluoride supplements and xylitol, for which there was no high quality systematic review, random effects meta-analysis using the profile likelihood model was performed to summarize effects on caries burden. The primary measure of caries burden was the DMFT index, evaluated as a continuous outcome; if data on the DMFT index were not available, the DMFS index was utilized instead. Because the number of missing teeth is low in this age group and missing teeth may not be due to caries, data for decayed or filled teeth (DFT) or surfaces (DFS) is similar to DMFT or DMFTS and was used if DMFT or DMFS was not reported. Meta-analyses focused on caries burden in permanent teeth based on higher consequence than caries burden in deciduous teeth. Analysis was based on mean difference in change from baseline caries index to followup (caries increment) when available; otherwise, the mean difference in follow-up values was used. Adjusted differences were utilized when reported. Data for dentin caries (e.g., graded D_3_ or greater) were used if available; otherwise data for any (enamel or dentin) caries were used. Arms for comparable interventions within the same study were combined in the primary analysis, so each study was represented once in a meta-analysis, to address correlation among the multiple interventions within the same study and avoid overweighting. For cluster randomized trials, treatment differences that accounted for the intracluster correlation were utilized, if reported. Otherwise, clustering was addressed by calculating the effective sample size using the assumed intracluster correlation before combining with individually randomized trials, resulting in smaller “effective” sample sizes for cluster randomized trials in the meta-analyses than the number of patients actually evaluated. In the primary analysis, an intracluster correlation of 0.02 was assumed, based on the values reported in two trials of fluoride varnish for young children.^73,74^ Additionally, a sensitivity analysis was conducted by utilizing an intracluster correlation of 0.045 reported in another trial of fluoride varnish for young children^75^; results of this sensitivity analysis were similar to the primary analysis and are not described further.

Prespecified study-level subgroup analyses were conducted on the following factors, when data were sufficient: control type (placebo or no treatment); setting (school or home); duration of follow-up (<3 years or >3 years); geographic region (Europe/Canada vs. other); and baseline caries burden (high vs. low). Although stratification of trials based on age greater or less than 13 years was planned, there were very few trials of adolescents older than 13 years; therefore, trials were stratified by age greater or less than 10 years. For xylitol, there were only two fair-quality trials; therefore, poor-quality trials were also included in the meta-analysis, with an analysis stratified according to quality. Information on water fluoridation level and provision of oral health education was too limited to conduct subgroup analyses on these factors.

For all meta-analyses, statistical heterogeneity among studies was assessed using the Cochran Qtest and I^2^ statistic.^76^ All meta-analyses were conducted using Stata/SE 16.1 (StataCorp, College Station, TX). All significance testing was 2-tailed; P values of 0.05 or less were considered statistically significant for treatment effects or effect modification; and 0.10 or less, for test of heterogeneity among studies.^77^ Assessment for potential small study effects using funnel plots and the Egger test was planned when there were at least 10 studies in a meta-analysis; however, the meta-analyses had fewer than 10 studies,^78^ so these were not performed.

For all Key Questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^72^ Evidence was rated “good”, “fair”, or “poor” based on study quality, consistency of results between studies, precision of estimates, study limitations, risk of reporting bias, and applicability.^72^

## USPSTF and AHRQ Involvement

The authors worked with USPSTF members at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated the systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.

## Expert Review and Public Comment

We obtained input to inform the draft work plan from Key Informants to identify important subpopulations and inform the development of the scope and Key Questions. In addition, the draft Research Plan was posted on the USPSTF website for public comment from March 18, 2021, to April 14, 2021. In response, the USPSTF revised the inclusion criteria to clarify that screening is performed by a primary care provider and that preventive interventions are administered by a primary care provider or are feasible to be administered by a primary care provider. The USPSTF made no other changes.

The draft report was reviewed by content experts and Federal collaborative partners (Appendix A7), and minor clarifications were made to the report. It was also posted for public comment from May 23, 2023 to June 20, 2023; no public comments were received.