# Chapter 1 Introduction and Background

## Purpose

Screening, referral, behavioral counseling, and preventive interventions for oral health in children age 5 years through 17 years is a new topic for the U.S. Preventive Services Task Force (USPSTF). However, the USPSTF previously addressed the related topics of counseling to prevent dental and periodontal disease (1996),^1^ screening and prevention of dental caries in children younger than 5 years of age (2021),^2^ and oral cancer screening (2013)^3^; a concurrent topic addresses screening, referral, behavioral counseling, and preventive interventions for oral health in adults.^4^

In 1996, the USPSTF issued several recommendations on counseling to prevent dental and periodontal disease (note: the grading system used for the 1996 recommendations differed from current USPSTF definitions and are defined below).^1^ The USPSTF recommended, for children in communities with water fluoride concentrations below recommended levels, clinicians prescribe supplemental oral fluoride at doses based on age and the water fluoride concentration (“A” recommendation [“good evidence to support the recommendation that the condition be specifically considered in a periodic health examination”]). The USPSTF also recommended counseling patients (ages not specified) to visit a dental care provider on a regular basis, floss daily, brush their teeth daily with a fluoride-containing toothpaste, and appropriately use fluoride for caries prevention and chemotherapeutic mouth rinses for plaque prevention (“B” recommendation [“fair evidence to support the recommendation that the condition be specifically considered in a periodic health examination”]). However, the USPSTF found that effectiveness of clinician counseling to change any of these behaviors had not been adequately evaluated (“C” recommendation [“insufficient evidence to recommend for or against the inclusion of the condition in a periodic health examination”]). Additionally, the USPSTF suggested that clinicians examine the oral cavity of patients (ages not specified) and be alert for obvious signs of oral disease (ungraded statement) (“C” [insufficient] recommendation in 1996; most recently, in 2013, the USPSTF issued an I [insufficient] statement on oral cancer screening).^3^

In 2004, the USPSTF issued recommendations on screening and prevention of dental caries in preschool age (<5 years) children who do not have access to school-based interventions and may lack access to oral health care except through a primary care provider;^5^ this topic remains active and was last updated in 2021.^2^ In 2006, the USPSTF inactivated the topic of counseling to prevent dental and periodontal disease in primary care populations (including school-age children 5 to 17 years of age), based on the lack of new evidence on the role of the primary care clinician in counseling for dental services to inform updated recommendations. In 2016, the USPSTF received a nomination on the topic of risks and benefits of dental x-rays for screening; oral health was selected as a topic for further refinement. Through the USPSTF topic refinement process, the scope was broadened to address screening, referral, behavioral counseling, and preventive interventions for various oral health conditions in children 5 to 17 years of age. Given current interest in primary care and oral health,^6–8^ evidence of gaps in provision of oral health services in school-age children,^9^ and potential new evidence to inform recommendations, the USPSTF commissioned a systematic review to address oral health in children 5 to 17 years of age. For this topic, screening was defined as risk assessment or oral cavity examination; dental x-rays were excluded during topic refinement because of limited relevance to primary care. The new oral health topic focuses on dental caries, the most common oral health condition in children, and was scoped to not overlap with currently active related topics (dental caries in children from birth to age 5 years^10^ and oral cancer screening^11^) and does not address school-based^12^ or community-based^13^ interventions for oral health. A concurrent systematic review was commissioned on screening and preventive services for oral health in adults.^4^ This review will be used by the USPSTF to inform the development of new recommendations on screening and prevention in primary care settings for oral health in children 5 to 17 years of age.

## Condition Background

### Condition Definition

In 2000, the U.S. Surgeon General published the first report on Oral Health in America.^14^ An Oral Health in America followup report from the National Institutes was published in 2021.^9^ The 2000 report emphasized that, “oral health means much more than healthy teeth. It means being free of chronic oral-facial pain conditions, oral and pharyngeal (throat) cancers, oral soft tissue lesions, birth defects such as cleft lip and palate, and scores of other diseases and disorders that affect the oral, dental, and craniofacial tissues, collectively known as the craniofacial complex.” Further, the report stated “the mouth is the center of vital tissues and functions that are critical to total health and well-being across the lifespan.”^14^ In children, dental caries is the most prevalent oral health condition^9^ and is the focus of this review. Oral health conditions that are associated with symptoms (e.g., orofacial pain) or do not require screening (e.g., craniofacial anomalies) and treatment of existing oral health conditions or management of oral health conditions that may occur due to other treatments or medications are outside the scope of the USPSTF.

### Prevalence and Burden of Disease/Illness

Dental caries can lead to pain, disability, and decreased wellbeing.^15–18^ In addition, infections and tooth loss may result in problems with eating, speaking, smiling, and learning and negatively impact quality of life and social interactions.^19^ Caries is common in children; based on NHANES 2011 to 2016 data,^20^ the overall prevalence of dental caries in primary teeth in children ages 6 to 8 years was 52 percent; for permanent teeth, the prevalence of dental caries was 17 percent among children 6 to 11 years of age (when permanent teeth start to erupt) and 57 percent among those 12 to 19 years of age. According to the Global Burden of Disease Study, untreated dental caries is the most common health condition worldwide.^21^ Among school-aged children, the prevalence of untreated dental caries increases with older age. In 2011 to 2014, the proportion of children with untreated dental caries in permanent teeth was 3.3 percent among those aged 6 to 8 years, 8.2 percent among those aged 9 to 11 years, and 26 percent among those aged 12 to 19 years.^9^ Among those 12 to 19 years of age, the mean number of decayed, missing or filled surfaces (DMFS) of permanent teeth was approximately 4.2.

### Etiology and Natural History

Dental caries is a multifactorial disease process that occurs when various strains of bacteria colonize the tooth surface and metabolize dietary carbohydrates (especially refined sugars) to produce lactic and other acids, resulting in demineralization of teeth.^22,23^ Dental caries first manifests as white spot lesions, which are small areas of demineralization under the enamel surface. At this stage, the caries lesion is usually reversible, if appropriate preventive action is taken (e.g., change in dietary behaviors and/or application of fluoride varnish). If oral conditions do not improve, demineralization progresses and eventually results in irreversible cavities, with a loss of the normal tooth shape and contour. Continued progression of the caries process can lead to pulpitis and tooth loss, and can be associated with complications such as facial cellulitis and systemic infections.^23,24^ Dental caries that occurs in permanent teeth is more consequential than that which occurs in deciduous (primary) teeth; on average, eruption of permanent teeth occurs by age 12 except for the second molar (11 to 13 years) and the third molar (17 to 21 years).^25^ Data on the prevalence of periodontal disease in children and adolescents are limited. Based on a national survey in 1986 to 1987, gingivitis was observed in approximately 60 percent of children 14 to 17 years of age.^26^ A study of 12 year old schoolchildren in Puerto Rico found that gingivitis was present in 80.4 percent of those examined.^27^

### Risk Factors

Risk factors for dental caries in children and adolescents include inappropriate dietary practices, poor oral hygiene, not using fluoridated toothpaste, poor caregiver oral health behaviors (inappropriate dietary practices or poor oral hygiene such as lack of tooth brushing), and medications or substances that cause xerostomia; risk factors that may also impact oral health in adolescents include tobacco use, excessive alcohol use, methamphetamine use, and cannabis use.^28,29^ As discussed earlier, among children and adolescents 5 to 17 years of age, older age is also associated with increased risk of dental caries.^9,30,31^

### Rationale for Screening/Screening Strategies

As noted, oral health issues in children are common, are often untreated, and can lead to tooth loss or irreversible damage and other adverse health outcomes. Children may be asymptomatic and children or caregivers may be unaware of their condition in the early stages of the dental caries process. In addition, children may have inadequate access to dental services due to insurance status or other socioeconomic factors, or not utilize dental services for other reasons.^32,33^ Estimates of the proportion of children greater than 5 years and adolescents that receive dental services vary. Based on the 2019 and 2020 National Health Information Survey, the percent of children who had a dental examination or cleaning in the past 12 months was 91 percent among children aged 5 to 11 years and 88 percent among children aged 12 to 17 years overall.^34^ However, an analysis of data from the Household Component of the Medical Expenditure Panel Survey found that 49 to 72 percent of children 6 to 11 years of age and 42 to 69 percent of children 12 to 18 years of age had a dental visit in the last year.^35^ In both analyses, the proportion that received dental care was lower for children from lower income households. For children who lack access to dental services, interventions and treatments that could prevent and treat early dental caries could potentially be provided in primary care settings. Therefore, identifying and providing services to prevent oral health issues early in primary care settings could help prevent adverse health outcomes.^36–38^

Screening for oral health conditions and provision of interventions for oral health in primary care also provide an opportunity to potentially reduce disparities in detection and treatment of oral health conditions among socioeconomic and racial/ethnic groups (see subsequent sections on Disparities and Contextual Question 2).

### Interventions/Treatment

Screening for oral health conditions includes risk assessment, visual/tactile examination, and imaging (dental x-rays)^39^ to identify children with untreated dental caries or periodontal disease, or those at high risk for developing these conditions. Interventions to prevent development of caries focus on reducing the burden of bacteria, reducing the intake of refined sugars, and increasing the resistance of teeth to caries development.^22,40^ Counseling interventions include those that address oral hygiene (e.g., brushing twice daily with fluoride toothpaste, flossing daily, or rinses [fluoride or antimicrobial]), diet, tobacco use, and alcohol use, as well as counseling to visit a dentist. Preventive interventions include oral or topical (e.g., varnish) fluoride, dental sealants, xylitol, and referral to a dentist.

Use of fluorides primarily focuses on promoting remineralization of the enamel. Fluoride exposure can be topical (fluoride dentifrices, rinses, gels, foams, varnishes) or systemic (dietary fluoride supplements).^22,40^ Fluoridated water has topical as well as systemic effects. The main effect, however, is now believed to be topical. Fluoride is incorporated into the biofilm (dental plaque), saliva and tooth enamel and increases tooth resistance to acid decay, acts as a reservoir for remineralization of caries lesions, and inhibits cariogenic bacteria.^22,24^ A potential harm of taking in too much systemic fluoride over a long period of time when the teeth are forming under the gums is dental fluorosis, a visible change in enamel opacity due to altered mineralization. The severity of enamel fluorosis depends on the dose, duration and timing of fluoride intake, and is most strongly associated with cumulative intake during enamel development; children are most susceptible between 15 to 30 months of age.^41,42^ Mild fluorosis manifests as small opaque white streaks or specks in the tooth enamel.^43^ Severe fluorosis results in discoloration and can result in pitted or rough enamel.^24^ In 1999 to 2004, the prevalence of severe enamel fluorosis in the United States was estimated at less than 1 percent.^43,44^

Topical fluoride is typically applied as a varnish with a small brush or as a gel or foam (more commonly used in older, school-aged children).^45^ Fluoride varnish application does not require specialized dental devices or equipment and can be applied quickly by both dental professionals and non-dental health professionals in a variety of settings; topical gels and foams typically require special suction to remove excess material. Systemic exposure to fluoride is lower following application of fluoride varnish compared to a gel or foam because smaller amounts are swallowed.^22,45–47^ Fluoride varnish results in prolonged contact time between the fluoride and the tooth surface, which maintains a higher level of the calcium fluoride in the biofilm; later the released fluoride promotes remineralization. Fluoride varnish is typically available in the United States as 5 percent sodium fluoride (2.26% F). Fluoride varnish is cleared for marketing by the U.S. Food and Drug Administration (FDA) as a cavity liner and tooth desensitizer; its use for prevention of caries is off-label.^48^ Fluoride gel is typically available as sodium fluoride and acidulated phosphate fluoride.

Silver diamine fluoride (SDF) is a topical solution that is noninvasive, relatively inexpensive, and easy to apply.^49,50^ Its mechanism of action is related to the antibacterial properties of silver, in addition to the effects of fluoride. The most common concentration is 38 percent, though it has been evaluated in formulations as low as 10 percent. SDF was cleared for marketing by the FDA in 2014 as a desensitizing agent in adults, similar to fluoride varnish 20 years earlier.^51^ SDF has long been used outside the United States to arrest progression of existing caries lesions and avoid the need for restorative treatment. SDF works by the combined effects of silver and fluoride on promoting remineralization, as a short-term germicide, and inhibiting enzymes involved in collagen degradation, all of which result in an arrest of the carious process^49,52^; SDF is also being evaluated for preventing future caries.^53^ A potential disadvantage of SDF is cosmetic concerns due to the permanent dark discoloration of active carious lesions by the silver component; however, SDF will not discolor healthy enamel, and carious lesions themselves may be discolored. Based on its potential as a caries treatment, SDF has been granted “breakthrough therapy” designation by the FDA, providing the opportunity for expedited approval for this indication, and a number of clinical trials of SDF for treating or preventing caries are in progress.

Xylitol is a naturally-occurring sugar that cannot be metabolized by the oral microflora and thus has the potential to reduce levels of caries-forming mutans streptococci in the plaque and saliva.^54^ Xylitol can be administered topically (e.g., wipes) or via gum, lozenges, or snack foods. FDA allows foods (including chewing gums) that contain xylitol to make the following statement: “Xylitol may reduce the risk of tooth decay.^55^” Other topical antimicrobials such as chlorhexidine varnish or gel and povidone-iodine rinses are not commonly used in the United States. Neither chlorhexidine nor povidone iodine has been approved by FDA for caries reduction or prevention.^56^

Dental sealants are thin coatings applied to the chewing and selected other surfaces of the premolars and molars that form a protective barrier and can prevent cavities (tooth decay) over a prolonged period of time. A variety of sealant materials are available, though the main materials are resins/composites and glass ionomers. Following application, sealants can be activated (cured) using light or chemicals resulting in polymerization of the sealant material and hardening on the tooth surface (some sealants are autopolymerized [not requiring light or chemicals]). Resin-based sealants are classified into four generations, based on the method of polymerizations. First generation sealants utilized ultraviolet light for polymerization and are no longer used; second generation sealants are auto-polymerizing or chemically cured; third generation sealants are activated using visible light; and fourth generation sealants contain fluoride-releasing particles.^57^ Glass ionomer sealants contain fluoride and can be classified as low or high viscosity; high viscosity sealants may have better retention on the tooth. Dental sealants are typically applied by dental health professionals in their office or in community settings such as schools.^58^ Other interventions typically performed by dental health professionals to prevent dental caries or periodontal disease or to treat disease identified on screening which are considered beyond the scope of primary care practice include teeth cleaning, plaque removal, and treatments for caries (fillings, crowns, root canals, tooth extractions) and periodontal disease (surgery and grafts).

Potential barriers to provision of oral health services in primary care settings are unfamiliarity with interventions, need for additional training or equipment (e.g., fluoride varnish, dental sealants, or silver diamine fluoride), and non-reimbursement; there are additional barriers to dental referrals from primary care.^59^ However, some data in non-adult populations suggest that increased provision of an oral health intervention (fluoride varnish) in young children (less than 5 years of age) primary care settings is feasible.^60,61^ For some oral health preventive interventions, state laws or regulations restrict administration to certain dental professionals (e.g., dental sealants can be placed by dentists, dental hygienists, and dental assistants [in certain states]), though such regulations do not apply to medical professionals.

### Current Clinical Practice/Recommendations of Other Groups

The 2000 U.S. Surgeon General’s report, Oral Health in America,^14^ and a 2021 followup report from the National Institutes of Health,^9^ highlight the importance of integrating oral health into primary care medical settings, primarily focusing on counseling, coordination, and referral. Reports from the Institute of Medicine in 2011 (Advancing Oral Health in America,^62^ and Improving Access to Oral Health Care for Vulnerable and Underserved Populations^63^) and from the Health Resources and Services Administration in 2014 (Integration of Oral Health and Primary Care Practice^64^), also emphasized the importance of integrating oral health services in primary care medicine. A U.S. study aimed at improving provision of dental fluoride varnish application in a primary care pediatric practice found that, after implementing a 2 hour training, automatic reminders in electronic health records and automatic fluoride orders for the recommended age groups, fluoride application increased from 14 to 55 percent without impacting patient office flow.^60^

The American Dental Association (ADA) and American Academy of Pediatric Dentistry (AAPD) have issued a number of guidelines on oral health (e.g., sealants, caries, fluoride, prevention of periodontitis) aimed at dental professionals.^65,66^ The American Academy of Family Physicians (AAFP) recommends that primary care physicians prescribe oral fluoride supplementation starting at age 6 months for children whose water supply is deficient in fluoride, and provide dietary fluoride supplements for children ages 6 months through 16 years in areas where drinking water levels are suboptimal.^67^ The American Academy of Pediatrics (AAP) recommends that pediatricians apply fluoride varnish applied every 3 to 6 months starting at tooth emergence and provide dietary fluoride supplements if the drinking water supply is not fluoridated.^68^ Guidelines from AAFP, ADA, AAPD, AAP, and the Community Services Task Force are summarized in Table 1. Other groups, such as Smiles for Life and Qualis Health, have also developed educational resources and recommendations on provision of oral health services in primary medical care settings.^68,69^ In general, the guidelines recommend counseling and use of topical fluoride, dietary fluoride supplementation in settings with inadequate water fluoridation, and dental sealants as preventive measures in children and adolescents. In some guidelines, the upper age ranges for the recommended interventions are unspecified or unclear.

Table 1 Recommendations of Other Groups

Organization | Recommendation
American Dental Association (ADA), 2013–2020^65^ | Recommends the use of 38% silver diamine fluoride, sealants, 5% sodium fluoride varnish, 1.23% acidulated phosphate fluoride gel, and 5,000 parts per million fluoride (1.1% sodium fluoride) toothpaste or gel, among others. Recommends against the use of 10% casein phosphopeptide–amorphous calcium phosphate.; Found that sealants are effective in preventing and arresting pit-and-fissure occlusal carious lesions of primary and permanent molars in children and adolescents compared with the nonuse of sealants or use of fluoride varnishes. Concluded that sealants could minimize the progression of noncavitated occlusal carious lesions (also referred to as initial lesions) that receive a sealant.; Recommends the following for people at risk of developing dental caries: 2.26% fluoride varnish or 1.23% fluoride (acidulated phosphate fluoride) gel, or a prescription-strength, home-use 0.5% fluoride gel or paste or 0.09% fluoride mouth rinse for patients 6 years or older. Only 2.26% fluoride varnish is recommended for children younger than 6 years.
American Academy of Pediatric Dentistry (AAPD), 2016^66^ | Advocates that oral health care must be included in the design and provision of individual, community-based, and national health care programs to achieve comprehensive health care.; Supports professional prophylaxis to instruct the caregiver and child or adolescent in proper oral hygiene techniques; remove dental plaque, extrinsic stain, and calculus deposits from the teeth; facilitate the examination of hard and soft tissues; and introduce dental procedures to the young child and apprehensive patient.; Encourages the application of professional fluoride treatments for all individuals at risk for dental caries. Supports the delegation of fluoride application to auxiliary dental personnel or other trained allied health professionals by prescription or order of a dentist after a comprehensive oral examination or by a physician after a dental screening has been performed. Encourages dental providers to talk to parents and caregivers about the benefits of fluoride and to proactively address fluoride hesitance through chairside and community education.; Supports the use of silver diamine fluoride as part of an ongoing caries management plan with the aim of optimizing individualized patient care consistent with the goals of a dental home. Supports delegation of application of silver diamine fluoride to auxiliary dental personnel or other trained health professionals according to a state’s dental practice act by prescription or order of a dentist after a comprehensive oral examination.; Supports the use of xylitol and other sugar alcohols as non-cariogenic sugar substitutes, recognizing that presently there is a lack of consistent evidence showing significant reductions in MS and dental caries in children. Recognizes that the large dose and high frequency of xylitol used in clinical trials may be unrealistic in clinical practice.
American Academy of Family Physicians (AAFP), 2018^67^ | Recommends primary care physicians prescribe oral fluoride supplementation starting at age 6 months for children whose water supply is deficient in fluoride, as well as provide dietary fluoride supplement for children ages 6 months through 16 years in areas where drinking water levels are suboptimal.; Recommends physician education in oral condition screening and management, as well as the consequences of poor oral hygiene on overall health, and encourages collaboration of family physicians with dental health practitioners to provide comprehensive medical care.
American Academy of Pediatrics (AAP), 2020^68^ | Recommends that pediatricians perform oral health risk assessments on all children at every routine well-child visit beginning at 6 months of age; administration of fluoride varnish at least one every 6 months for all children and every 3 months for children at high risk for caries, starting when the first tooth erupts and until establishment of a dental home; and provision of dietary fluoride supplements if drinking water supply is not fluoridated.
Community Preventive Services Task Force (CPSTF), 2013^186^ | Recommends community water fluoridation to reduce tooth decay (strong evidence).; Recommends school-based programs to deliver dental sealants and prevent dental caries (tooth decay) among children (strong evidence).; Found insufficient evidence to determine the effectiveness of community-based initiatives to promote use of dental sealants. Although strong evidence exists for the efficacy of sealants and their delivery through school-based programs for preventing caries (tooth decay), few studies examined uptake of sealants following community-based promotion initiatives and their results were inconsistent.

Abbreviations: AAFP = American Academy of Family Physicians; AAP = American Academy of Pediatrics; AAPD = American Academy of Pediatric Dentistry; ADA = American Dental Association; CPSTF = Community Preventive Services Task Force.

### Disparities

Oral health disparities in children and adolescents have been described with regard to race/ethnicity (Black, Hispanic, American Indian, and Alaska Native persons are disproportionately impacted), socioeconomic status,^70^ insurance status, health literacy, immigration status, and educational level.^20,71^ Populations with increased prevalence of caries include people with disabilities, individuals living in rural and urban underserved areas, persons without insurance, persons who are publicly insured, and persons experiencing homelessness.^63^ In 2011 to 2016, the prevalence of untreated dental caries among children 6 to 11 years of age was approximately 8.1 percent in persons living at <100% of the federal poverty threshold and 3.5 percent among those at ≥200% of the federal poverty threshold^20^; among those 12 to 19 years of age, corresponding rates were 23 percent and 11 percent. Stratified by race/ethnicity, the prevalence of untreated dental caries was approximately 7.5 percent among Mexican American children 6 to 11 years of age, 7 percent among non-Hispanic Black children, and 4.3 percent among non-Hispanic White children; among those 12 to 19 years of age corresponding rates were 21 percent, 20 percent, and 16 percent. (Additional details on oral health disparities are discussed in Contextual Question 2.)