# Appendix B Evidence Tables and Quality Tables

Appendix B Table 1 Data Abstraction of Diagnostic Accuracy Study

Appendix B Table 2 Quality Assessment of Diagnostic Accuracy Study

Appendix B Table 3 Data Abstraction of Fluoride Supplement Trials

Appendix B Table 4 Quality Assessment of Fluoride Supplement Trials

Appendix B Table 5 Quality Assessment of Fluoride Gel Systematic Review

Appendix B Table 6 Data Abstraction of Fluoride Gel Systematic Review

Appendix B Table 7 Data Abstraction of Additional Fluoride Gel Trial

Appendix B Table 8 Quality Assessment of Additional Fluoride Gel Trial

Appendix B Table 9 Quality Assessment of Fluoride Varnish Systematic Review

Appendix B Table 10 Data Abstraction of Fluoride Varnish Systematic Review

Appendix B Table 11 Data Abstraction of Additional Fluoride Varnish Trial

Appendix B Table 12 Quality Assessment of Additional Fluoride Varnish Trial

Appendix B Table 13 Quality Assessment of Sealants Systematic Review

Appendix B Table 14 Data Abstraction of Sealants Systematic Review

Appendix B Table 15 Data Abstraction of Additional Sealants Trial and Longer-term Followup of Previous Trial

Appendix B Table 16 Quality Assessment of Additional Sealants Trial and Longer-term Followup of Previous Trial

Appendix B Table 17 Data Abstraction of Silver Diamine Fluoride Trial

Appendix B Table 18 Quality Assessment of Silver Diamine Fluoride Trial

Appendix B Table 19 Data Abstraction of Xylitol Trials

Appendix B Table 20 Quality Assessment of Xylitol Trials