# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Overall

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti.
2 limit 1 to full systematic reviews
3 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti.
4 2 and 3

### Screening

#### Database: Ovid MEDLINE(R) ALL (Systematic Reviews)

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Mass Screening/
8 screen*.ti,ab,kf.
9 Risk Assessment/
10 Risk Factors/
11 risk.ti,ab,kf.
12 or/7–11
13 6 and 12
14 limit 13 to (meta analysis or "systematic review")
15 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
16 14 and 15
17 limit 16 to english language
18 14 not 15
19 limit 18 to english language
20 from 19 keep 1–1844

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab.
6 or/1–5
7 Mass Screening/
8 screen*.ti,ab.
9 Risk Assessment/
10 Risk Factors/
11 risk.ti,ab.
12 or/7–11
13 6 and 12
14 conference abstract.pt.
15 "journal: conference abstract".pt.
16 "journal: conference review".pt.
17 "http://www.who.int/trialsearch*".so.
18 "https://clinicaltrials.gov*".so.
19 14 or 15 or 16 or 17 or 18
20 13 not 19
21 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,sh.
22 20 and 21

#### Database: Ovid MEDLINE(R) ALL

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Mass Screening/
8 screen*.ti,ab,kf.
9 Risk Assessment/
10 Risk Factors/
11 risk.ti,ab,kf.
12 or/7–11
13 Primary Health Care/
14 ("primary care" or "general practic*" or "family medicine" or "family practic*").ti,ab,kf.
15 13 or 14
16 6 and 12 and 15
17 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
18 16 and 17

#### Database: Ovid MEDLINE(R) ALL

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Mass Screening/
8 screen*.ti,ab,kf.
9 Risk Assessment/
10 Risk Factors/
11 risk.ti,ab,kf.
12 or/7–11
13 6 and 12
14 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
15 13 and 14
16 exp "Sensitivity and Specificity"/
17 (diagnos* adj2 accura*).ti,ab,kf.
18 16 or 17
19 15 and 18
20 limit 15 to randomized controlled trial
21 (random* or control* or trial or cohort).ti,ab.
22 15 and 21
23 19 or 20 or 22

### Interventions

#### Database: Ovid MEDLINE(R) ALL (Systematic Reviews)

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Counseling/
8 health education/ or health education, dental/ or health promotion/ or patient education as topic/
9 exp Cariostatic Agents/
10 "Pit and Fissure Sealants"/
11 exp Dentifrices/
12 Xylitol/
13 "Referral and Consultation"/
14 (counsel* or education or fluoride or "silver diamine" or sealant* or xylitol or referral).ti,ab,kf.
15 or/7–14
16 6 and 15
17 limit 16 to (meta analysis or "systematic review")
18 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
19 17 and 18
20 17 not 19
21 limit 20 to english language
22 limit 19 to english language

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab.
6 or/1–5
7 Counseling/
8 health education/ or health education, dental/ or health promotion/ or patient education as topic/
9 exp Cariostatic Agents/
10 "Pit and Fissure Sealants"/
11 exp Dentifrices/
12 Xylitol/
13 "Referral and Consultation"/
14 (counsel* or education or fluoride or "silver diamine" or sealant* or xylitol or referral).ti,ab.
15 or/7–14
16 6 and 15
17 limit 16 to english language
18 conference abstract.pt.
19 "journal: conference abstract".pt.
20 "journal: conference review".pt.
21 "http://www.who.int/trialsearch*".so.
22 "https://clinicaltrials.gov*".so.
23 18 or 19 or 20 or 21 or 22
24 17 not 23
25 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,sh.
26 24 and 25

#### Database: Ovid MEDLINE(R) ALL

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Counseling/
8 health education/ or health education, dental/ or health promotion/ or patient education as topic/
9 exp Cariostatic Agents/
10 "Pit and Fissure Sealants"/
11 exp Dentifrices/
12 Xylitol/
13 "Referral and Consultation"/
14 (counsel* or education or fluoride or "silver diamine" or sealant* or xylitol or referral).ti,ab,kf.
15 or/7–14
16 Primary Health Care/
17 ("primary care" or "general practic*" or "family medicine" or "family practic*").ti,ab,kf.
18 16 or 17
19 6 and 15 and 18
20 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
21 19 and 20
22 limit 21 to english language

#### Database: Ovid MEDLINE(R) ALL

1 Oral Health/
2 Mouth Diseases/
3 exp Periodontal Diseases/
4 exp Tooth Diseases/
5 ("oral health" or "oral disease*" or "dental caries" or "tooth decay" or "periodontal disease" or periodontitis or gingivitis or "gum disease").ti,ab,kf.
6 or/1–5
7 Counseling/
8 health education/ or health education, dental/ or health promotion/ or patient education as topic/
9 exp Cariostatic Agents/
10 "Pit and Fissure Sealants"/
11 exp Dentifrices/
12 Xylitol/
13 "Referral and Consultation"/
14 (counsel* or education or fluoride or "silver diamine" or sealant* or xylitol or referral).ti,ab,kf.
15 or/7–14
16 6 and 15
17 (child* or pediatric* or youth or teen* or adolescen* or "school age*").ti,ab,kf,sh.
18 16 and 17
19 limit 18 to randomized controlled trial
20 (random* or control* or trial or cohort).ti,ab,kf.
21 18 and 20
22 19 or 21

## Appendix A2 Inclusion and Exclusion Criteria

Category | Included | Excluded
Populations | Asymptomatic children starting at age 5 years through adolescents age 17 years; Populations of interest include groups defined by: age (those with deciduous teeth vs. permanent dentition), sex, socioeconomic status, race/ethnicity, educational attainment, and health literacy | Children younger than age 5 years (this population is addressed in a separate USPSTF recommendation) Adults age 18 and older (this population is addressed in a separate USPSTF recommendation)
Interventions | Screening:; - Oral examination/clinical assessment by a primary care provider; - Risk assessment by a primary care provider for dental caries based on history, examination, standardized risk-assessment instrument, or some combination thereof; Preventive interventions:; - Behavioral counseling/education by a primary care provider; - Preventive medications (topical fluoride [varnish, foam, or gel], oral fluoride supplementation, silver diamine fluoride, dental sealants, and xylitol-containing products) that are feasible to be administered by a primary care provider; - Referral of persons deemed at high risk for oral diseases by a primary care provider to a dental care health provider | Treatment for existing oral health issues
Comparisons | No intervention or placebo | Active treatment
Outcomes | Dental caries (incidence and severity); Tooth loss; Morbidity; Quality of life; Functional status; Harms of screening and treatment (e.g., dental fluorosis, tooth staining, bone effects, and neurological effects) | Cost effectiveness
Setting | Primary care or applicable to U.S. primary care practice (e.g., screening or preventive interventions do not require specialized dental training or equipment and are feasible for implementation in primary care); includes tele-dentistry approaches based in primary care settings | Dental clinics providing interventions not available in primary care settings
Study Design | Screening: Trials and cohort studies; Preventive interventions: Trials; large cohort studies for selected harms (e.g., dental fluorosis); Risk assessment: Studies of diagnostic accuracy or risk prediction | Case-control studies or uncontrolled studies
Study Quality | Good or fair quality | Poor quality

Abbreviations: U.S. = United States; USPSTF = U.S. Preventive Services Task Force.

## Appendix A3 Literature Flow Diagram

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The figure shows that 8,677 citations were identified through literature database searches and other sources. Five hundred and thirty-one articles were reviewed at the full-text level after excluding 8,146 citations based on review of titles and abstracts. Four hundred and forty-eight full-text articles were excluded for the following reasons: Ineligible intervention: 127, Ineligible study design: 60, Ineligible population: 56, Publication used as source document to identify studies: 54, Ineligible outcome: 40, Ineligible comparison: 42, Not a study: 31, Study not in English: 10, Ineligible setting: 9, Ineligible criteria for SRs: 7, Poor quality: 4, Ineligible screener: 3, Ineligible country: 2, Abstract only: 2, Results not usable: 1. Twenty-three studies (in 27 publications) and 3 SRs were included that provided evidence for the KQs. A footnote describes that 54 trials were included in the SRs (in 53 publications). For the Screening framework, there was one study included for KQ2a on diagnostic accuracy for those with existing oral health issues. There were no studies included for KQs 1, 2b, or 3. For the Prevention framework, for KQ4 on Preventive Interventions, the following studies were included: Supplements: 7 trials (in 8 publications), Fluoride gel: 1 SR (26 trials, in 25 publications), 1 subsequent trial, Fluoride varnish: 1 SR (14 trials), 1 subsequent trial, Sealants: 1 SR (16 trials), 2 subsequent trials, 1 additional publication, SDF: 1 trial, Xylitol: 10 trials (in 12 publications). For KQ5 on Harms of Preventive Interventions, the following 13 studies were included: Supplements: 1 trial, Fluoride gel: 2 trials, Fluoride varnish: 6 trials, Sealants: 3 trials, SDF: 1 trial, Xylitol: 1 trial. There were no studies included for KQs 1, 2, or 3.

## Appendix A4 List of Included Studies

1 Aasenden R, DePaola PF, Brudevold F. Effects of daily rinsing and ingestion of fluoride solutions upon dental caries and enamel fluoride. Arch Oral Biol. 1972 Dec;17(12):1705–14. doi: 10.1016/0003-9969(72)90233-6. PMID: 4405216.4405216
2 Ahovuo-Saloranta A, Forss H, Walsh T, Pit and fissure sealants for preventing dental decay in permanent teeth. Cochrane Database Syst Rev. 2017 07 31;7:CD001830. doi: 10.1002/14651858.CD001830.pub5. PMID: 28759120.28759120 Trials Included in Ahouvo-Saloranta 2017 Systematic Review: Bojanini J, Garces H, McCune RJ, Effectiveness of pit and fissure sealants in the prevention of caries. J Prev Dent. 1976 Nov-Dec;3(6):31–4. PMID: 1069846.1069846 Bravo M, Montero J, Bravo JJ, Sealant and fluoride varnish in caries: a randomized trial. J Dent Res. 2005;84(12):1138–43. doi: 10.1177/154405910508401209. PMID: 16304443.16304443 Brooks JD, Mertz-Fairhurst EJ, Della-Giustina VE, A comparative study of two pit and fissure sealants: two-year results in Augusta, Ga. J Am Dent Assoc. 1979 May;98(5):722–5. doi: 10.14219/jada.archive.1979.0149. PMID: 374449.374449 Charbeneau GT, Dennison JB. Clinical success and potential failure after single application of a pit and fissure sealant: a four-year report. J Am Dent Assoc. 1979 Apr;98(4):559–64. doi: 10.14219/jada.archive.1979.0112. PMID: 372286.372286 Erdogan B, Alaçam T. Evaluation of a chemically polymerized pit and fissure sealant: results after 4.5 years. J Paediatr Dent. 1987;3:11–3. Hunter PB. A study of pit and fissure sealing in the School Dental Service. N Z Dent J. 1988 Jan;84(375):10–2. PMID: 3133616.3133616 Liu BY, Lo EC, Chu CH, Randomized trial on fluorides and sealants for fissure caries prevention. J Dent Res. 2012;91(8):753–8. doi: 10.1177/0022034512452278. PMID: 22736448.22736448 Liu Y, Rong W, Zhao X, [Caries prevention effect of resin based sealants and glass ionomor sealants]. Chung Hua Kou Chiang Hsueh Tsa Chih. 2014 Apr;49(4):199–203. PMID: 24969592.24969592 Muller-Bolla M, Lupi-Pegurier L, Bardakjian H, Effectiveness of school-based dental sealant programs among children from low-income backgrounds in France: a pragmatic randomized clinical trial. Community Dent Oral Epidemiol. 2013;41(3):232–41. doi: 10.1111/cdoe.12011. PMID: 23072366.23072366 Reisbick MH, Thanos CE, Berson RB, Benefit from sealants in a moderately fluoridated community. CDA J. 1982 Jan;10(1):53–6. PMID: 6213312.6213312 Richardson AS, Waldman R, Gibson GB, The effectiveness of a chemically polymerized sealant in preventing occlusal caries: two year results. Dent J. 1978 Jun;44(6):269–72. PMID: 277401.277401 Rock WP, Gordon PH, Bradnock G. The effect of operator variability and patient age on the retention of fissure sealant resin. Br Dent J. 1978 Aug 1;145(3):72–5. doi: 10.1038/sj.bdj.4804121. PMID: 278624.278624 Sheykholeslam Z, Houpt M. Clinical effectiveness of an autopolymerized fissure sealant after 2 years. Community Dent Oral Epidemiol. 1978;6(4):181–4. doi: 10.1111/j.1600-0528.1978.tb01146.x. PMID: 278700.278700 Songpaisan Y, Bratthall D, Phantumvanit P, Effects of glass ionomer cement, resin-based pit and fissure sealant and HF applications on occlusal caries in a developing country field trial. Community Dent Oral Epidemiol. 1995;23(1):25–9. doi: 10.1111/j.1600-0528.1995.tb00193.x. PMID: 7774173.7774173 Tagliaferro EP, Pardi V, Ambrosano GM, Occlusal caries prevention in high and low risk schoolchildren. A clinical trial. Am J Dent. 2011;24(2):109–14. PMID: 21698991.21698991 Tang LH, Shi L, Yuan S, [Effectiveness of 3 different methods in prevention of dental caries in permanent teeth among children]. Shanghai Kou Qiang Yi Xue/Shanghai Journal of Stomatology. 2014 Dec;23(6):736–9. PMID: 25636293.25636293
3 Alanen P, Isokangas P, Gutmann K. Xylitol candies in caries prevention: results of a field study in Estonian children. Community Dent Oral Epidemiol. 2000 Jun;28(3):218–24. doi: 10.1034/j.1600-0528.2000.280308.x. PMID: 10830649.10830649
4 Beltran ED, Malvitz DM, Eklund SA. Validity of two methods for assessing oral health status of populations. J Public Health Dent. 1997;57(4):206–14. doi: 10.1111/j.1752-7325.1997.tb02977.x. PMID: 9558624.9558624
5 Blinkhorn AS, Downer MC, Mackie IC, Evaluation of a practice based preventive programme for adolescents. Community Dent Oral Epidemiol. 1981;9(6):275–9. doi: 10.1111/j.1600-0528.1981.tb00345.x. PMID: 6955127.6955127
6 DePaola PF, Lax M. The caries-inhibiting effect of acidulated phosphate-fluoride chewable tablets: a two-year double-blind study. J Am Dent Assoc. 1968;76(3):554–7. PMID: 4865754.4865754
7 Driscoll WS, Heifetz SB, Korts DC. Effect of acidulated phosphate-fluoride chewable tablets on dental caries in schoolchildren: results after 30 months. J Am Dent Assoc. 1974 Jul;89(1):115–20. doi: 10.14219/jada.archive.1974.0338. PMID: 4151915.4151915
8 Driscoll WS, Heifetz SB, Korts DC. Effect of chewable fluoride tablets on dental caries in schoolchildren: results after six years of use. J Am Dent Assoc. 1978;97(5):820–4. PMID: 102674.102674
9 Hesse D, Guglielmi CA B, Raggio DP, Atraumatic Restorative Treatment-Sealed versus Nonsealed First Permanent Molars: a 3-Year Split-Mouth Clinical Trial. Caries Res. 2021; 55(1):12–20. doi: 10.1159/000506466. PMID: 33326970.33326970
10 Honkala E, Honkala S, Shyama M, Field trial on caries prevention with xylitol candies among disabled school students. Caries Res. 2006;40(6):508–13. doi: 10.1159/000095650. PMID: 17063022.17063022
11 Isokangas P, Alanen P, Tiekso J, Xylitol chewing gum in caries prevention: a field study in children. J Am Dent Assoc. 1988 Aug;117(2):315–20. doi: 10.1016/S0002-8177(88)72017-6. PMID: 3166474.3166474
12 Kandelman D, Bär A, Hefti A. Collaborative WHO xylitol field study in French Polynesia. I. Baseline prevalence and 32-month caries increment. Caries Res. 1988;22(1):55–62. doi: 10.1159/000261084. PMID: 3422062.3422062
13 Kandelman D, Gagnon G. A 24-month clinical study of the incidence and progression of dental caries in relation to consumption of chewing gum containing xylitol in school preventive programs. J Dent Res. 1990 Nov;69(11):1771–5. PMID: 2229617.2229617
14 Lee W, Spiekerman C, Heima M, The effectiveness of xylitol in a school-based cluster-randomized clinical trial. Caries Res. 2015;49(1):41–9. doi: 10.1159/000360869. PMID: 25428785.25428785
15 Lenkkeri AM, Pienihakkinen K, Hurme S, The caries-preventive effect of xylitol/maltitol and erythritol/maltitol lozenges: results of a double-blinded, cluster-randomized clinical trial in an area of natural fluoridation. Int J Paediatr Dent. 2012 May;22(3):180–90. doi: 10.1111/j.1365-263X.2011.01182.x. PMID: 21951305.21951305
16 Liu HY, Hung HC, Hsiao SY, Impact of 24-month fluoride tablet program on children with disabilities in a non-fluoridated country. Res Dev Disabil. 2013;34(9):2598–605. PMID: 23747945.23747945
17 Llodra JC, Rodriguez A, Ferrer B, Efficacy of silver diamine fluoride for caries reduction in primary teeth and first permanent molars of schoolchildren: 36-month clinical trial. J Dent Res. 2005;84(8):721–4. doi: 10.1177/154405910508400807. PMID: 16040729.16040729
18 Machiulskiene V, Nyvad B, Baelum V. Caries preventive effect of sugar-substituted chewing gum. Community Dent Oral Epidemiol. 2001;29(4):278–88. doi: 10.1034/j.1600-0528.2001.290407.x. PMID: 11515642.11515642
19 Makinen KK, Bennett CA, Hujoel PP, Xylitol chewing gums and caries rates: a 40-month cohort study. J Dental Res. 1995;74(12):1904–13. doi: 10.1177/00220345950740121501. PMID: 8600188.8600188
20 Marinho CC V, Worthington HV, Walsh T, Fluoride gels for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2015(2)doi: 10.1002/14651858.CD002280.pub2. PMID: 26075879.26075879 Trials Included in Marinho 2015 Systematic Review: Abadia S. Prevenção da cárie dentária através da aplicaçãotópica de gel de flúor fosfato ácido, utilizando-se isolamentorelativo e absoluto. Baurú (SP): Universidade de São Paulo. 1978. Bijella M. Prevenção da cárie dentária através daaplicação tópica de gel e solução de fuor fosfato acidulado come sem profilaxia prévia. Bauru (SP): Universidadede São Paulo. 1981. Bryan ET, Williams JE. The cariostatic effectiveness of a phosphate-fluoride gel administered annually to school children; final results. J Public Health Dent. 1970 Winter;30(1):13–6. doi: 10.1111/j.1752-7325.1970.tb00531.x. PMID: 4149070.4149070 Cobb HB, Rozier RG, Bawden JW. A clinical study of the caries preventive effects of an APF solution and APF thixotropic gel. Pediatr Dent. 1980 Dec;2(4):263–6. PMID: 6941001.6941001 Cons NC, Janerich DT, Senning RS. Albany topical fluoride study. J Am Dent Assoc. 1970 Apr;80(4):777–81. doi: 10.14219/jada.archive.1970.0113. PMID: 4392097.4392097 DePaola PF, Soparkar M, Van Leeuwen M, The anticaries effect of single and combined topical fluoride systems in school children. Arch Oral Biol. 1980;25(10):649–53. doi: 10.1016/0003-9969(80)90095-3. PMID: 7016089.7016089 Englander HR, Keyes PH, Gestwicki M, Clinical anticaries effect of repeated topical sodium fluoride applications by mouthpieces. J Am Dent Assoc. 1967 Sep;75(3):638–44. doi: 10.14219/jada.archive.1967.0266. PMID: 4382492.4382492 Englander HR, Sherrill LT, Miller BG, Incremental rates of dental caries after repeated topical sodium fluoride applications in children with lifelong consumption of fluoridated water. J Am Dent Assoc. 1971 Feb;82(2):354–8. doi: 10.14219/jada.archive.1971.0042. PMID: 4395303.4395303 Gisselsson H, Birkhed D, Emilson CG. Effect of professional flossing with NaF or SnF2 gel on approximal caries in 13–16-year-old schoolchildren. Acta Odontol Scand. 1999;57(2):121–5. doi: 10.1080/000163599429020. PMID: 10445367.10445367 Hagan PP, Rozier RG, Bawden JW. The caries-preventive effects of full- and half-strength topical acidulated phosphate fluoride. Pediatr Dent. 1985 Sep;7(3):185–91. PMID: 3865156.3865156 Heifetz SB, Horowitz HS, Driscoll WS. Two-year evaluation of a self-administered procedure for the topical application of acidulated phosphate-fluoride; final report. J Public Health Dent. 1970 Winter;30(1):7–12. doi: 10.1111/j.1752-7325.1970.tb00530.x. PMID: 4149071.4149071 Horowitz HS, Doyle J. The effect on dental caries of topically applied acidulated phosphate-fluoride: results after three years. J Am Dent Assoc. 1971 Feb;82(2):359–65. doi: 10.14219/jada.archive.1971.0063. PMID: 4395304.4395304 Horowitz HS, Heifetz SB, McClendon BJ, Evaluation of self-administered prophylaxis and supervised toothbrushing with acidulated phosphate fluoride. Caries Res. 1974;8(1):39–51. doi: 10.1159/000260092. PMID: 4151901.4151901 Ingraham RQ, Williams JE. An evaluation of the utility of application and cariostatic effectiveness of phosphate-fluorides in solution and gel states. J Tenn State Dent Assoc. 1970 Jan;50(1):5–12. PMID: 4391820.4391820 Jiang H, Tai B, Du M, Effect of professional application of APF foam on caries reduction in permanent first molars in 6–7-year-old children: 24-month clinical trial. J Dent. 2005;33(6):469–73. PMID: CN-00528390.15935266 Mainwaring PJ, Naylor MN. A three-year clinical study to determine the separate and combined caries-inhibiting effects of sodium monofluorophosphate toothpaste and an acidulated phosphate-fluoride gel. Caries Res. 1978;12(4):202–12. doi: 10.1159/000260334. PMID: 356989.356989 Marthaler TM, König KG, Mühlemann HR. The effect of a fluoride gel used for supervised toothbrushing 15 or 30 times per year. Helv Odontol Acta. 1970 Oct;14(2):67–77. PMID: 4395021. (Considered as two trials.)4395021 Mestrinho HD, Bijella M, Bijella VT, Prevention of dental caries through topical application of APF gel with plastic trays. Odontologo Moderno. 1983;10(1–2):29–32. Olivier M, Brodeur JM, Simard PL. Efficacy of APF treatments without prior toothcleaning targeted to high-risk children. Community Dent Oral Epidemiol. 1992;20(1):38–42. PMID: 1547611.1547611 Ran F, Gedalia I, Fried M, Effectiveness of fortnightly tooth brushing with amine fluorides in caries-prone subjects. J Oral Rehabil. 1991;18(4):311–6. PMID: 1890532.1890532 Shern RJ, Duany LF, Senning RS, Clinical study of an amine fluoride gel and acidulated phosphate fluoride gel. Community Dent Oral Epidemiol. 1976;4(4):133–6. PMID: 782777.782777 Szwejda LF. Fluorides in community programs; a study of four years of various fluorides applied topically to the teeth of children in fluoridated communities. J Public Health Dent. 1972 Winter;32(1):25–33. doi: 10.1111/j.1752-7325.1972.tb03938.x. PMID: 4400348.4400348 Trubman A, Crellin JA. Effect on dental caries of self-application of acidulated phosphate fluoride paste and gel. J Am Dent Assoc. 1973 Jan;86(1):153–7. doi: 10.1016/S0002-8177(73)61038-0. PMID: 4404788.4404788 Truin GJ, van ť Hof MA. Professionally applied fluoride gel in low-caries 10.5-year-olds. Journal of dental research. 2005;84(5):418–21. PMID: CN-00515312.15840776 van Rijkom HM, Truin GJ, van ť Hof MA. Caries-inhibiting effect of professional fluoride gel application in low-caries children initially aged 4.5–6.5 years. Caries Res. 2004;38(2):115–23. PMID: 14767168.14767168
21 Marinho VC, Worthington HV, Walsh T, Fluoride varnishes for preventing dental caries in children and adolescents. Cochrane Database Syst Rev. 2013 Jul 11(7):CD002279. doi: 10.1002/14651858.CD002279.pub2. PMID: 23846772.23846772 Trials Included in Marinho 2013 Systematic Review: Arruda AO, Senthamarai Kannan R, Inglehart MR, Effect of 5% fluoride varnish application on caries among school children in rural Brazil: a randomized controlled trial. Community Dent Oral Epidemiol. 2012;40(3):267–76. PMID: 22150341.22150341 Borutta A, Kunzel W, Rubsam F. [The caries-protective efficacy of 2 fluoride varnishes in a 2-year controlled clinical trial]. Dtsch Zahn Mund Kieferheilkd Zentralbl. 1991;79(7):543–9. PMID: 1756217.1756217 Bravo M, Baca P, Llodra JC, A 24-month study comparing sealant and fluoride varnish in caries reduction on different permanent first molar surfaces. J Public Health Dent. 1997;57(3):184–6. PMID: 9383759.9383759 Clark DC, Stamm JW, Robert G, Results of a 32-month fluoride varnish study in Sherbrooke and Lac-Megantic, Canada. J Am Dent Assoc. 1985 Dec;111(6):949–53. doi: 10.14219/jada.archive.1985.0211. PMID: 3905917.3905917 Gugwad SC, Shah P, Lodaya R, Caries prevention effect of intensive application of sodium fluoride varnish in molars in children between age 6 and 7 years. J Contemp Dent Pract. 2011;12(6):408–13. doi: 10.5005/jp-journals-10024-1068. PMID: 22269229.22269229 Hardman MC, Davies GM, Duxbury JT, A cluster randomised controlled trial to evaluate the effectiveness of fluoride varnish as a public health measure to reduce caries in children. Caries Res. 2007;41(5):371–6. doi: 10.1159/000104795. PMID: 17713337.17713337 Holm GB, Holst K, Mejare I. The caries-preventive effect of a fluoride varnish in the fissures of the first permanent molar. Acta Odontol Scand. 1984;42(4):193–7. PMID: 6594021.6594021 Koch G, Petersson LG. Caries preventive effect of a fluoride-containing varnish (Duraphat) after 1 year's study. Community Dent Oral Epidemiol. 1975 Nov;3(6):262–6. PMID: 1059514.1059514 Liu BY, Lo EC, Chu CH, Randomized trial on fluorides and sealants for fissure caries prevention. J Dent Res. 2012;91(8):753–8. doi: 10.1177/0022034512452278. PMID: 22736448.22736448 Milsom KM, Blinkhorn AS, Walsh T, A cluster-randomized controlled trial: fluoride varnish in school children. Journal Dental Res. 2011;90(11):1306–11. doi: 10.1177/0022034511422063. PMID: 21921250.21921250 Moberg Skold U, Petersson LG, Lith A, Effect of school-based fluoride varnish programmes on approximal caries in adolescents from different caries risk areas. Caries Res. 2005;39(4):273–9. doi: 10.1159/000084833. PMID: 15942186.15942186 Modeer T, Twetman S, Bergstrand F. Three-year study of the effect of fluoride varnish (Duraphat) on proximal caries progression in teenagers. Scand J Dent Res. 1984 Oct;92(5):400–7. PMID: 6593805.6593805 Tagliaferro EP, Pardi V, Ambrosano GM, Occlusal caries prevention in high and low risk schoolchildren. A clinical trial. Am J Dent. 2011;24(2):109–14. PMID: 21698991.21698991 Tewari A, Chawla HS, Utreja A. Comparative evaluation of the role of NaF, APF & Duraphat topical fluoride applications in the prevention of dental caries--a 2 1/2 years study. J Indian Soc Pedod Prev Dent. 1991 Mar;8(1):28–35. PMID: 2056344.2056344
22 Muller-Bolla M, Pierre A, Lupi-Pegurier L, Effectiveness of school-based dental sealant programs among children from low-income backgrounds: a pragmatic randomized clinical trial with a follow-up of 3 years. Community Dent Oral Epidemiol. 2016;44(5):504–11. doi: 10.1111/cdoe.12241. PMID: 27349618.27349618
23 O'Rourke CA, Attrill M, Holloway PJ. Cost appraisal of a fluoride tablet programme to Manchester primary schoolchildren. Community Dent Oral Epidemiol. 1988 Dec;16(6):341–4. doi: 10.1111/j.1600-0528.1988.tb00578.x. PMID: 3144446.3144446
24 Rim KH, Jong MC, Hwang CJ, Preventive effect of subacidic 1% NaF-HF gel on dental caries in 6- to 7-year-old schoolchildren: a randomized controlled trial. Quintessence Int 0(0):318–26. doi: 10.3290/j.qi.b912653. PMID: 33491385.33491385
25 Scheinin A, Banoczy J. Xylitol and caries: the collaborative WHO oral disease preventive programme in Hungary. Int Dent J. 1985 Mar;35(1):50–7. PMID: 3858229.3858229
26 Scheinin A, Bánóczy J, Szöke J, Collaborative WHO xylitol field studies in Hungary. I. Three-year caries activity in institutionalized children. Acta Odontol Scand. 1985 Dec;43(6):327–47. doi: 10.3109/00016358509046517. PMID: 3879082.3879082
27 Scheinin A, Pienihakkinen K, Tiekso J, Collaborative WHO xylitol field studies in Hungary. VII. Two-year caries incidence in 976 institutionalized children. Acta Odontol Scand. 1985 Dec;43(6):381–7. doi: 10.3109/00016358509046523. PMID: 3879087.3879087
28 Stephen KW, Campbell D. Caries reduction and cost benefit after 3 years of sucking fluoride tablets daily at school. A double-blind trial. Br Dent J. 1978;144(7):202–6. PMID: 416842.416842
29 Uzel I, Gurlek C, Kuter B, Ertugrul F, Eden E. Caries-Preventive Effect and Retention of Glass-Ionomer and Resin-Based Sealants: A Randomized Clinical Comparative Evaluation. Biomed Res Int. 2022 Jun 20;2022:7205692. doi: 10.1155/2022/7205692. PMID: 35769675.35769675
30 Wang Z, Rong W, Xu T. Effect of Fluoride Varnish in Caries Prevention on Permanent First Molars: a 36-Month Cluster Randomized Controlled Trial. Pediatr Dent. 2021;43(2):82–7. PMID: 33892830.33892830

## Appendix A5 List of Excluded Studies

1 Adair PM, Burnside G, Pine CM. Analysis of health behaviour change interventions for preventing dental caries delivered in primary schools. Caries Research. 2013;47 Suppl 1(Suppl 1):2–12. doi: 10.1159/000351829. PMID: 24107603. Exclusion reason: Ineligible intervention24107603
2 Adair SM. Evidence-based use of fluoride in contemporary pediatric dental practice. Pediatric dentistry. 2006 Mar-Apr;28(2):133–42; discussion 92–8. PMID: 16708788. Exclusion reason: Not a study16708788
3 Agrawal N, Pushpanjali K. Feasibility of including APF gel application in a school oral health promotion program as a caries-preventive agent: a community intervention trial. J Oral Sci. 2011;53(2):185–91. doi: 10.2334/josnusd.53.185. PMID: 21712623. Exclusion reason: Ineligible population21712623
4 Ahovuo-Saloranta A, Forss H, Walsh T, Sealants for preventing dental decay in the permanent teeth. Cochrane Database of Systematic Reviews. 2013 Mar 28(3):CD001830. doi: 10.1002/14651858.CD001830.pub4. PMID: 23543512. Exclusion reason: Used as source document23543512
5 Ahovuo-Saloranta A, Hiiri A, Nordblad A, Pit and fissure sealants for preventing dental decay in the permanent teeth of children and adolescents. Cochrane Database of Systematic Reviews. 2008 Oct 08(4):CD001830. doi: 10.1002/14651858.CD001830.pub3. PMID: 18843625. Exclusion reason: Used as source document18843625
6 Ahovuo-Saloranta A, Hiiri A, Nordblad A, Pit and fissure sealants for preventing dental decay in the permanent teeth of children and adolescents. Cochrane Database of Systematic Reviews. 2004(3):CD001830. doi: 10.1002/14651858.CD001830.pub2. PMID: 15266455. Exclusion reason: Used as source document15266455
7 Al Dehailan L, Martinez-Mier EA. Prevention Program Including Fluoride Varnish and 1450-ppm Fluoride Toothpaste Targeting Young Children in Clinical Setting in UK did not Stop Sental Caries From Developing but Slowed Lesion Progression. J Evid Based Dent Pract. 2019;19(2):207–9. doi: 10.1016/j.jebdp.2019.05.013. PMID: 31326059. Exclusion reason: Ineligible population31326059
8 Al-Janabi WH, Al-Sultani HF F. The effect of maternal level of mother education on the prevalence of dental caries in school aged children. Indian J Public Health Res Dev. 2019;10(6):1264–8. doi: 10.5958/0976-5506.2019.01468.2. PMID: CN-01979814. Exclusion reason: Ineligible intervention
9 AlHumaid J, Salloot Z, Al-Ansari A, Contribution of preventive methods in controlling caries among Saudi primary schoolchildren: a population-based cross-sectional study. Acta Odontol Scand. 2018 Aug;76(6):422–6. doi: 10.1080/00016357.2018.1425899. PMID: 29320886. Exclusion reason: Ineligible intervention29320886
10 Allmark C, Green HP, Linney AD, A community study of fluoride tablets for school children in portsmouth. results after six years. Br Dent J. 1982 Dec 21;153(12):426–30. doi: 10.1038/sj.bdj.4804967. PMID: 6961931. Exclusion reason: Poor quality6961931
11 Almabadi ES, Bauman A, Akhter R, The Effect of a Personalized Oral Health Education Program on Periodontal Health in an At-Risk Population: a Randomized Controlled Trial. Int J Environ Res Public Health. 2021;18(2):846. doi: 10.3390/ijerph18020846. PMID: 33478179. Exclusion reason: Ineligible intervention33478179
12 Alrashdi M, Cervantes Mendez MJ, Farokhi MR. A Randomized Clinical Trial Preventive Outreach Targeting Dental Caries and Oral-Health-Related Quality of Life for Refugee Children. Int J Environ Res Public Health. 2021;18(4):1686. doi: 10.3390/ijerph18041686. PMID: 33578661. Exclusion reason: Ineligible intervention33578661
13 Alvesalo L, Brummer R, Le Bell Y. On the use of fissure sealants in caries prevention. A clinical study. Acta Odontol Scand. 1977;35(3):155–9. doi: 10.3109/00016357709056004. PMID: 331847. Exclusion reason: Ineligible intervention331847
14 Andruskeviciene V, Milciuviene S, Bendoraitiene E, Oral health status and effectiveness of caries prevention programme in kindergartens in Kaunas city (Lithuania). Oral health prev. 2008;6(4):343–8. doi: 10.3290/j.ohpd.a14181. PMID: 19178101. Exclusion reason: Ineligible population19178101
15 Anonymous. Evidence-based Clinical Practice Guideline for the Use of Pit-and-Fissure Sealants. Pediatric dentistry. 2016 Oct 15;38(5):120–36. doi: 10.1016/j.adaj.2016.06.001. PMID: 28206888. Exclusion reason: Used as source document28206888
16 Anonymous. Use of Pit-and-Fissure Sealants. Pediatric dentistry. 2017 Sep 15;39(6):156–72. PMID: 29179354. Exclusion reason: Used as source document29179354
17 Anonymous. Systematic review and meta-analysis of randomised controlled trials on the effectiveness of school-based dental screening versus no screening on improving oral health in children. Br Dent J. 2017 May 12;222(9):675. doi: 10.1038/sj.bdj.2017.403. PMID: 28496244. Exclusion reason: Not a study28496244
18 Anonymous. Use of Pit-and-Fissure Sealants. Pediatric dentistry. 2018 Oct 15;40(6):162–78. PMID: 32074886. Exclusion reason: Used as source document32074886
19 Anopa Y, Conway DI. Exploring the cost-effectiveness of child dental caries prevention programmes. Are we comparing apples and oranges? Evid Based Dent. 2020 03;21(1):5–7. doi: 10.1038/S41432-020-0085-7. PMID: 32221482. Exclusion reason: Ineligible outcome32221482
20 Antunes LA, Andrade MR, Leao AT, Systematic review: change in the quality of life of children and adolescents younger than 14 years old after oral health interventions: a systematic review. Pediatric dentistry. 2013 Jan-Feb;35(1):37–42. PMID: 23635896. Exclusion reason: Ineligible intervention23635896
21 Aps JK M, Lim LZ, Tong HJ, Diagnostic efficacy of and indications for intraoral radiographs in pediatric dentistry: a systematic review. European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2020 Aug;21(4):429–62. doi: 10.1007/S40368-020-00532-y. PMID: 32390073. Exclusion reason: Ineligible intervention32390073
22 Armfield JM, Spencer AJ. Community effectiveness of fissure sealants and the effect of fluoridated water consumption. Community Dent Health. 2007 Mar;24(1):4–11. PMID: 17405464. Exclusion reason: Ineligible study design17405464
23 Arora A, Khattri S, Ismail NM, School dental screening programmes for oral health. Cochrane Database of Systematic Reviews. 2019 Aug 8;8(8):Cd012595. doi: 10.1002/14651858.CD012595.pub3. PMID: 31425627. Exclusion reason: Ineligible setting31425627
24 Arora A, Khattri S, Ismail NM, School dental screening programmes for oral health. Cochrane Database of Systematic Reviews. 2017 12 21;12(12):CD012595. doi: 10.1002/14651858.CD012595.pub2. PMID: 29267989. Exclusion reason: Ineligible study design29267989
25 Arora S, Kumar JV, Moss ME. Does water fluoridation affect the prevalence of enamel fluorosis differently among racial and ethnic groups? J Public Health Dent. 2018 03;78(2):95–9. doi: 10.1111/jphd.12258. PMID: 29171664. Exclusion reason: Ineligible intervention29171664
26 Arrow P. Cost minimisation analysis of two occlusal caries preventive programmes. Community Dent Health. 2000 Jun;17(2):85–91. PMID: 11349992. Exclusion reason: Ineligible outcome11349992
27 Azarpazhooh A, Main PA. Fluoride varnish in the prevention of dental caries in children and adolescents: a systematic review. J Can Dent Assoc. 2008 Feb;74(1):73–9. PMID: 18298889. Exclusion reason: Used as source document18298889
28 Azarpazhooh A, Main PA. Pit and fissure sealants in the prevention of dental caries in children and adolescents: a systematic review. J Can Dent Assoc. 2008 Mar;74(2):171–7. PMID: 18353204. Exclusion reason: Used as source document18353204
29 Azarpazhooh A, Main PA. Fluoride varnish in the prevention of dental caries in children and adolescents: a systematic review. Hawaii Dent J. 2009 Jan-Feb;40(1):6–7, 10–3; quiz 7. PMID: 19449609. Exclusion reason: Used as source document19449609
30 Azevedo MS, Goettems ML, Torriani DD, Factors associated with dental fluorosis in school children in southern Brazil: a cross-sectional study. Pesqui Odontol Bras. 2014;28doi: 10.1590/1807-3107bor-2014.vol28.0014. PMID: 24878674. Exclusion reason: Ineligible study design24878674
31 Babaei A, Pakdaman A, Hessari H. Effect of an Oral Health Promotion Program Including Supervised Toothbrushing on 6 to 7-Year-Old School Children: A Randomized Controlled Trial. Front Dent. 2020 Aug;17(19):1–9. doi: 10.18502/fid.v17i19.4313. PMID: 33615295. Exclusion reason: Ineligible study design33615295
32 Bader JD, Rozier G, Harris R, Dental Caries Prevention: The Physician's Role in Child Oral Health Systematic Evidence Review [Internet]. Agency for Healthcare Research and Quality (US). 2004 04;04:04. PMID: 20722125. Exclusion reason: Not a study20722125
33 Bader JD, Rozier RG, Lohr KN, Physicians' roles in preventing dental caries in preschool children: a summary of the evidence for the U.S. Preventive Services Task Force. Am J Prev Med. 2004 May;26(4):315–25. doi: 10.1016/j.amepre.2003.12.001. PMID: 15110059. Exclusion reason: Ineligible population15110059
34 Bader JD, Shugars DA, Vollmer WM, Design of the xylitol for adult caries trial (X-ACT). BMC oral health. 2010;10(22)doi: 10.1186/1472-6831-10-22. PMID: 20920261. Exclusion reason: Not usable20920261
35 Badovinac RL, Morgan KE, Lefevre J, Risk assessment criteria applied to a screening exam: implications for improving the efficiency of a sealant program. J Public Health Dent. 2005;65(4):203–8. doi: 10.1111/j.1752-7325.2005.tb03019.x. PMID: 16468461. Exclusion reason: Ineligible screener16468461
36 Baginska J, Rodakowska E, Milewski R, Dental caries in primary and permanent molars in 7–8-year-old schoolchildren evaluated with Caries Assessment Spectrum and Treatment (CAST) index. BMC Oral Health. 2014 Jun 21;14:74. doi: 10.1186/1472-6831-14-74. PMID: 24952612. Exclusion reason: Ineligible outcome24952612
37 Bain MJ, Strahan JD. The effect of a 1% chlorhexidine gel in the initial therapy of chronic periodontal disease. Journal of periodontology. 1978;49(9):469–74. doi: 10.1902/jop.1978.49.9.469. PMID: 364003. Exclusion reason: Ineligible intervention364003
38 Ballestin M, Villalbi JR. [Evaluation of a program for the prevention of dental caries in the school environment]. Rev Sanid Hig Publica (Madr). 1989 Jan-Feb;63(1–2):71–9. PMID: 2636788. Exclusion reason: Not in English2636788
39 Barmes D, Barnaud J, Khambonanda S, Field trials of preventive regimens in Thailand and French Polynesia. Int Dent J. 1985 Mar;35(1):66–72. PMID: 3888852. Exclusion reason: Ineligible comparator3888852
40 Beil HA, Rozier RG. Primary health care providers' advice for a dental checkup and dental use in children. Pediatrics. 2010 Aug;126(2):e435–41. doi: 10.1542/peds.2009-2311. PMID: 20660547. Exclusion reason: Ineligible outcome20660547
41 Beiruti N, Frencken JE, vanť Hof MA, Caries-preventive effect of a one-time application of composite resin and glass ionomer sealants after 5 years. Caries research. 2006;40(1):52–9. doi: 10.1159/000088907. PMID: 16352882. Exclusion reason: Ineligible comparator16352882
42 Beltran-Aguilar ED, Griffin SO, Lockwood SA. Prevalence and trends in enamel fluorosis in the United States from the 1930s to the 1980s. J Am Dent Assoc. 2002 Feb;133(2):157–65. doi: 10.14219/jada.archive.2002.0139. PMID: 11868834. Exclusion reason: Ineligible study design11868834
43 Bennie AM, Tullis JI, Stephen KW, Five years of community preventive dentistry and health education in the county of Sutherland, Scotland. Community Dentistry & Oral Epidemiology. 1978 Jan;6(1):1–5. doi: 10.1111/j.1600-0528.1978.tb01109.x. PMID: 272258. Exclusion reason: Ineligible intervention272258
44 Bergstrom EK, Birkhed D, Granlund C, Approximal caries increment in adolescents in a low caries prevalence area in Sweden after a 3.5-year school-based fluoride varnish programme with Bifluorid 12 and Duraphat. Community Dent Oral Epidemiol. 2014;42(5):404–11. PMID: CN-01071153. Exclusion reason: Ineligible comparator24865129
45 Bernstein RS, Johnston B, Mackay K, Implementation of a primary care physician-led Cavity Clinic using silver diamine fluoride. J Public Health Dent. 2019 09;79(3):193–7. doi: 10.1111/jphd.12331. PMID: 31389017. Exclusion reason: Ineligible population31389017
46 Bijella MF, Bijella VT, Lopes ES, Comparison of dental prophylaxis and toothbrushing prior to topical APF applications. Community Dentistry & Oral Epidemiology. 1985 Aug;13(4):208–11. doi: 10.1111/j.1600-0528.1985.tb01904.x. PMID: 3930138. Exclusion reason: Ineligible intervention3930138
47 Bonner BC, Clarkson JE, Dobbyn L, Slow-release fluoride devices for the control of dental decay. Cochrane Database of Systematic Reviews. 2006 Oct 18(4):CD005101. doi: 10.1002/14651858.CD005101.pub2. PMID: 17054238. Exclusion reason: Ineligible intervention17054238
48 Borrelli B, Tooley EM, Scott-Sheldon LA. Motivational Interviewing for Parent-child Health Interventions: A Systematic Review and Meta-Analysis. Pediatric dentistry. 2015 May-Jun;37(3):254–65. PMID: 26063554. Exclusion reason: Ineligible intervention26063554
49 Borutta A, Reuscher G, Hufnagl S, Caries prevention with fluoride varnishes among preschool children. Gesundheitswesen (Bundesverband der Arzte des Offentlichen Gesundheitsdienstes (Germany)). 2006;68(11):731–4. doi: 10.1055/s-2006-927247. PMID: CN-00574796. Exclusion reason: Ineligible population17199209
50 Bratthall D, Serinirach R, Rapisuwon S, A study into the prevention of fissure caries using an antimicrobial varnish. Int Dent J. 1995;45(4):245–54. PMID: 7558363. Exclusion reason: Ineligible intervention7558363
51 Bruun C, Bille J, Hansen KT, Three-year caries increments after fluoride rinses or topical applications with a fluoride varnish. Community Dent Oral Epidemiol. 1985;13(6):299–303. doi: 10.1111/j.1600-0528.1985.tb00460.x. PMID: 3910338. Exclusion reason: Ineligible comparator3910338
52 Buckley LA. An investigation of a simple method for screening periodontal patients in general practice. J Ir Dent Assoc. 1988;34(4):138–42. PMID: 3273307. Exclusion reason: Ineligible intervention3273307
53 Burgette JM, Mestre Y, Martin B, Success rates of pediatric dental referrals made by public health dental hygiene practitioners. J Public Health Dent. 2021 Sep;81(3):169–77. doi: 10.1111/jphd.12428. PMID: 33210783. Exclusion reason: Ineligible outcome33210783
54 Burns J, Hollands K. Nano Silver Fluoride for preventing caries. Evid Based Dent. 2015 Mar;16(1):8–9. doi: 10.1038/sj.ebd.6401073. PMID: 25909929. Exclusion reason: Not a study25909929
55 Burt BA, Berman DS, Silverstone LM. Sealant retention and effects on occlusal caries after 2 years in a public program. Community Dentistry & Oral Epidemiology. 1977 Jan;5(1):15–21. doi: 10.1111/j.1600-0528.1977.tb01612.x. PMID: 318957. Exclusion reason: Ineligible intervention318957
56 Buyukkaplan US, Guldag MU. Evaluation of mandibular bone mineral density using the dual-energy X-ray absorptiometry technique in edentulous subjects living in an endemic fluorosis region. Dentomaxillofac Radiol. 2012 Jul;41(5):405–10. doi: 10.1259/dmfr/20380362. PMID: 22241885. Exclusion reason: Ineligible outcome22241885
57 Campus G, Cagetti MG, Sale S, Cariogram validity in schoolchildren: a two-year follow-up study. Caries Research. 2012;46(1):16–22. doi: 10.1159/000334932. PMID: 22222621. Exclusion reason: Ineligible intervention22222621
58 Campus G, Cagetti MG, Sale S, Six months of high-dose xylitol in high-risk caries subjects-a 2-year randomised, clinical trial. Clin Oral Investig. 2013;17(3):785–91. doi: 10.1007/S00784-012-0774-5. PMID: 22791282. Exclusion reason: Ineligible comparator22791282
59 Canga M, Malagnino G, Malagnino VA, Effectiveness of Sealants Treatment in Permanent Molars: A Longitudinal Study. Jaypee's int. 2021 Jan-Feb;14(1):41–5. doi: 10.5005/jp-journals-10005-1878. PMID: 34326582. Exclusion reason: Ineligible study design34326582
60 Canga M, Malagnino VA, Malagnino I, Effectiveness of Fluoridation Depending on Periodicity in 6–10-year-old Children. Jaypee's int. 2019 Jul-Aug;12(4):280–2. doi: 10.5005/jp-journals-10005-1648. PMID: 31866710. Exclusion reason: Ineligible study design31866710
61 Cao HZ, Wang S, Pan Y. [An investigation of the clinical effect of the 0.3% Triclosan varnish on caries prevention of primary teeth]. Shanghai Kou Qiang Yi Xue/Shanghai Journal of Stomatology. 2007 Feb;16(1):8–10. PMID: 17377691. Exclusion reason: Ineligible population17377691
62 Carey CM. Focus on fluorides: update on the use of fluoride for the prevention of dental caries. The Journal of Evidencebased Dental Practice. 2014 Jun;14 Suppl:95–102. doi: 10.1016/j.jebdp.2014.02.004. PMID: 24929594. Exclusion reason: Not a study24929594
63 Carlsson A, Jonsson Y, Svensson K, Pit and fissure sealing and mutans streptococci levels in saliva. Am J Dent. 1992 Oct;5(5):280–2. PMID: 1299258. Exclusion reason: Ineligible outcome1299258
64 Carlsson A, Petersson M, Twetman S. 2-year clinical performance of a fluoride-containing fissure sealant in young schoolchildren at caries risk. Am J Dent. 1997;10(3):115–9. PMID: 9545884. Exclusion reason: Ineligible population9545884
65 Carlsson P, Struzycka I, Wierzbicka M, Effect of a preventive program on dental caries and mutans streptococci in Polish schoolchildren. Community Dentistry & Oral Epidemiology. 1988 Oct;16(5):253–7. doi: 10.1111/j.1600-0528.1988.tb01768.x. PMID: 3180711. Exclusion reason: Ineligible comparator3180711
66 Carvalho TS, Kehrle HM, Sampaio FC. Prevalence and severity of dental fluorosis among students from Joao Pessoa, PB, Brazil. Pesqui Odontol Bras. 2007 Jul-Sep;21(3):198–203. doi: 10.1590/S1806-83242007000300002. PMID: 17710283. Exclusion reason: Ineligible outcome17710283
67 Celeste RK, Luz PB. Independent and Additive Effects of Different Sources of Fluoride and Dental Fluorosis. Pediatric dentistry. 2016;38(3):233–8. PMID: 27306248. Exclusion reason: Ineligible study design27306248
68 Chabadel O, Veronneau J, Montal S, Effectiveness of pit and fissure sealants on primary molars: a 2-yr split-mouth randomized clinical trial. Eur J Oral Sci. 2021;129(1):e12758. doi: 10.1111/eos.12758. PMID: 33377533. Exclusion reason: Ineligible intervention33377533
69 Chachra S, Dhawan P, Kaur T, The most effective and essential way of improving the oral health status education. Journal of the indian society of pedodontics and preventive dentistry. 2011;29(3):216–21. doi: 10.4103/0970-4388.85825. PMID: 21985877. Exclusion reason: Ineligible country21985877
70 Chaffee BW, Cheng J, Featherstone JD. Baseline caries risk assessment as a predictor of caries incidence. J Dent. 2015 May;43(5):518–24. doi: 10.1016/j.jdent.2015.02.013. PMID: 25731155. Exclusion reason: Ineligible intervention25731155
71 Chaves SC, Vieira-Da-Silva LM. [Preventive strategies in the control of dental caries: a research synthesis]. Cad Saude Publica. 2002 Jan-Feb;18(1):129–39. doi: 10.1590/S0102-311x2002000100014. PMID: 11910432. Exclusion reason: Not in English11910432
72 Chen S, Li B, Lin S, Change of urinary fluoride and bone metabolism indicators in the endemic fluorosis areas of southern China after supplying low fluoride public water. BMC Public Health. 2013;13(156)doi: 10.1186/1471-2458-13-156. PMID: 23425550. Exclusion reason: Ineligible intervention23425550
73 Chestnutt IG, Jones PR, Jacobson AP, Prevalence of clinically apparent recurrent caries in Scottish adolescents, and the influence of oral hygiene practices. Caries research. 1995;29(4):266–71. doi: 10.1159/000262080. PMID: 7656295. Exclusion reason: Ineligible study design7656295
74 Chibinski AC, Wambier LM, Feltrin J, Silver Diamine Fluoride Has Efficacy in Controlling Caries Progression in Primary Teeth: A Systematic Review and Meta-Analysis. Caries Research. 2017;51(5):527–41. doi: 10.1159/000478668. PMID: 28972954. Exclusion reason: Used as source document28972954
75 Chong GT, Evans RW, Dennison PJ. Screening for caries in targeted schools in the Blue Mountains and Hawkesbury districts, New South Wales, Australia: an evaluation of the School Assessment Program. Journal of Investigative & Clinical Dentistry. 2011 Nov;2(4):259–67. doi: 10.1111/j.2041-1626.2011.00069.x. PMID: 25426897. Exclusion reason: Ineligible outcome25426897
76 Chong LY, Clarkson JE, Dobbyn-Ross L, Slow-release fluoride devices for the control of dental decay. Cochrane Database of Systematic Reviews. 2018 03 01;3(3):CD005101. doi: 10.1002/14651858.CD005101.pub4. PMID: 29495063. Exclusion reason: Ineligible intervention29495063
77 Chu CH, Lo EC, Lin HC. Effectiveness of silver diamine fluoride and sodium fluoride varnish in arresting dentin caries in Chinese pre-school children. Journal of dental research. 2002;81(11):767–70. doi: 10.1177/0810767. PMID: CN-00410982. Exclusion reason: Ineligible population12407092
78 Cirkel L, Konrad M, Kostev K. Prevalence of and reasons for referral of primary care outpatients to dentists in Germany. Int J Clin Pharmacol Ther. 2021 Mar;59(3):182–8. doi: 10.5414/CP203881. PMID: 33210995. Exclusion reason: Ineligible outcome33210995
79 Cline JT, Messer LB. Long term retention of sealants applied by inexperienced operators in Minneapolis. Community Dentistry & Oral Epidemiology. 1979 Aug;7(4):206–12. doi: 10.1111/j.1600-0528.1979.tb01217.x. PMID: 391475. Exclusion reason: Ineligible outcome391475
80 Colaizzi LR, Tomar SL, Urdegar SM, Does the Structure of Dental Hygiene Instruction Impact Plaque Control in Primary School Students? J Dent Hyg. 2015 Jun;89(3):180–9. PMID: 26077537. Exclusion reason: Ineligible outcome26077537
81 Colvara BC, Faustino-Silva DD, Meyer E, Motivational interviewing for preventing early childhood caries: A systematic review and meta-analysis. Community Dentistry & Oral Epidemiology. 2020 Sep 30;30:30. doi: 10.1111/cdoe.12578. PMID: 33000877. Exclusion reason: Ineligible population33000877
82 Community Preventive Services Task Force. Preventing Dental Caries: School-based Dental Sealant Delivery Programs. Atlanta, GA: US Department of Health and Human Services, Community Preventive Services Task Force; 2013. https://www.thecommunityguide.org/findings/dental-caries-cavities-school-based-dental-sealant-delivery-programsexternal icon. Accessed November 20, 2020. Exclusion reason: Used as source document
83 Condo R, Cioffi A, Riccio A, Sealants in dentistry: a systematic review of the literature. Oral Implantol. 2013 Mar;6(3):67–74. PMID: 24772264. Exclusion reason: Used as source document24772264
84 Contreras V, Toro MJ, Elías-Boneta AR, Effectiveness of silver diamine fluoride in caries prevention and arrest: a systematic literature review. Gen Dent. 2017 May-Jun;65(3):22–9. PMID: 28475081. Exclusion reason: Used as source document28475081
85 Conway DI, MacPherson LM, Stephen KW, Prevalence of dental fluorosis in children from non-water-fluoridated Halmstad, Sweden: fluoride toothpaste use in infancy. Acta Odontol Scand. 2005 Feb;63(1):56–63. doi: 10.1080/00016350510019748. PMID: 16095064. Exclusion reason: Ineligible study design16095064
86 Cooney PV, Hardwick F. A fissure sealant pilot project in a third party insurance program in Manitoba. J Can Dent Assoc. 1994 Feb;60(2):140–1, 4–5. PMID: 8111658. Exclusion reason: Ineligible comparator8111658
87 Cooper AM, O'Malley LA, Elison SN, Primary school-based behavioural interventions for preventing caries. Cochrane Database of Systematic Reviews. 2013 May 31;5(5):CD009378. doi: 10.1002/14651858.CD009378.pub2. PMID: 23728691. Exclusion reason: Ineligible intervention23728691
88 Croxson LJ. A simplified periodontal screening examination: the Community Periodontal Index of Treatment Needs (WHO) in general practice. Int Dent J. 1984 Mar;34(1):28–34. PMID: 6584398. Exclusion reason: Not a study6584398
89 Crystal YO, Marghalani AA, Ureles SD, Use of silver diamine fluoride for dental caries management in children and adolescents, including those with special health care needs. Pediatric dentistry. 2017 Sep 15;39(5):135–45. PMID: 29070149. Exclusion reason: Used as source document29070149
90 Cueto AU, Barraza AS, Munoz DA, Evaluation of an Oral Health Promotion and Preventive Programme: A Case-Control Study. Oral health prev. 2016;14(1):49–54. doi: 10.3290/j.ohpd.a34994. PMID: 26525119. Exclusion reason: Ineligible study design26525119
91 Cunha-Cruz J, Milgrom P, Shirtcliff RM, "Everybody brush!": protocol for a parallel-group randomized controlled trial of a family-focused primary prevention program with distribution of oral hygiene products and education to increase frequency of toothbrushing. JMIR Res Protoc. 2015 May 22;4(2):e58. doi: 10.2196/resprot.4485. PMID: 26002091. Exclusion reason: Ineligible intervention26002091
92 Curtis AM, Levy SM, Cavanaugh JE, Decline in Dental Fluorosis Severity during Adolescence: A Cohort Study. Journal of Dental Research. 2020 04;99(4):388–94. doi: 10.1177/0022034520906089. PMID: 32091961. Exclusion reason: Ineligible study design32091961
93 Cury JA, de Oliveira BH, dos Santos AP, Are fluoride releasing dental materials clinically effective on caries control? Dent Mater. 2016 Mar;32(3):323–33. doi: 10.1016/j.dental.2015.12.002. PMID: 26777115. Exclusion reason: Not a study26777115
94 Cutress T, Howell PT, Finidori C, Caries preventive effect of high fluoride and xylitol containing dentifrices. J Dent Child. 1992 Jul-Aug;59(4):313–8. PMID: 1430505. Exclusion reason: Ineligible intervention1430505
95 D'Cruz AM, Aradhya S. Impact of oral health education on oral hygiene knowledge, practices, plaque control and gingival health of 13- to 15-year-old school children in Bangalore city. Int. 2013 May;11(2):126–33. doi: 10.1111/j.1601-5037.2012.00563.x. PMID: 22747831. Exclusion reason: Ineligible intervention22747831
96 Daouda F, Aida K, Mbacke LC, Assessment of dental caries prevention program applied to a cohort of elementary school children of Kebemer, a city in Senegal. Journal of International Society of Preventive & Community Dentistry. 2016 Aug;6(Suppl 2):S105–10. doi: 10.4103/2231-0762.189736. PMID: 27652240. Exclusion reason: Ineligible study design27652240
97 Davis MM, Hilton TJ, Benson S, Unmet dental needs in rural primary care: a clinic-, community-, and practice-based research network collaborative. J Am Board Fam Med. 2010 Jul-Aug;23(4):514–22. doi: 10.3122/jabfm.2010.04.090080. PMID: 20616294. Exclusion reason: Ineligible outcome20616294
98 de Farias IA, de Araujo Souza GC, Ferreira MA. A health education program for Brazilian public schoolchildren: the effects on dental health practice and oral health awareness. J Public Health Dent. 2009;69(4):225–30. doi: 10.1111/j.1752-7325.2009.00127.x. PMID: 19453867. Exclusion reason: Ineligible intervention19453867
99 de Jongh A, Muris P, ter Horst G, One-session cognitive treatment of dental phobia: preparing dental phobics for treatment by restructuring negative cognitions. Behaviour research and therapy. 1995;33(8):947–54. doi: 10.1016/0005-7967(95)00027-u. PMID: 7487854. Exclusion reason: Ineligible outcome7487854
100 de Luca-Fraga LR, Pimenta LA. Clinical evaluation of glass-ionomer/resin-based hybrid materials used as pit and fissure sealants. Quintessence Int. 2001 Jun;32(6):463–8. PMID: 11491626. Exclusion reason: Ineligible comparator11491626
101 de Silva AM, Hegde S, Akudo Nwagbara B, Community-based population-level interventions for promoting child oral health. Cochrane Database of Systematic Reviews. 2016 Sep 15;9(9):CD009837. doi: 10.1002/14651858.CD009837.pub2. PMID: 27629283. Exclusion reason: Used as source document27629283
102 de Sousa FS O, Dos Santos AP P, Nadanovsky P, Fluoride Varnish and Dental Caries in Preschoolers: A Systematic Review and Meta-Analysis. Caries Research. 2019;53(5):502–13. doi: 10.1159/000499639. PMID: 31220835. Exclusion reason: Ineligible population31220835
103 Deery C. Strong evidence for the effectiveness of resin based sealants. Evid Based Dent. 2013 Sep;14(3):69–70. doi: 10.1038/sj.ebd.6400945. PMID: 24071670. Exclusion reason: Not a study24071670
104 Disney JA, Graves RC, Stamm JW, The University of North Carolina Caries Risk Assessment study: further developments in caries risk prediction. Community Dentistry & Oral Epidemiology. 1992 Apr;20(2):64–75. doi: 10.1111/j.1600-0528.1992.tb00679.x. PMID: 1555390. Exclusion reason: Ineligible intervention1555390
105 Do LG, Spencer AJ. Decline in the prevalence of dental fluorosis among South Australian children. Community Dentistry & Oral Epidemiology. 2007 Aug;35(4):282–91. doi: 10.1111/j.1600-0528.2007.00314.x. PMID: 17615015. Exclusion reason: Ineligible study design17615015
106 Dodhia SA, West NX, Thomas SJ, Examining the causal association between 25-hydroxyvitamin D and caries in children and adults: a two-sample Mendelian randomization approach. Wellcome Open Res. 2020;5:281. doi: 10.12688/wellcomeopenres.16369.2. PMID: 34386609. Exclusion reason: Ineligible study design34386609
107 Donaldson M, Kinirons M. Effectiveness of the school dental screening programme in stimulating dental attendance for children in need of treatment in Northern Ireland. Community Dent Oral Epidemiol. 2001;29(2):143–9. doi: 10.1034/j.1600-0528.2001.290209.x. PMID: 11300174. Exclusion reason: Ineligible setting11300174
108 Downer MC. Caries prediction from initial measurements in clinical trial subjects. Pharmacol Ther Dent. 1978;3(2–4):117–22. PMID: 286370. Exclusion reason: Ineligible study design286370
109 Duane B. Xylitol and caries prevention. Evid Based Dent. 2015 Jun;16(2):37–8. doi: 10.1038/sj.ebd.6401088. PMID: 26114781. Exclusion reason: Not a study26114781
110 Duane BG. No evidence of caries reduction found in a school xylitol and erythritol lozenge programme. Evid Based Dent. 2011 Dec;12(4):102–3. doi: 10.1038/sj.ebd.6400822. PMID: 22193650. Exclusion reason: Not a study22193650
111 Duggan G, Midda M. Clinical trial of a new fissure sealant. J Int Assoc Dent Child. 1987 Dec;18(2):17–20. PMID: 3078701. Exclusion reason: Ineligible intervention3078701
112 Dugmore CR, Rock WP. A multifactorial analysis of factors associated with dental erosion. Br Dent J. 2004 Mar 13;196(5):283–6; discussion 73. doi: 10.1038/sj.bdj.4811041. PMID: 15017418. Exclusion reason: Ineligible study design15017418
113 Effenberger S, Greenwall L, Cebula M, Cost-effectiveness and efficacy of fluoride varnish for caries prevention in South African children: A cluster-randomized controlled community trial. Community Dent Oral Epidemiol. 2022;50(5):453–60. doi: 10.1111/cdoe.12702. Exclusion reason: Ineligible intervention34676577
114 Ekman A. Dental caries and related factors--a longitudinal study of Finnish immigrant children in the north of Sweden. Swed Dent J. 1990;14(2):93–9. PMID: 2374997. Exclusion reason: Ineligible study design2374997
115 Ekuni D, Mizutani S, Kojima A, Relationship between increases in BMI and changes in periodontal status: a prospective cohort study. J Clin Periodontol. 2014 Aug;41(8):772–8. doi: 10.1111/jcpe.12273. PMID: 24813869. Exclusion reason: Ineligible study design24813869
116 Englander HR, Mellberg JR, Engler WO. Observations on dental caries in primary teeth after frequent fluoride toplications in a program involving other preventives. J Dent Res. 1978 Sep-Oct;57(9–10):855–60. doi: 10.1177/00220345780570090101. PMID: 281356. Exclusion reason: Ineligible population281356
117 Evans RW. An epidemiological assessment of the chronological distribution of dental fluorosis in human maxillary central incisors. Journal of Dental Research. 1993 May;72(5):883–90. doi: 10.1177/00220345930720050901. PMID: 8501286. Exclusion reason: Ineligible study design8501286
118 Faghihian R, Faghihian E, Kazemi A, Impact of motivational interviewing on early childhood caries: A systematic review and meta-analysis. J Am Dent Assoc. 2020 Sep;151(9):650–9. doi: 10.1016/j.adaj.2020.06.003. PMID: 32854867. Exclusion reason: Ineligible population32854867
119 Fee PA, Riley P, Worthington HV, Recall intervals for oral health in primary care patients. Cochrane Database of Systematic Reviews. 2020 10 14;10(10):CD004346. doi: 10.1002/14651858.CD004346.pub5. PMID: 33053198. Exclusion reason: Ineligible outcome33053198
120 Ferro R, Besostri A, Olivieri A, Caries experience in 14-year-olds from Northeast Italy. Is socioeconomic-status (SES) still a risk factor? Eur J Paediatr Dent. 2012 Mar;13(1):46–52. PMID: 22455528. Exclusion reason: Ineligible outcome22455528
121 Ferro R, Saran G, Beltrame A. [Prevention of caries in a district. Comparison of a target group with a control group at 7 years]. Prev Assist Dent. 1990 Sep-Oct;16(5):45–8. PMID: 2284211. Exclusion reason: Not in English2284211
122 Fischman SL, English JA, Albino JE, A comprehensive caries control program--design and evaluation of the clinical trial. Journal of Dental Research. 1977 Oct;56 Spec No:C99–103. doi: 10.1177/00220345770560032501. PMID: 273036. Exclusion reason: Ineligible comparator273036
123 Folke BD, Walton JL, Feigal RJ. Occlusal sealant success over ten years in a private practice: comparing longevity of sealants placed by dentists, hygienists, and assistants. Pediatric dentistry. 2004 Sep-Oct;26(5):426–32. PMID: 15460298. Exclusion reason: Ineligible study design15460298
124 Fraihat N, Madae'en S, Bencze Z, Clinical Effectiveness and Cost-Effectiveness of Oral-Health Promotion in Dental Caries Prevention among Children: Systematic Review and Meta-Analysis. Int J Environ Res Public Health. 2019 07 25;16(15):25. doi: 10.3390/ijerph16152668. PMID: 31349691. Exclusion reason: Ineligible intervention31349691
125 Freitas-Fernandes LB, Novaes AB, Feitosa AC, Effectiveness of an oral hygiene program for Brazilian orphans. Braz Dent J. 2002;13(1):44–8. PMID: 11870962. Exclusion reason: Ineligible intervention11870962
126 Frencken JE, Borsum-Andersson K, Makoni F, Effectiveness of an oral health education programme in primary schools in Zimbabwe after 3.5 years. Community Dent Oral Epidemiol. 2001;29(4):253–9. doi: 10.1034/j.1600-0528.2001.290403.x. PMID: 11515638. Exclusion reason: Ineligible population11515638
127 Frenkel H, Harvey I, Needs K. Oral health care education and its effect on caregivers' knowledge and attitudes: a randomised controlled trial. Community Dent Oral Epidemiol. 2002;30(2):91–100. doi: 10.1034/j.1600-0528.2002.300202.x. PMID: 12000349. Exclusion reason: Ineligible outcome12000349
128 Frostell G, Birkhed D, Edwardsson S, Effect of partial substitution of invert sugar for sucrose in combination with Duraphat treatment on caries development in preschool children: the Malmo Study. Caries research. 1991;25(4):304–10. doi: 10.1159/000261381. PMID: CN-00078452. Exclusion reason: Ineligible population1913770
129 Gambhir RS, Sohi RK, Nanda T, Impact of school based oral health education programmes in India: a systematic review. J Clin Diagn Res. 2013 Dec;7(12):3107–10. doi: 10.7860/JCDR/2013/6212.3718. PMID: 24551745. Exclusion reason: Ineligible intervention24551745
130 Gao SS, Zhang S, Mei ML, Caries remineralisation and arresting effect in children by professionally applied fluoride treatment - a systematic review. BMC Oral Health. 2016 Feb 1;16:12. doi: 10.1186/S12903-016-0171-6. PMID: 26831727. Exclusion reason: Ineligible intervention26831727
131 Gao SS, Zhao IS, Hiraishi N, Clinical trials of silver diamine fluoride in arresting caries among children: a systematic review. JDR Clinical & Translational Research. 2016;1(3):201–10. doi: 10.1177/2380084416661474. PMID: 30931743. Exclusion reason: Used as source document30931743
132 Garcia RI, Gregorich SE, Ramos-Gomez F, Absence of Fluoride Varnish-Related Adverse Events in Caries Prevention Trials in Young Children, United States. Preventing chronic disease. 2017 Feb 16;14:E17. doi: 10.5888/pcd14.160372. PMID: 28207379. Exclusion reason: Ineligible population28207379
133 Garcia-Pola M, Gonzalez-Diaz A, Garcia-Martin JM. Effect of a Preventive Oral Health Program Starting during Pregnancy: A Case-Control Study Comparing Immigrant and Native Women and Their Children. Int J Environ Res Public Health. 2021 04 13;18(8):13. doi: 10.3390/ijerph18084096. PMID: 33924511. Exclusion reason: Ineligible study design33924511
134 Gauba A, Bal IS, Jain A, School based oral health promotional intervention: Effect on knowledge, practices and clinical oral health related parameters. Contemp. 2013 Oct;4(4):493–9. doi: 10.4103/0976-237X.123056. PMID: 24403795. Exclusion reason: Ineligible intervention24403795
135 Geetha Priya PR, Asokan S, Janani RG, Effectiveness of school dental health education on the oral health status and knowledge of children: A systematic review. Indian J Dent Res. 2019 May-Jun;30(3):437–49. doi: 10.4103/ijdr.IJDR_805_18. PMID: 31397422. Exclusion reason: Used as source document31397422
136 GeethaPriya PR, Asokan S, Kandaswamy D, Effectiveness of different modes of school dental health education on the oral health status of children - an interventional study with 2-year follow-up. International journal of health promotion & education. 2020;58(1):13–27. doi: 10.1080/14635240.2019.1658536. PMID: CN-02126749. Exclusion reason: Ineligible intervention
137 George A, Villarosa AR, Ingram S, Oral health status, behaviours, food and beverage consumption of aboriginal children in Australia. Health Promot J Aust. 2021 Apr;32(2):208–15. doi: 10.1002/hpja.354. PMID: 32338802. Exclusion reason: Ineligible study design32338802
138 Going RE, Conti AJ, Haugh LD, Two-year clinical evaluation of a pit and fissure sealant. Part II. Caries initiation and progression. J Am Dent Assoc. 1976 Mar;92(3):578–85. doi: 10.14219/jada.archive.1976.0543. PMID: 1062461. Exclusion reason: Ineligible intervention1062461
139 Going RE, Haugh LD, Grainger DA, Two-year clinical evaluation of a pit and fissure sealant. Part I: Retention and loss of substance. The Journal of the American Dental Association. 1976 1976/02/01/;92(2):388–97. doi: 10.14219/jada.archive.1976.0400. Exclusion reason: Ineligible outcome
140 Going RE, Haugh LD, Grainger DA, Four-year clinical evaluation of a pit and fissure sealant. J Am Dent Assoc. 1977 Nov;95(5):972–81. doi: 10.14219/jada.archive.1977.0163. PMID: 269879. Exclusion reason: Ineligible intervention269879
141 Gold J. Silver Diamine Fluoride Prevents Caries in Primary Teeth Superior to No Treatment, Placebo, or Fluoride Varnish. The Journal of Evidencebased Dental Practice. 2020 03;20(1):101422. doi: 10.1016/j.jebdp.2020.101422. PMID: 32381404. Exclusion reason: Used as source document32381404
142 Gomez SS, Weber AA, Emilson CG. A prospective study of a caries prevention program in pregnant women and their children five and six years of age. ASDC journal of dentistry for children. 2001 2001;68(3):191–5. PMID: 11693012. Exclusion reason: Ineligible population11693012
143 Gooch BF, Griffin SO, Gray SK, Preventing dental caries through school-based sealant programs: updated recommendations and reviews of evidence. J Am Dent Assoc. 2009 Nov;140(11):1356–65. doi: 10.14219/jada.archive.2009.0070. PMID: 19884392. Exclusion reason: Not a study19884392
144 Gourley JM. A two-year study of fissure sealant in two Nova Scotia communities. J Public Health Dent. 1975 Spring;35(2):132–7. doi: 10.1111/j.1752-7325.1975.tb04037.x. PMID: 1055237. Exclusion reason: Ineligible intervention1055237
145 Goward PE. Enamel mottling in a non-fluoride community in England. Community Dentistry & Oral Epidemiology. 1976 May;4(3):111–4. doi: 10.1111/j.1600-0528.1976.tb02109.x. PMID: 1063608. Exclusion reason: Ineligible outcome1063608
146 Graham A, Tajmehr N, Deery C. School dental screening programmes for oral health: Cochrane systematic review. Evid Based Dent. 2020 09;21(3):87. doi: 10.1038/S41432-020-0114-6. PMID: 32978533. Exclusion reason: Not a study32978533
147 Granath L, Widenheim J, Birkhed D. Diagnosis of mild enamel fluorosis in permanent maxillary incisors using two scoring systems. Community Dentistry & Oral Epidemiology. 1985 Oct;13(5):273–6. doi: 10.1111/j.1600-0528.1985.tb00452.x. PMID: 3863736. Exclusion reason: Ineligible outcome3863736
148 Graves RC, McNeal DR, Haefner DP, A comparison of the effectiveness of the "Toothkeeper" and a traditional dental health education program. J Public Health Dent. 1975;35(2):85–90. doi: 10.1111/j.1752-7325.1975.tb04031.x. PMID: 1055242. Exclusion reason: Ineligible outcome1055242
149 Greenberg JR, Sinclair S, Janssen CA, An Electronic Screening System for Oral Health Examination and Collection of Critical Data in a Nonclinical Setting: Validation Trial. Compend Contin Educ Dent. 2018 May;39(5):318–24. PMID: 29714498. Exclusion reason: Ineligible intervention29714498
150 Greer MH, Larson K, Sison S. Comparative analysis of oral health indicators among young children in Hawai'i, the Republic of Palau and Territory of Guam, 1999–2000. Pac Health Dialog. 2003 Mar;10(1):6–11. PMID: 16276935. Exclusion reason: Ineligible outcome16276935
151 Gugnani N, Gugnani S. Remineralisation and arresting caries in children with topical fluorides. Evid Based Dent. 2017 06 23;18(2):41–2. doi: 10.1038/sj.ebd.6401234. PMID: 28642564. Exclusion reason: Not a study28642564
152 Guimaraes AR, Peres MA, Vieira Rde S, Self-perception of side effects by adolescents in a chlorhexidine-fluoride-based preventive oral health program. Journal of Applied Oral Science. 2006 Aug;14(4):291–6. doi: 10.1590/S1678-77572006000400015. PMID: 19089279. Exclusion reason: Ineligible intervention19089279
153 Gupta A, Sharda S, Nishant, Topical fluoride-antibacterial agent combined therapy versus topical fluoride monotherapy in preventing dental caries: a systematic review and meta-analysis. Eur Arch Paediatr Dent. 2020 Oct 1;21(6):629–46. doi: 10.1007/S40368-020-00561-7. PMID: 33006116. Exclusion reason: Ineligible outcome33006116
154 Gupta SK, Gupta RC, Seth AK, Reversal of fluorosis in children. Acta paediatrica japonica: overseas edition. 1996;38(5):513–9. doi: 10.1111/j.1442-200x.1996.tb03536.x. PMID: 8942013. Exclusion reason: Ineligible intervention8942013
155 Guzman-Armstrong S. Rampant caries. J Sch Nurs. 2005 Oct;21(5):272–8. doi: 10.1177/10598405050210050501. PMID: 16262438. Exclusion reason: Not a study16262438
156 Habbu SG, Krishnappa P. Effectiveness of oral health education in children - a systematic review of current evidence (2005–2011). Int Dent J. 2015 Apr;65(2):57–64. doi: 10.1111/idj.12137. PMID: 25345565. Exclusion reason: Ineligible intervention25345565
157 Haggblom A, Naimi-Akbar A, Lith A, Approximal caries increment in adolescents after a visual aid in combination with a comprehensive open discussion. Acta Odontol Scand. 2013;71(3–4):676–82. doi: 10.3109/00016357.2012.715189. PMID: 22900665. Exclusion reason: Ineligible intervention22900665
158 Hakojarvi HR, Selanne L, Salantera S. Child involvement in oral health education interventions a systematic review of randomised controlled studies. Community Dent Health. 2019 Nov 28;36(4):286–92. doi: 10.1922/CDH_Hakojarvi07. PMID: 31724837. Exclusion reason: Ineligible outcome31724837
159 Hamdan MA. The prevalence and severity of dental fluorosis among 12-year-old schoolchildren in Jordan. Int J Paediatr Dent. 2003 Mar;13(2):85–92. doi: 10.1046/j.1365-263x.2003.00438.x. PMID: 12605625. Exclusion reason: Ineligible intervention12605625
160 Hamp SE, Johansson LA, Karlsson R. Clinical effects of preventive regimens for young people in their early and middle teens in relation to previous experience with dental prevention. Acta Odontol Scand. 1984;42(2):99–108. doi: 10.3109/00016358409035247. PMID: 6588726. Exclusion reason: Ineligible intervention6588726
161 Hamp SE, Lindhe J, Fornell J, Effect of a field program based on systematic plaque control on caries and gingivitis in schoolchildren after 3 years. Community Dentistry & Oral Epidemiology. 1978 Jan;6(1):17–23. doi: 10.1111/j.1600-0528.1978.tb01112.x. PMID: 272260. Exclusion reason: Ineligible intervention272260
162 Hanno AG, Alamoudi NM, Almushayt AS, Effect of xylitol on dental caries and salivary Streptococcus mutans levels among a group of mother-child pairs. Journal of clinical pediatric dentistry. 2011;36(1):25–30. doi: 10.17796/jcpd.36.1.d4g77616714w3372. PMID: 22900440. Exclusion reason: Ineligible comparator22900440
163 Hawley GM, Ellwood RP, Davies RM. Dental caries, fluorosis and the cosmetic implications of different TF scores in 14-year-old adolescents. Community Dent Health. 1996 Dec;13(4):189–92. PMID: 9018880. Exclusion reason: Ineligible outcome9018880
164 Hawley GM, Wainwright-Stringer Y, Craven R, An investigation into the use of a dental hygienist in school screening. Community Dent Health. 1999 Dec;16(4):232–5. PMID: 10665177. Exclusion reason: Ineligible screener10665177
165 Heidmann JM, Arnbjerg D, Poulsen S, Development of caries in a group of Danish school-age children after cessation of systematic fluoride rinsing. Ugeskr Laeger. 1993;155(38):2995–8. PMID: 8256303. Exclusion reason: Not in English8256303
166 Heintze SD, Bastos JR, Bastos R. Urinary fluoride levels and prevalence of dental fluorosis in three Brazilian cities with different fluoride concentrations in the drinking water. Community Dentistry & Oral Epidemiology. 1998 Oct;26(5):316–23. doi: 10.1111/j.1600-0528.1998.tb01967.x. PMID: 9792123. Exclusion reason: Ineligible intervention9792123
167 Hetherington I, White DA. The diagnostic accuracy and reproducibility of school dental screening using an index of treatment need. Community Dent Health. 2004 Jun;21(2):170–4. PMID: 15228207. Exclusion reason: Ineligible intervention15228207
168 Higson JF. Caries prevention in first permanent molars by fissure sealing. A 2-year study in 6--8-year-old children. J Dent. 1976 Sep;4(5):218–22. doi: 10.1016/0300-5712(76)90051-8. PMID: 823184. Exclusion reason: Ineligible intervention823184
169 Hiiri A, Ahovuo-Saloranta A, Nordblad A, Pit and fissure sealants versus fluoride varnishes for preventing dental decay in children and adolescents. Cochrane Database of Systematic Reviews. 2006 Oct 18(4):CD003067. doi: 10.1002/14651858.CD003067.pub2. PMID: 17054158. Exclusion reason: Ineligible comparator17054158
170 Hiiri A, Ahovuo-Saloranta A, Nordblad A, Pit and fissure sealants versus fluoride varnishes for preventing dental decay in children and adolescents. Cochrane Database of Systematic Reviews. 2010 Mar 17(3):CD003067. doi: 10.1002/14651858.CD003067.pub3. PMID: 20238319. Exclusion reason: Ineligible comparator20238319
171 Hilgert LA, Leal SC, Mulder J, Caries-preventive Effect of Supervised Toothbrushing and Sealants. Journal of dental research. 2015;94(9):1218–24. doi: 10.1177/0022034515592857. PMID: 26116491. Exclusion reason: Ineligible intervention26116491
172 Hiller KA, Wilfart G, Schmalz G. Developmental enamel defects in children with different fluoride supplementation--a follow-up study. Caries Research. 1998;32(6):405–11. doi: 10.1159/000016479. PMID: 9745112. Exclusion reason: Ineligible study design9745112
173 Hintze H, Wenzel A. Accuracy of clinical diagnosis for the detection of dentoalveolar anomalies with panoramic radiography as validating criterion. J Dent Child. 1990 Mar-Apr;57(2):119–23. PMID: 2319054. Exclusion reason: Ineligible screener2319054
174 Holm AK. Effect of fluoride varnish (Duraphat) in preschool children. Community Dentistry & Oral Epidemiology. 1979 Oct;7(5):241–5. doi: 10.1111/j.1600-0528.1979.tb01225.x. PMID: 295702. Exclusion reason: Ineligible population295702
175 Holund U. Effect of a nutrition education program, "learning by teaching", on adolescents' knowledge and beliefs. Community Dent Oral Epidemiol. 1990;18(2):61–5. doi: 10.1111/j.1600-0528.1990.tb00017.x. PMID: 2335063. Exclusion reason: Ineligible outcome2335063
176 Hong CY, Hong YC, Guo MK, Prevalence of mottled enamel after 12 years of water fluoridation in Chung-hsing New Village. J Formos Med Assoc. 1990 Mar;89(3):225–30. PMID: 1974596. Exclusion reason: Ineligible intervention1974596
177 Hong L, Levy SM, Broffitt B, Timing of fluoride intake in relation to development of fluorosis on maxillary central incisors. Community Dentistry & Oral Epidemiology. 2006 Aug;34(4):299–309. doi: 10.1111/j.1600-0528.2006.00281.x. PMID: 16856950. Exclusion reason: Ineligible population16856950
178 Hong L, Levy SM, Warren JJ, Primary tooth fluorosis and amoxicillin use during infancy. J Public Health Dent. 2004;64(1):38–44. doi: 10.1111/j.1752-7325.2004.tb02724.x. PMID: 15078060. Exclusion reason: Ineligible intervention15078060
179 Honkala S, ElSalhy M, Shyama M, Sealant versus Fluoride in Primary Molars of Kindergarten Children Regularly Receiving Fluoride Varnish: one-Year Randomized Clinical Trial Follow-Up. Caries research. 2015;49(4):458–66. doi: 10.1159/000431038. PMID: 26228621. Exclusion reason: Ineligible population26228621
180 Honkala S, Runnel R, Saag M, Effect of erythritol and xylitol on dental caries prevention in children. Caries research. 2014;48(5):482–90. doi: 10.1159/000358399. PMID: 24852946. Exclusion reason: Ineligible comparator24852946
181 Horowitz LG, Dillenberg J, Rattray J. Self-care motivation: a model for primary preventive oral health behavior change. J Sch Health. 1987;57(3):114–8. doi: 10.1111/j.1746-1561.1987.tb05382.x. PMID: 3645177. Exclusion reason: Ineligible intervention3645177
182 Horst JA. Silver Fluoride as a Treatment for Dental Caries. Adv Dent Res. 2018 02;29(1):135–40. doi: 10.1177/0022034517743750. PMID: 29355428. Exclusion reason: Not a study29355428
183 Hoskin ER, Keenan AV. Can we trust visual methods alone for detecting caries in teeth? Evid Based Dent. 2016 06;17(2):41–2. doi: 10.1038/sj.ebd.6401165. PMID: 27339234. Exclusion reason: Not a study27339234
184 Hou J, Gu Y, Zhu L, Systemic review of the prevention of pit and fissure caries of permanent molars by resin sealants in children in China. Journal of Investigative & Clinical Dentistry. 2017 Feb;8(1)doi: 10.1111/jicd.12183. PMID: 26272130. Exclusion reason: Used as source document26272130
185 Hu YH, Wu SS. Fluoride in cerebrospinal fluid of patients with fluorosis. J Neurol Neurosurg Psychiatry. 1988 Dec;51(12):1591–3. doi: 10.1136/jnnp.51.12.1591. PMID: 3221229. Exclusion reason: Ineligible outcome3221229
186 Hujoel PP, Makinen KK, Bennett CA, The optimum time to initiate habitual xylitol gum-chewing for obtaining long-term caries prevention. Journal of Dental Research. 1999 Mar;78(3):797–803. doi: 10.1177/00220345990780031301. PMID: 10096456. Exclusion reason: Ineligible population10096456
187 Iida H, Kumar JV. The association between enamel fluorosis and dental caries in U.S. schoolchildren. J Am Dent Assoc. 2009 Jul;140(7):855–62. doi: 10.14219/jada.archive.2009.0279. PMID: 19571049. Exclusion reason: Ineligible outcome19571049
188 Ijaz S, Croucher RE, Marinho VC. Systematic reviews of topical fluorides for dental caries: a review of reporting practice. Caries Research. 2010;44(6):579–92. doi: 10.1159/000322132. PMID: 21150202. Exclusion reason: Ineligible outcome21150202
189 Ines Meurer M, Caffery LJ, Bradford NK, Accuracy of dental images for the diagnosis of dental caries and enamel defects in children and adolescents: A systematic review. J Telemed Telecare. 2015 Dec;21(8):449–58. doi: 10.1177/1357633X15605225. PMID: 26377122. Exclusion reason: Ineligible intervention26377122
190 Innes N, Fee PA. Is personal oral hygiene advice effective in preventing coronal dental caries? Evid Based Dent. 2019 06;20(2):52–3. doi: 10.1038/S41432-019-0028-3. PMID: 31253966. Exclusion reason: Ineligible setting31253966
191 Ismail AI, Bandekar RR. Fluoride supplements and fluorosis: a meta-analysis. Community Dent Oral Epidemiol. 1999 Feb;27(1):48–56. doi: 10.1111/j.1600-0528.1999.tb01991.x. PMID: 10086926. Exclusion reason: Used as source document10086926
192 Ismail AI, Brodeur JM, Kavanagh M, Prevalence of dental caries and dental fluorosis in students, 11–17 years of age, in fluoridated and non-fluoridated cities in Quebec. Caries Research. 1990;24(4):290–7. doi: 10.1159/000261285. PMID: 2276168. Exclusion reason: Ineligible study design2276168
193 Ismail AI, Hasson H. Fluoride supplements, dental caries and fluorosis: a systematic review. J Am Dent Assoc. 2008 Nov;139(11):1457–68. doi: 10.14219/jada.archive.2008.0071. PMID: 18978383. Exclusion reason: Ineligible population
194 Ismail AI, Messer JG, Hornett PJ. Prevalence of dental caries and fluorosis in seven- to 12-year-old children in northern Newfoundland and Forteau, Labrador. J Can Dent Assoc. 1998 Feb;64(2):118–24. PMID: 9509819. Exclusion reason: Ineligible study design9509819
195 Isokangas P, Alanen P, Tiekso J. The clinician's ability to identify caries risk subjects without saliva tests--a pilot study. Community Dentistry & Oral Epidemiology. 1993 Feb;21(1):8–10. doi: 10.1111/j.1600-0528.1993.tb00709.x. PMID: 8432109. Exclusion reason: Ineligible intervention8432109
196 Ivanovic M, Lekic P. Transient effect of a short-term educational programme without prophylaxis on control of plaque and gingival inflammation in school children. J Clin Periodontol. 1996;23(8):750–7. doi: 10.1111/j.1600-051x.1996.tb00605.x. PMID: 8877661. Exclusion reason: Ineligible intervention8877661
197 Jabin Z, Vishnupriya V, Agarwal N, Effect of 38% silver diamine fluoride on control of dental caries in primary dentition: A Systematic review. J Family Med Prim Care. 2020 Mar;9(3):1302–7. doi: 10.4103/jfmpc.jfmpc_1017_19. PMID: 32509608. Exclusion reason: Used as source document32509608
198 Jackson RJ, Newman HN, Smart GJ, The effects of a supervised toothbrushing programme on the caries increment of primary school children, initially aged 5–6 years. Caries research. 2005;39(2):108–15. doi: 10.1159/000083155. PMID: 15741722. Exclusion reason: Ineligible population15741722
199 James P, Harding M, Beecher T, Impact of Reducing Water Fluoride on Dental Caries and Fluorosis. Journal of Dental Research. 2021 05;100(5):507–14. doi: 10.1177/0022034520978777. PMID: 33345672. Exclusion reason: Ineligible intervention33345672
200 James P, Harding M, Beecher T, Fluoride And Caring for Children's Teeth (FACCT): Clinical Fieldwork Protocol. HRB open res. 2018;1:4. doi: 10.12688/hrbopenres.12799.1. PMID: 32002500. Exclusion reason: Not a study32002500
201 James P, Parnell C, Whelton H. The caries-preventive effect of chlorhexidine varnish in children and adolescents: a systematic review. Caries Research. 2010;44(4):333–40. doi: 10.1159/000315346. PMID: 20606432. Exclusion reason: Ineligible intervention20606432
202 Janakiram C, Deepan Kumar CV, Joseph J. Xylitol in preventing dental caries: A systematic review and meta-analyses. J. 2017 Jan-Jun;8(1):16–21. doi: 10.4103/0976-9668.198344. PMID: 28250669. Exclusion reason: Used as source document28250669
203 Jarvis HG, Heslop P, Kisima J, Prevalence and aetiology of juvenile skeletal fluorosis in the south-west of the Hai district, Tanzania--a community-based prevalence and case-control study. Tropical Medicine & International Health. 2013 Feb;18(2):222–9. doi: 10.1111/tmi.12027. PMID: 23198699. Exclusion reason: Ineligible study design23198699
204 Javidi H, Vettore M, Benson PE. Does orthodontic treatment before the age of 18 years improve oral health-related quality of life? A systematic review and meta-analysis. Am J Orthod Dentofacial Orthop. 2017 Apr;151(4):644–55. doi: 10.1016/j.ajodo.2016.12.011. PMID: 28364887. Exclusion reason: Ineligible intervention28364887
205 Jeppesen BA, Foldspang A. Can the development of new dental caries in Danish schoolchildren be predicted from surveillance data in the School Dental Service? Community Dentistry & Oral Epidemiology. 2006 Jun;34(3):205–12. doi: 10.1111/j.1600-0528.2006.00276.x. PMID: 16674752. Exclusion reason: Ineligible intervention16674752
206 Jin C, Yan Z, Jian-Wei L, Prevention and control of brick-tea type fluorosis--a 3-year observation in Dangxiong, Tibet. Ecotoxicol Environ Saf. 2003 Oct;56(2):222–7. doi: 10.1016/S0147-6513(03)00065-4. PMID: 12927553. Exclusion reason: Ineligible intervention12927553
207 Jodkowska E. Efficacy of pit and fissure sealing: long-term clinical observations. Quintessence international (Berlin, Germany:. 2008;1985) 39(7):593–602. PMID: 19107268. Exclusion reason: Ineligible comparator19107268
208 Joharji RM, Adenubi JO. Prevention of pit and fissure caries using an antimicrobial varnish: 9 month clinical evaluation. J Dent. 2001;29(4):247–54. doi: 10.1016/S0300-5712(00)00060-9. PMID: 11525226. Exclusion reason: Ineligible intervention11525226
209 Johnston DW, Lewis DW. Three-year randomized trial of professionally applied topical fluoride gel comparing annual and biannual applications with/without prior prophylaxis. Caries research. 1995;29(5):331–6. doi: 10.1159/000262087. PMID: 8521432. Exclusion reason: Ineligible comparator8521432
210 Jorgensen MR, Castiblanco G, Twetman S, Prevention of caries with probiotic bacteria during early childhood. Promising but inconsistent findings. Am J Dent. 2016 Jun;29(3):127–31. PMID: 27505986. Exclusion reason: Ineligible population27505986
211 Jorgensen MR, Twetman S. A systematic review of risk assessment tools for early childhood caries: is there evidence? European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2020 Apr;21(2):179–84. doi: 10.1007/S40368-019-00480-2. PMID: 31559535. Exclusion reason: Ineligible population31559535
212 Joury E, Bernabe E, Sabbah W, Systematic review and meta-analysis of randomised controlled trials on the effectiveness of school-based dental screening versus no screening on improving oral health in children. J Dent. 2017 Mar;58:1–10. doi: 10.1016/j.jdent.2016.11.008. PMID: 27884719. Exclusion reason: Ineligible setting27884719
213 Julien MG. The effect of behaviour modification techniques on oral hygiene and gingival health of 10-year-old Canadian children. Int J Paediatr Dent. 1994;4(1):3–11. doi: 10.1111/j.1365-263x.1994.tb00094.x. PMID: 7748845. Exclusion reason: Ineligible intervention7748845
214 Kadir RA, Al-Maqtari RA. Endemic fluorosis among 14-year-old Yemeni adolescents: an exploratory survey. Int Dent J. 2010 Dec;60(6):407–10. doi: 10.1922/IDJ_2545-Kadir04. PMID: 21302739. Exclusion reason: Ineligible study design21302739
215 Kallestal C, Flinck A, Allebeck P, Evaluation of caries preventive measures. Swed Dent J. 2000;24(1–2):1–11. PMID: CN-00372419. Exclusion reason: Ineligible population10997757
216 Kamppi A, Tanner T, Pakkila J, Comparison of simple screening criteria with the International Caries Detection and Assessment System classification in determining restorative treatment need. Int Dent J. 2016 Apr;66(2):63–70. doi: 10.1111/idj.12204. PMID: 26503398. Exclusion reason: Ineligible study design26503398
217 Kanellis MJ. Caries risk assessment and prevention: strategies for Head Start, Early Head Start, and WIC. J Public Health Dent. 2000;60(3):210–7; discussion 8–20. doi: 10.1111/j.1752-7325.2000.tb03330.x. PMID: 11109220. Exclusion reason: Not a study11109220
218 Kapadia H, Stallard n, Volpe n, Evaluation of a curriculum for dental health in 3rd grade school children in Mumbai, India. Journal of the Indian Society of Pedodontics and Preventive Dentistry. 1999;17(2):65–8. PMID: 10863494. Exclusion reason: Ineligible outcome10863494
219 Karademir S, Akcam M, Kuybulu AE, Effects of fluorosis on QT dispersion, heart rate variability and echocardiographic parameters in children. Anadolu Kardiyol Derg. 2011 Mar;11(2):150–5. doi: 10.5152/akd.2011.038. PMID: 21342861. Exclusion reason: Ineligible outcome21342861
220 Kashbour W, Gupta P, Worthington HV, Pit and fissure sealants versus fluoride varnishes for preventing dental decay in the permanent teeth of children and adolescents. Cochrane Database Syst Rev. 2020 Nov 4;11(11):Cd003067. doi: 10.1002/14651858.CD003067.pub5. PMID: 33142363. Exclusion reason: Ineligible comparator33142363
221 Kashbour W, Gupta P, Worthington HV, Sealants or fluoride varnishes: which treatment is better for preventing decay in the permanent back teeth of children and adolescents? 4 November 2020.; 2020. Exclusion reason: Ineligible comparator
222 Kaye EK. Daily Intake of Probiotic Lactobacilli May Reduce Caries Risk in Young Children. The Journal of Evidencebased Dental Practice. 2017 09;17(3):284–6. doi: 10.1016/j.jebdp.2017.07.005. PMID: 28865830. Exclusion reason: Ineligible intervention28865830
223 Khandare AL, Gourineni SR, Validandi V. Dental fluorosis, nutritional status, kidney damage, and thyroid function along with bone metabolic indicators in school-going children living in fluoride-affected hilly areas of Doda district, Jammu and Kashmir, India. Environ Monit Assess. 2017 Oct 23;189(11):579. doi: 10.1007/S10661-017-6288-5. PMID: 29063198. Exclusion reason: Ineligible study design
224 Khandare AL, Validandi V, Boiroju N. Fluoride Alters Serum Elemental (Calcium, Magnesium, Copper, and Zinc) Homeostasis Along with Erythrocyte Carbonic Anhydrase Activity in Fluorosis Endemic Villages and Restores on Supply of Safe Drinking Water in School-Going Children of Nalgonda District, India. Biol Trace Elem Res. 2018 Oct;185(2):289–94. doi: 10.1007/S12011-018-1271-8. PMID: 29455289. Exclusion reason: Ineligible intervention29455289
225 Khandare AL, Validandi V, Gourineni SR, Dose-dependent effect of fluoride on clinical and subclinical indices of fluorosis in school going children and its mitigation by supply of safe drinking water for 5 years: an Indian study. Environ Monit Assess. 2018 Feb 02;190(3):110. doi: 10.1007/S10661-018-6501-1. PMID: 29396763. Exclusion reason: Ineligible intervention29396763
226 Khocht A, Zohn H, Deasy M, Assessment of periodontal status with PSR and traditional clinical periodontal examination. Journal of the American Dental Association (1939). 1995;126(12):1658–65. doi: 10.14219/jada.archive.1995.0115. PMID: 7499668. Exclusion reason: Ineligible population7499668
227 Kim JM, Choi JS, Choi YH, Simplified Prediction Model for Accurate Assessment of Dental Caries Risk among Participants Aged 10–18 Years. Tohoku Journal of Experimental Medicine. 2018 10;246(2):81–6. doi: 10.1620/tjem.246.81. PMID: 30333362. Exclusion reason: Ineligible intervention30333362
228 Koch G, Petersson LG, Ryden H. Effect of flouride varnish (Duraphat) treatment every six months compared with weekly mouthrinses with 0.2 per cent NaF solution on dental caries. Swed Dent J. 1979;3(2):39–44. PMID: 288179. Exclusion reason: Ineligible comparator288179
229 Kohli R, Clemens J, Mann L, Training dental hygienists to place interim therapeutic restorations in a school-based teledentistry program: Oregon's virtual dental home. J Public Health Dent. 2021 Jun 17;17:17. doi: 10.1111/jphd.12465. PMID: 34142372. Exclusion reason: Ineligible intervention34142372
230 Kolmakow S, Honkala E, Kuzmina EM, Surface-specific effect of a mineralizing agent on the permanent teeth and on periodontal status. Journal of clinical pediatric dentistry. 1991;15(2):113–9. PMID: 1931746. Exclusion reason: Ineligible intervention1931746
231 Kugahara T, Shosenji Y, Ohashi K. Screening for periodontitis in pregnant women with salivary enzymes. J Obstet Gynaecol Res. 2008 Feb;34(1):40–6. doi: 10.1111/j.1447-0756.2007.00681.x. PMID: 18226127. Exclusion reason: Ineligible intervention18226127
232 Kuhnisch J, Ekstrand KR, Pretty I, Best clinical practice guidance for management of early caries lesions in children and young adults: an EAPD policy document. European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2016 Feb;17(1):3–12. doi: 10.1007/S40368-015-0218-4. PMID: 26732946. Exclusion reason: Not a study26732946
233 Kukleva MP. Treatment of incipient caries in children with fluoride gel. Folia Med (Plovdiv). 2002;44(1–2):50–5. PMID: 12422628. Exclusion reason: Ineligible intervention12422628
234 Kukleva MP, Isheva AV, Kondeva VK, Prevalence of dental fluorosis among 4- to 14-year-old children from the town of Dimitrovgrad (Bulgaria). Folia Med (Plovdiv). 2007;49(1–2):25–31. PMID: 18018466. Exclusion reason: Ineligible study design18018466
235 Kukleva MP, Kondeva VK. Dynamics of caries activity and caries reduction in group prophylaxis with fluoride gel. Folia medica. 2001;43(1–2):12–5. PMID: 15354458. Exclusion reason: Ineligible criteria for SRs15354458
236 Kumar JV, Swango PA. Low birth weight and dental fluorosis: is there an association? J Public Health Dent. 2000;60(3):167–71. doi: 10.1111/j.1752-7325.2000.tb03323.x. PMID: 11109214. Exclusion reason: Ineligible outcome11109214
237 Kumar RK, Reddy KS, Reddy NV, Relationship between dental fluorosis and I.Q of school going children aged 10–12 years in and around Nalgonda district-A cross-sectional study. J Indian Soc Pedod Prev Dent. 2020 Oct-Dec;38(4):332–7. doi: 10.4103/JISPPD.JISPPD_160_20. PMID: 33402613. Exclusion reason: Ineligible intervention33402613
238 Kumar V, Chahar P, Kajjari S, Fluoride, Thyroid Hormone Derangements and its Correlation with Tooth Eruption Pattern Among the Pediatric Population from Endemic and Nonendemic Fluorosis Areas. J Contemp Dent Pract. 2018 Dec 01;19(12):1512–6. PMID: 30713182. Exclusion reason: Ineligible study design30713182
239 Kutlucan A, Kale Koroglu B, Numan Tamer M, The investigation of effects of fluorosis on thyroid volume in school-age children. Medicinski Glasnik Ljekarske Komore Zenickodobojskog Kantona. 2013 Feb;10(1):93–8. PMID: 23348169. Exclusion reason: Ineligible population23348169
240 Lai H, Fann JC, Yen AM, Long-term effectiveness of school-based children oral hygiene program on oral health after 10-year follow-up. Community Dentistry & Oral Epidemiology. 2016 Jun;44(3):209–15. doi: 10.1111/cdoe.12207. PMID: 26691608. Exclusion reason: Ineligible study design26691608
241 Lai YY L, Zafar S, Leonard HM, Oral health education and promotion in special needs children: Systematic review and meta-analysis. Oral Dis. 2020 Nov 20;20:20. doi: 10.1111/odi.13731. PMID: 33215786. Exclusion reason: Ineligible population33215786
242 Lalloo R, Solanki GS. An evaluation of a school-based comprehensive public oral health care programme. Community Dent Health. 1994;11(3):152–5. PMID: 7953934. Exclusion reason: Ineligible intervention7953934
243 Lalumandier JA, Rozier RG. The prevalence and risk factors of fluorosis among patients in a pediatric dental practice. Pediatric dentistry. 1995 Jan-Feb;17(1):19–25. PMID: 7899097. Exclusion reason: Ineligible intervention7899097
244 Lam PP Y, Sardana D, Ekambaram M, Effectiveness of Pit and Fissure Sealants for Preventing and Arresting Occlusal Caries in Primary Molars: A Systematic Review and Meta-Analysis. J Evid Based Dent Pract. 2020 Jun;20(2):101404. doi: 10.1016/j.jebdp.2020.101404. PMID: 32473795. Exclusion reason: Used as source document32473795
245 Lampert LM, Lo D. Limited evidence for preventing childhood caries using fluoride supplements. Evid Based Dent. 2012;13(4):112–3. doi: 10.1038/sj.ebd.6400896. PMID: 23258179. Exclusion reason: Not a study23258179
246 Lattanzi A, Silveira FM, Guimaraes L, Effects of oral health promotion programmes on adolescents' oral health-related quality of life: A systematic review. Int. 2020 Aug;18(3):228–37. doi: 10.1111/idh.12440. PMID: 32348613. Exclusion reason: Used as source document32348613
247 Law FE, Jeffreys MH, Sheary HC. Topical applications of fluoride solutions in dental caries control. Public Health Rep. 1961 Apr;76(4):287–90. PMID: 13759649. Exclusion reason: Poor quality13759649
248 Lawrence HP, Binguis D, Douglas J, A 2-year community-randomized controlled trial of fluoride varnish to prevent early childhood caries in Aboriginal children. Community Dent Oral Epidemiol. 2008;36(6):503–16. doi: 10.1111/j.1600-0528.2008.00427.x. PMID: CN-00686841. Exclusion reason: Ineligible population18422711
249 Leal SC. Are standardised caries risk assessment models effective? Evid Based Dent. 2018 12;19(4):102–3. doi: 10.1038/sj.ebd.6401338. PMID: 30573864. Exclusion reason: Not a study30573864
250 Leske AM, Mustchin C, Bhujel N, Fidelity of motivational interviewing with families in high-caries-risk children. Community Dentistry & Oral Epidemiology. 2021 10;49(5):410–9. doi: 10.1111/cdoe.12614. PMID: 33345398. Exclusion reason: Ineligible intervention33345398
251 Leverett DH, Featherstone JD, Proskin HM, Caries risk assessment by a cross-sectional discrimination model. Journal of Dental Research. 1993 Feb;72(2):529–37. doi: 10.1177/00220345930720021001. PMID: 8423251. Exclusion reason: Ineligible intervention8423251
252 Leverett DH, Proskin HM, Featherstone JD, Caries risk assessment in a longitudinal discrimination study. Journal of Dental Research. 1993 Feb;72(2):538–43. doi: 10.1177/00220345930720021101. PMID: 8380821. Exclusion reason: Ineligible intervention8380821
253 Levinson J, Kohl K, Baltag V, Investigating the effectiveness of school health services delivered by a health provider: A systematic review of systematic reviews. PLoS ONE. 2019;14(6):e0212603. doi: 10.1371/journal.pone.0212603. PMID: 31188826. Exclusion reason: Ineligible intervention31188826
254 Li X, Zhong Y, Jiang X, Randomized clinical trial of the efficacy of dentifrices containing 1.5% arginine, an insoluble calcium compound and 1450 ppm fluoride over two years. Journal of clinical dentistry. 2015;26(1):7–12. PMID: 26054185. Exclusion reason: Ineligible intervention26054185
255 Li Y, Wang W. Predicting caries in permanent teeth from caries in primary teeth: an eight-year cohort study. Journal of Dental Research. 2002 Aug;81(8):561–6. doi: 10.1177/154405910208100812. PMID: 12147748. Exclusion reason: Ineligible intervention12147748
256 Lim S, Sohn W, Burt BA, Cariogenicity of soft drinks, milk and fruit juice in low-income african-american children: a longitudinal study. J Am Dent Assoc. 2008 Jul;139(7):959–67; quiz 95. doi: 10.14219/jada.archive.2008.0283. PMID: 18594082. Exclusion reason: Ineligible study design18594082
257 Lim S, Tellez M, Ismail AI. Estimating a Dynamic Effect of Soda Intake on Pediatric Dental Caries Using Targeted Maximum Likelihood Estimation Method. Caries Research. 2019;53(5):532–40. doi: 10.1159/000497359. PMID: 30889593. Exclusion reason: Ineligible outcome30889593
258 Lin YT, Tsai CL. Comparative anti-caries effects of tablet and liquid fluorides in cleft children. Journal of clinical dentistry. 2000;11(4):104–6. PMID: CN-00349509. Exclusion reason: Ineligible population11460274
259 Liu W, Xiong L, Li J, The anticaries effects of pit and fissure sealant in the first permanent molars of school-age children from Guangzhou: a population-based cohort study. BMC Oral Health. 2019 07 16;19(1):156. doi: 10.1186/S12903-019-0846-x. PMID: 31311541. Exclusion reason: Ineligible study design31311541
260 Llena C, Calabuig E. Risk factors associated with new caries lesions in permanent first molars in children: a 5-year historical cohort follow-up study. Clin Oral Investig. 2018 Apr;22(3):1579–86. doi: 10.1007/S00784-017-2253-5. PMID: 29063383. Exclusion reason: Ineligible study design29063383
261 Locker D, Frosina C, Murray H, Identifying children with dental care needs: evaluation of a targeted school-based dental screening program. J Public Health Dent. 2004;64(2):63–70. doi: 10.1111/j.1752-7325.2004.tb02729.x. PMID: 15180073. Exclusion reason: Ineligible study design15180073
262 Loken SY, Wang NJ, Wigen TI. Health nurses' experiences and attitudes regarding collaboration with dental personnel. BMC Oral Health. 2016 Jun 06;16(1):66. doi: 10.1186/S12903-016-0226-8. PMID: 27268261. Exclusion reason: Ineligible population27268261
263 Louw AJ, Carstens IL, Hartshorne JE. A caries preventive programme for Robertson school children--baseline data. J Dent Assoc S Afr. 1991 Sep;46(9):463–5. PMID: 1820680. Exclusion reason: Ineligible study design1820680
264 Lu D, Meng H, Xu L, New attempts to modify periodontal risk assessment for generalized aggressive periodontitis: a retrospective study. Journal of Periodontology. 2013 Nov;84(11):1536–45. doi: 10.1902/jop.2013.120427. PMID: 23305112. Exclusion reason: Ineligible intervention23305112
265 Luksamijarulkul N, Pongpanich S, Panza A. Protective factors for caries of a school-based oral health program in Bangkok, Thailand: a retrospective cohort study. Public Health. 2020 Oct;187:53–8. doi: 10.1016/j.puhe.2020.07.010. PMID: 32898761. Exclusion reason: Ineligible study design32898761
266 Lundman UA, Bolin AK, Rangne Y, Dental survey at school with the purpose to select children with no actual need of dental treatment. Swed Dent J. 1998;22(5–6):203–10. PMID: 9974204. Exclusion reason: Ineligible setting9974204
267 Luo W, Hu DY, Fan X. [Comparison between the effectiveness of two oral health education program for middle-school students]. Hua Xi Kou Qiang Yi Xue Za Zhi. 2007 Jun;25(3):266–8. PMID: 17629203. Exclusion reason: Not in English17629203
268 Luoma H, Meurman J, Helminen S, Retention of a fissure sealant with caries reduction in Finnish children after six months. Scand J Dent Res. 1973;81(7):510–2. doi: 10.1111/j.1600-0722.1973.tb00356.x. PMID: 4520613. Exclusion reason: Ineligible intervention4520613
269 MacRitchie HM, Longbottom C, Robertson M, Development of the Dundee Caries Risk Assessment Model (DCRAM)--risk model development using a novel application of CHAID analysis. Community Dentistry & Oral Epidemiology. 2012 Feb;40(1):37–45. doi: 10.1111/j.1600-0528.2011.00630.x. PMID: 21838824. Exclusion reason: Ineligible population21838824
270 Maguire A. ADA clinical recommendations on topical fluoride for caries prevention. Evid Based Dent. 2014 Jun;15(2):38–9. doi: 10.1038/sj.ebd.6401019. PMID: 24971851. Exclusion reason: Used as source document24971851
271 Makinen KK, Hujoel PP, Bennett CA, Polyol chewing gums and caries rates in primary dentition: a 24-month cohort study. Caries research. 1996;30(6):408–17. doi: 10.1159/000262352. PMID: 8946097. Exclusion reason: Ineligible study design8946097
272 Makra C. [Results of the caries prevention program in Gdollo. I. Cariologic studies]. Fogorvosi Szemle. 1990 Mar;83(3):77–81. PMID: 2323457. Exclusion reason: Not in English2323457
273 Mann J, Horesh E, Ran F, The effect of fluoride drop administration on dental caries increment--a longitudinal study. Isr J Dent Sci. 1989 Oct;2(3):148–52. PMID: 2490929. Exclusion reason: Poor quality2490929
274 Marghalani AA, Guinto E, Phan M, Effectiveness of Xylitol in Reducing Dental Caries in Children. Pediatric dentistry. 2017 Mar 15;39(2):103–10. PMID: 28390459. Exclusion reason: Used as source document28390459
275 Margolis FJ, Macauley J, Freshman E. The effects of measured doses of fluoride. A five-year preliminary report. Am J Dis Child. 1967 Jun;113(6):670–2. doi: 10.1001/archpedi.1967.02090210084007. PMID: 4381737. Exclusion reason: Ineligible population4381737
276 Marinho CC V, Chong L- Y, Worthington HV, Fluoride mouthrinses for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2021(2)doi: 10.1002/14651858.CD002284.pub2. PMID: 27472005. Exclusion reason: Ineligible intervention27472005
277 Marinho CC V, Higgins PT J, Logan S, Topical fluoride (toothpastes, mouthrinses, gels or varnishes) for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2009 or 2003;2003(1):CD002782. doi: 10.1002/14651858.CD002782. PMID: 14583954. Exclusion reason: Used as source document14583954
278 Marinho CC V, Higgins PT J, Logan S, Topical fluoride (toothpastes, mouthrinses, gels or varnishes) for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2010(1)doi: 10.1002/14651858.CD002782. PMID: 14583954. Exclusion reason: Used as source document14583954
279 Marinho CC V, Higgins PT J, Sheiham A, Combinations of topical fluoride (toothpastes, mouthrinses, gels, varnishes) versus single topical fluoride for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2009(1)doi: 10.1002/14651858.CD002781.pub2. PMID: 14973992. Exclusion reason: Ineligible comparator14973992
280 Marinho CC V, Higgins PT J, Sheiham A, One topical fluoride (toothpastes, or mouthrinses, or gels, or varnishes) versus another for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2009(1)doi: 10.1002/14651858.CD002780.pub2. PMID: 14973991. Exclusion reason: Ineligible comparator14973991
281 Marinho CC V, Worthington HV, Walsh T, Fluoride varnishes for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2014(2)doi: 10.1002/14651858.CD002279.pub2. PMID: 23846772. Exclusion reason: Used as source document23846772
282 Marinho VC. Cochrane reviews of randomized trials of fluoride therapies for preventing dental caries. European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2009 Sep;10(3):183–91. doi: 10.1007/BF03262681. PMID: 19772849. Exclusion reason: Not a study19772849
283 Marinho VC, Higgins JP, Logan S, Fluoride varnishes for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2002(3):CD002279. doi: 10.1002/14651858.CD002279. PMID: 12137653. Exclusion reason: Used as source document12137653
284 Marinho VC, Higgins JP, Logan S, Fluoride gels for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2002(2):CD002280. doi: 10.1002/14651858.CD002280. PMID: 12076446. Exclusion reason: Used as source document12076446
285 Marinho VC, Higgins JP, Logan S, Topical fluoride (toothpastes, mouthrinses, gels or varnishes) for preventing dental caries in children and adolescents. Cochrane Database of Systematic Reviews. 2003;2003(4):CD002782. doi: 10.1002/14651858.CD002782. PMID: 14583954. Exclusion reason: Used as source document14583954
286 Marinho VC, Higgins JP, Logan S, Systematic review of controlled trials on the effectiveness of fluoride gels for the prevention of dental caries in children. J Dent Educ. 2003 Apr;67(4):448–58. doi: 10.1002/j.0022-0337.2003.67.4.tb03646.x. PMID: 12749574. Exclusion reason: Used as source document12749574
287 Marino R, Villa A, Weitz A, Prevalence of fluorosis in children aged 6–9 years-old who participated in a milk fluoridation programme in Codegua, Chile. Community Dent Health. 2004 Jun;21(2):143–8. PMID: 15228203. Exclusion reason: Ineligible intervention15228203
288 Martens L, Vanobbergen J, Willems S, Determinants of early childhood caries in a group of inner-city children. Quintessence Int. 2006 Jul-Aug;37(7):527–36. PMID: 16841600. Exclusion reason: Ineligible population16841600
289 Martins FV, Vasques WF, Fonseca EM. Evaluation of the efficiency of fluoride-releasing adhesives for preventing secondary caries in-vitro: a systematic review and meta-analysis. European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2019 Feb;20(1):1–8. doi: 10.1007/S40368-018-0388-y. PMID: 30382524. Exclusion reason: Ineligible population30382524
290 Martins MT, Sardenberg F, Abreu MH, Factors associated with dental caries in Brazilian children: a multilevel approach. Community Dentistry & Oral Epidemiology. 2014 Aug;42(4):289–99. doi: 10.1111/cdoe.12087. PMID: 24354434. Exclusion reason: Ineligible study design24354434
291 Masood M, Yusof N, Hassan MI, Assessment of dental caries predictors in 6-year-old school children - results from 5-year retrospective cohort study. BMC Public Health. 2012 Nov 16;12:989. doi: 10.1186/1471-2458-12-989. PMID: 23158416. Exclusion reason: Ineligible intervention23158416
292 Mbawalla H, Masalu JR, Masatu M, Changes in adolescents' oral health status following oral health promotion activities in Tanzania. Acta Odontol Scand. 2013;71(2):333–42. doi: 10.3109/00016357.2012.680907. PMID: 22563991. Exclusion reason: Ineligible intervention22563991
293 Mejare I, Axelsson S, Dahlen G, Caries risk assessment. A systematic review. Acta Odontol Scand. 2014 Feb;72(2):81–91. doi: 10.3109/00016357.2013.822548. PMID: 23998481. Exclusion reason: Ineligible intervention23998481
294 Mejare I, Lingstrom P, Petersson LG, Caries-preventive effect of fissure sealants: a systematic review. Acta Odontol Scand. 2003 Dec;61(6):321–30. doi: 10.1080/00016350310007581. PMID: 14960003. Exclusion reason: Used as source document14960003
295 Mejare IA, Klingberg G, Mowafi FK, A systematic map of systematic reviews in pediatric dentistry--what do we really know? PLoS ONE. 2015;10(2):e0117537. doi: 10.1371/journal.pone.0117537. PMID: 25706629. Exclusion reason: Not a study25706629
296 Melo MM, Souza WV, Lima ML, [Factors associated with dental caries in preschoolers in Recife, Pernambuco State, Brazil]. Cad Saude Publica. 2011 Mar;27(3):471–85. doi: 10.1590/S0102-311x2011000300008. PMID: 21519698. Exclusion reason: Ineligible population21519698
297 Menghini G, Steiner M, Imfeld T. [Early childhood caries--facts and prevention]. Ther Umsch. 2008 Feb;65(2):75–82. doi: 10.1024/0040-5930.65.2.75. PMID: 18517061. Exclusion reason: Ineligible study design18517061
298 Meurman JH, Helminen SK, Luoma H. Caries reduction over 5 years from a single application of a fissure sealant. Scand J Dent Res. 1978 May;86(3):153–6. doi: 10.1111/j.1600-0722.1978.tb01925.x. PMID: 276913. Exclusion reason: Ineligible intervention276913
299 Meurman JH, Luoma H, Heikkila H, Caries reduction 1.5 years after application of a fissure sealant as related to dietary habits. Scand J Dent Res. 1975 Jan;83(1):1–6. doi: 10.1111/j.1600-0722.1975.tb00411.x. PMID: 1056077. Exclusion reason: Ineligible intervention1056077
300 Meyer K, Geurtsen W, Gunay H. An early oral health care program starting during pregnancy: results of a prospective clinical long-term study. Clin Oral Investig. 2010;14(3):257–64. doi: 10.1007/S00784-009-0297-x. PMID: 19543927. Exclusion reason: Ineligible population19543927
301 Micheloni F, Montanari G, Zanetti M. [Epidemiological studies of dental caries, dysgnathism and periodontal diseases in the school population of the Republic of San Marino. Result of a trial of fluoride prophylaxis]. Ig Mod. 1968;61(1):45–62. PMID: 5740381. Exclusion reason: Not in English5740381
302 Miller E, Lee JY, DeWalt DA, Impact of caregiver literacy on children's oral health outcomes. Pediatrics. 2010 Jul;126(1):107–14. doi: 10.1542/peds.2009-2887. PMID: 20547644. Exclusion reason: Ineligible population20547644
303 Milsom K, Blinkhorn A, Worthington H, The effectiveness of school dental screening: a cluster-randomized control trial. Journal of dental research. 2006;85(10):924–8. doi: 10.1177/154405910608501010. PMID: 16998133. Exclusion reason: Ineligible setting16998133
304 Mishra P, Fareed N, Battur H, Role of fluoride varnish in preventing early childhood caries: A systematic review. Dent Res J 2017 May-Jun;14(3):169–76. doi: 10.4103/1735-3327.208766. PMID: 28702057. Exclusion reason: Ineligible population28702057
305 Mitropoulos CM, Holloway PJ, Davies TG, Relative efficacy of dentifrices containing 250 or 1000 ppm F- in preventing dental caries--report of a 32-month clinical trial. Community Dent Health. 1984 Nov;1(3):193–200. PMID: 6399218. Exclusion reason: Ineligible comparator6399218
306 Mohamadkhah F, Amin Shokravi F, Karimy M, Effects of lecturing on selfcare oral health behaviors of elementary students. Med J Islam Repub Iran. 2014;28:86. PMID: 25664287. Exclusion reason: Ineligible outcome25664287
307 Monse B, Heinrich-Weltzien R, Mulder J, Caries preventive efficacy of silver diammine fluoride (SDF) and ART sealants in a school-based daily fluoride toothbrushing program in the Philippines. BMC oral health. 2012;12(52)doi: 10.1186/1472-6831-12-52. PMID: 23171244. Exclusion reason: Ineligible comparator23171244
308 Morgan MV, Crowley SJ, Wright C. Economic evaluation of a pit and fissure dental sealant and fluoride mouthrinsing program in two nonfluoridated regions of Victoria, Australia. J Public Health Dent. 1998;58(1):19–27. doi: 10.1111/j.1752-7325.1998.tb02986.x. PMID: 9608442. Exclusion reason: Ineligible intervention9608442
309 Morosini Ide A, de Oliveira DC, Ferreira Fde M, Performance of distant diagnosis of dental caries by teledentistry in juvenile offenders. Telemedicine Journal & E-Health. 2014 Jun;20(6):584–9. doi: 10.1089/tmj.2013.0202. PMID: 24693859. Exclusion reason: Ineligible intervention24693859
310 Morrant AM, Holloway PJ, Taylor GO. A novel school dental screening programme. Community Dent Health. 1995 Sep;12(3):128–32. PMID: 7584578. Exclusion reason: Ineligible outcome7584578
311 Mortazavi S, Enshaei Z, Farajzadegan Z. Development of Caries Risk Assessment Tool for Iranian Preschoolers: A Primary Validation Study. Int J Prev Med. 2017;8:92. doi: 10.4103/ijpvm.IJPVM_256_17. PMID: 29184643. Exclusion reason: Ineligible population29184643
312 Moskovitz M, Abud W, Ram D. The influence of an oral health education program provided in a community dental clinic on the prevalence of caries among 12–14 year-old children. Journal of Clinical Pediatric Dentistry. 2009;33(3):259–64. doi: 10.17796/jcpd.33.3.r3p7351l5x52737u. PMID: 19476103. Exclusion reason: Ineligible study design19476103
313 Mossey PA, Southwick CA, Wrieden WL, Fluoride supplements and changes in tooth decay on the Island of Tristan da Cunha: 1966–1996. Br Dent J. 2003 Aug 09;195(3):159–62; discussion 49. doi: 10.1038/sj.bdj.4810406. PMID: 12907985. Exclusion reason: Ineligible study design12907985
314 Mota KR, da Silva JV F, Borges CD, Effectiveness of the use of xylitol chewing gum in prevention of dental caries: A systematic review. J Indian Soc Pedod Prev Dent. 2021 Apr-Jun;39(2):113–9. doi: 10.4103/JISPPD.JISPPD_330_20. PMID: 34341229. Exclusion reason: Used as source document34341229
315 Motohashi M, Yamada H, Genkai F, Employing dmft score as a risk predictor for caries development in the permanent teeth in Japanese primary school girls. J Oral Sci. 2006 Dec;48(4):233–7. doi: 10.2334/josnusd.48.233. PMID: 17220622. Exclusion reason: Ineligible outcome17220622
316 Mucci LA, Hsieh CC, Williams PL, Birth order, sibship size, and housing density in relation to tooth loss and periodontal disease: a cohort study among Swedish twins. American Journal of Epidemiology. 2004 Mar 01;159(5):499–506. doi: 10.1093/aje/kwh063. PMID: 14977646. Exclusion reason: Ineligible study design14977646
317 Muller-Bolla M, Courson F, Lupi-Pegurier L, Effectiveness of Resin-Based Sealants with and without Fluoride Placed in a High Caries Risk Population: multicentric 2-Year Randomized Clinical Trial. Caries research. 2018;52(4):312–22. doi: 10.1159/000486426. PMID: 29495020. Exclusion reason: Ineligible comparator29495020
318 Munoz-Millan P, Zaror C, Espinoza-Espinoza G, Effectiveness of fluoride varnish in preventing early childhood caries in rural areas without access to fluoridated drinking water: a randomized control trial. Community Dent Oral Epidemiol. 2018;46(1):63–9. doi: 10.1111/cdoe.12330. PMID: 28850712. Exclusion reason: Ineligible population28850712
319 Murray JJ, Winter GB, Hurst CP. Duraphat fluoride varnish. A 2-year clinical trial in 5-year-old children. Br Dent J. 1977 Jul 05;143(1):11–7. doi: 10.1038/sj.bdj.4803939. PMID: 329846. Exclusion reason: Ineligible criteria for SRs329846
320 Murthy AK, Fareed N. Economic evaluation of school-based caries preventive programs: A systematic review. Community Dent Health. 2020 Aug 31;37(3):205–15. doi: 10.1922/CDH_00010Murthy11. PMID: 32227705. Exclusion reason: Ineligible outcome32227705
321 Naidu J, Nandlal B. Evaluation of the Effectiveness of a Primary Preventive Dental Health Education Programme Implemented Through School Teachers for Primary School Children in Mysore City. Journal of International Society of Preventive & Community Dentistry. 2017 Mar-Apr;7(2):82–9. doi: 10.4103/jispcd.JISPCD_326_16. PMID: 28462175. Exclusion reason: Ineligible setting28462175
322 Neurath C, Limeback H, Osmunson B, Dental Fluorosis Trends in US Oral Health Surveys: 1986 to 2012. JDR clinical and translational research. 2019 Mar 6;4(4):298–308. doi: 10.1177/2380084419830957. PMID: 30931722. Exclusion reason: Ineligible study design30931722
323 Newton JT, Awojobi O, Nasseripour M, A Systematic Review and Meta-Analysis of the Role of Sugar-Free Chewing Gum in Dental Caries. Jdr Clinical & Translational Research. 2020 Jul;5(3):214–23. doi: 10.1177/2380084419887178. PMID: 31743654. Exclusion reason: Ineligible intervention31743654
324 Nguyen VT N, Zaitsu T, Oshiro A, Impact of School-Based Oral Health Education on Vietnamese Adolescents: A 6-Month Study. Int J Environ Res Public Health. 2021 03 08;18(5):08. doi: 10.3390/ijerph18052715. PMID: 33800242. Exclusion reason: Ineligible intervention33800242
325 Nishino M, Yoshida S, Sobue S, Effect of topically applied ammoniacal silver fluoride on dental caries in children. The Journal of Osaka University Dental School. 1969;9:149–55. PMID: 4245744. Exclusion reason: Ineligible intervention4245744
326 Nowjack-Raymer RE, Selwitz RH, Kingman A, The prevalence of dental fluorosis in a school-based program of fluoride mouthrinsing, fluoride tablets, and both procedures combined. J Public Health Dent. 1995;55(3):165–70. doi: 10.1111/j.1752-7325.1995.tb02361.x. PMID: 7562730. Exclusion reason: Ineligible comparator7562730
327 Ohmori I, Kikuchi K, Masuhara E, Effect of the methyl methacrylate-tributylborane sealant in preventing occlusal caries. Bull Tokyo Med Dent Univ. 1976 Sep;23(3):149–55. doi: 10.11480/btmd.230303. PMID: 1071430. Exclusion reason: Ineligible population1071430
328 Okunseri CE, Hodgson B, Okunseri E, Dental sealants and restorative treatment for first molars among Medicaid enrollees. Community Dentistry & Oral Epidemiology. 2020 12;48(6):487–92. doi: 10.1111/cdoe.12560. PMID: 33020929. Exclusion reason: Ineligible study design33020929
329 Oliveira BH, Rajendra A, Veitz-Keenan A, The Effect of Silver Diamine Fluoride in Preventing Caries in the Primary Dentition: A Systematic Review and Meta-Analysis. Caries Res. 2019;53(1):24–32. doi: 10.1159/000488686. PMID: 29874642. Exclusion reason: Used as source document29874642
330 Ortiz AS, Tomazoni F, Knorst JK, Influence of socioeconomic inequalities on levels of dental caries in adolescents: A cohort study. Int J Paediatr Dent. 2020 Jan;30(1):42–9. doi: 10.1111/ipd.12572. PMID: 31454454. Exclusion reason: Ineligible study design31454454
331 Pakdaman A, Montazeri A, Evans RW. Deciduous dentition approximal caries lesion progression and regression following preventive treatment: literature review. Australian Dental Journal. 2018 12;63(4):422–8. doi: 10.1111/adj.12646. PMID: 30069879. Exclusion reason: Used as source document30069879
332 Papageorgiou SN, Dimitraki D, Kotsanos N, Performance of pit and fissure sealants according to tooth characteristics: A systematic review and meta-analysis. J Dent. 2017 Nov;66:8–17. doi: 10.1016/j.jdent.2017.08.004. PMID: 28797916. Exclusion reason: Used as source document28797916
333 Pardi V, Pereira AC, Mialhe FL, A 5-year evaluation of two glass-ionomer cements used as fissure sealants. Community Dent Oral Epidemiol. 2003;31(5):386–91. doi: 10.1034/j.1600-0528.2003.00113.x. PMID: 14667010. Exclusion reason: Ineligible intervention14667010
334 Paredes Rivera MP, Paredes Rivera M, Sandoval Navarrete J. [Effectiveness of a health education technique in Mexican children]. Pract Odontol. 1990 Jun;11(6):25–7. PMID: 2131456. Exclusion reason: Not in English2131456
335 Peng B, Petersen PE, Bian Z, Can school-based oral health education and a sugar-free chewing gum program improve oral health? Results from a two-year study in PR China. Acta Odontol Scand. 2004;62(6):328–32. doi: 10.1080/00016350410010036. PMID: 15848976. Exclusion reason: Ineligible intervention15848976
336 Pereira AC, Pardi V, Mialhe FL, A 3-year clinical evaluation of glass-ionomer cements used as fissure sealants. Am J Dent. 2003;16(1):23–7. PMID: 12744408. Exclusion reason: Ineligible intervention12744408
337 Peres MA, de Oliveira Latorre Mdo R, Sheiham A, Social and biological early life influences on severity of dental caries in children aged 6 years. Community Dentistry & Oral Epidemiology. 2005 Feb;33(1):53–63. doi: 10.1111/j.1600-0528.2004.00197.x. PMID: 15642047. Exclusion reason: Ineligible study design15642047
338 Peres MA, Liu P, Demarco FF, Income trajectories affect treatment of dental caries from childhood to young adulthood: a birth cohort study. Pesqui Odontol Bras. 2018;32:e36. doi: 10.1590/1807-3107bor-2018.vol32.0036. PMID: 29742233. Exclusion reason: Ineligible study design29742233
339 Peres MA, Sheiham A, Liu P, Sugar Consumption and Changes in Dental Caries from Childhood to Adolescence. Journal of Dental Research. 2016 Apr;95(4):388–94. doi: 10.1177/0022034515625907. PMID: 26758380. Exclusion reason: Ineligible study design26758380
340 Petersen PE, Peng B, Tai B, Effect of a school-based oral health education programme in Wuhan City, Peoples Republic of China. Int Dent J. 2004;54(1):33–41. doi: 10.1111/j.1875-595x.2004.tb00250.x. PMID: 15005471. Exclusion reason: Ineligible intervention15005471
341 Petersen PE, Razanamihaja N. Carbamide-containing polyol chewing gum and prevention of dental caries in schoolchildren in Madagascar. Int Dent J. 1999 Aug;49(4):226–30. doi: 10.1111/j.1875-595x.1999.tb00526.x. PMID: 10858758. Exclusion reason: Ineligible intervention10858758
342 Petersson LG, Arthursson L, Ostberg C, Caries-inhibiting effects of different modes of Duraphat varnish reapplication: a 3-year radiographic study. Caries research. 1991;25(1):70–3. doi: 10.1159/000261345. PMID: 2070384. Exclusion reason: Ineligible comparator2070384
343 Petersson LG, Magnusson K, Andersson H, Effect of quarterly treatments with a chlorhexidine and a fluoride varnish on approximal caries in caries-susceptible teenagers: a 3-year clinical study. Caries research. 2000;34(2):140–3. doi: 10.1159/000016581. PMID: 10773631. Exclusion reason: Ineligible intervention10773631
344 Petersson LG, Svanholm I, Andersson H, Approximal caries development following intensive fluoride mouthrinsing in teenagers. A 3-year radiographic study. Eur J Oral Sci. 1998;106(6):1048–51. PMID: 9879918. Exclusion reason: Ineligible intervention9879918
345 Petersson LG, Westerberg I. Intensive fluoride varnish program in Swedish adolescents: economic assessment of a 7-year follow-up study on proximal caries incidence. Caries research. 1994;28(1):59–63. doi: 10.1159/000261622. PMID: 8124699. Exclusion reason: Ineligible comparator8124699
346 Pienihakkinen K, Jokela J, Alanen P. Risk-based early prevention in comparison with routine prevention of dental caries: a 7-year follow-up of a controlled clinical trial; clinical and economic aspects. BMC Oral Health. 2005;5(1):2–7. doi: 10.1186/1472-6831-5-2. PMID: 15784155. Exclusion reason: Ineligible intervention15784155
347 Pine C, Adair P, Robinson L, The BBaRTS Healthy Teeth Behaviour Change Programme for preventing dental caries in primary school children: study protocol for a cluster randomised controlled trial. Trials. 2016;17(1):103. doi: 10.1186/S13063-016-1226-3. PMID: 26897029. Exclusion reason: Ineligible study design26897029
348 Pine CM, McGoldrick PM, Burnside G, An intervention programme to establish regular toothbrushing: understanding parents' beliefs and motivating children. Int Dent J. 2000;50(6):312–23. doi: 10.1111/j.1875-595x.2000.tb00581.x. PMID: 11197192. Exclusion reason: Ineligible intervention11197192
349 Plutzer K, Spencer AJ, Keirse MJ. Reassessment at 6-7 years of age of a randomized controlled trial initiated before birth to prevent early childhood caries. Community Dent Oral Epidemiol. 2012;40(2):116–24. doi: 10.1111/j.1600-0528.2011.00643.x. PMID: 22022927. Exclusion reason: Ineligible population22022927
350 Poulsen S, Kirkegaard E, Bangsbo G, Caries clinical trial of fluoride rinses in a Danish Public Child Dental Service. Community Dent Oral Epidemiol. 1984;12(5):283–7. doi: 10.1111/j.1600-0528.1984.tb01456.x. PMID: 6593146. Exclusion reason: Ineligible intervention6593146
351 Poulsen S, Thylstrup A, Christensen PF, Evaluation of a pit- and fissure-sealing program in a public dental health service after 2 years. Community Dentistry & Oral Epidemiology. 1979 Jun;7(3):154–7. doi: 10.1111/j.1600-0528.1979.tb01205.x. PMID: 287586. Exclusion reason: Ineligible intervention287586
352 Quach H. How can children be involved in developing oral health education interventions? Evid Based Dent. 2020 09;21(3):104–5. doi: 10.1038/S41432-020-0122-6. PMID: 32978543. Exclusion reason: Not a study32978543
353 Quinonez RB, Kranz AM, Lewis CW, Oral health opinions and practices of pediatricians: updated results from a national survey. Academic pediatrics. 2014 Nov-Dec;14(6):616–23. doi: 10.1016/j.acap.2014.07.001. PMID: 25439160. Exclusion reason: Ineligible outcome25439160
354 Raadal M, Laegreid O, Laegreid KV, Fissure sealing of permanent first molars in children receiving a high standard of prophylactic care. Community Dentistry & Oral Epidemiology. 1984 Apr;12(2):65–8. doi: 10.1111/j.1600-0528.1984.tb01414.x. PMID: 6584265. Exclusion reason: Ineligible comparator6584265
355 Rajendra A, Veitz‐Keenan A, Oliveira BH, Topical silver diamine fluoride for managing dental caries in children and adults. Cochrane Database Syst Rev. 2017 12 July;2017(7):411–9. doi: 10.1002/14651858.Cd012718. PMID: 28812312. Exclusion reason: Not a study28812312
356 Ramamurthy P, Rath A, Sidhu P, Sealants for preventing dental caries in primary teeth. The Cochrane database of systematic reviews. 2022;2:CD012981. doi: 10.1002/14651858.CD012981.pub2. Exclusion reason: Used as source document35146744
357 Ramamurthy P, Rath A, Sidhu P, Sealants for preventing dental caries in primary teeth. Cochrane Database of Systematic Reviews. 2018(3):Art. No.: CD012981. doi: 10.1002/14651858.Cd012981. Exclusion reason: Not a study
358 Redmond CA, Blinkhorn FA, Kay EJ, A cluster randomized controlled trial testing the effectiveness of a school-based dental health education program for adolescents. J Public Health Dent. 1999;59(1):12–7. doi: 10.1111/j.1752-7325.1999.tb03229.x. PMID: 3206197. Exclusion reason: Ineligible outcome11396038
359 Richards D. Fluoride gel effective at reducing caries in children. Evid Based Dent. 2015 Dec;16(4):108–9. doi: 10.1038/sj.ebd.6401131. PMID: 26680518. Exclusion reason: Not a study26680518
360 Richards D. Insufficient evidence that slow-release fluoride devices reduce caries. Evid Based Dent. 2015 Jun;16(2):45. doi: 10.1038/sj.ebd.6401092. PMID: 26114785. Exclusion reason: Not a study26114785
361 Richards D. The effectiveness of silver diamine fluoride in arresting caries. Evid Based Dent. 2017 10 27;18(3):70. doi: 10.1038/sj.ebd.6401250. PMID: 29075024. Exclusion reason: Not a study29075024
362 Riley P, Moore D, Ahmed F, Xylitol-containing products for preventing dental caries in children and adults. Cochrane Database of Systematic Reviews. 2015 Mar 26;2015(3):CD010743. doi: 10.1002/14651858.CD010743.pub2. PMID: 25809586. Exclusion reason: Used as source document25809586
363 Roder DM, Sundrum P, Boundy H, The effect of a pilot dental health education programme on high school students. Australian Dental Journal. 1977 Feb;22(1):6–10. doi: 10.1111/j.1834-7819.1977.tb04434.x. PMID: 266886. Exclusion reason: Ineligible intervention266886
364 Ruff RR, Barry-Godín T, Niederman R. Effect of Silver Diamine Fluoride on Caries Arrest and Prevention: The CariedAway School-Based Randomized Clinical Trial. JAMA Netw Open. 2023 Feb 1;6(2):e2255458. doi: 10.1001/jamanetworkopen.2022.55458. PMID: 36757696. Exclusion reason: Ineligible comparator36757696
365 Ruff RR, Niederman R. Comparative effectiveness of treatments to prevent dental caries given to rural children in school-based settings: protocol for a cluster randomised controlled trial. BMJ open. 2018 Apr 13;8(4):e022646. doi: 10.1136/bmjopen-2018-022646. PMID: 29654053. Exclusion reason: Ineligible comparator29654053
366 Ruff RR, Niederman R. Silver diamine fluoride versus therapeutic sealants for the arrest and prevention of dental caries in low-income minority children: study protocol for a cluster randomized controlled trial. Trials. 2018 Sep 26;19(1):523. doi: 10.1186/S13063-018-2891-1. PMID: 30257696. Exclusion reason: Ineligible comparator30257696
367 Ruff RR, Whittemore R, Grochecki M, Silver diamine fluoride and oral health-related quality of life: A review and network meta-analysis. PLoS ONE. 2022;17(2):e0261627. doi: 10.1371/journal.pone.0261627. Exclusion reason: Ineligible intervention35104291
368 Salazar M. Efetividade da aplicação semestral de verniz fluoretado no controle da cárie dentária em pré-escolares: resultados após 12 meses de acompanhamento. 2008. Exclusion reason: Ineligible population
369 Sampaio JR F, Vidal SA, de Goes PS A, Sociodemographic, Behavioral and Oral Health Factors in Maternal and Child Health: An Interventional and Associative Study from the Network Perspective. Int J Environ Res Public Health. 2021 04 08;18(8):08. doi: 10.3390/ijerph18083895. PMID: 33917677. Exclusion reason: Ineligible comparator33917677
370 Schwendicke F, Stolpe M. In-Office Application of Fluoride Gel or Varnish: Cost-Effectiveness and Expected Value of Perfect Information Analysis. Caries Research. 2017;51(3):231–9. doi: 10.1159/000458729. PMID: 28391272. Exclusion reason: Ineligible population28391272
371 Seberol E, Ökte Z. Caries arresting effect of silver diamine fluoride on primary teeth. J Dent Res. 2013;88:48. Exclusion reason: Abstract only
372 Seifo N, Cassie H, Radford JR, Silver diamine fluoride for managing carious lesions: an umbrella review. BMC Oral Health. 2019 07 12;19(1):145. doi: 10.1186/S12903-019-0830-5. PMID: 31299955. Exclusion reason: Used as source document31299955
373 Selwitz RH, Nowjack-Raymer R, Driscoll WS, Evaluation after 4 years of the combined use of fluoride and dental sealants. Community Dent Oral Epidemiol. 1995;23(1):30–5. doi: 10.1111/j.1600-0528.1995.tb00194.x. PMID: 7774174. Exclusion reason: Ineligible study design7774174
374 Senneby A, Mejare I, Sahlin NE, Diagnostic accuracy of different caries risk assessment methods. A systematic review. J Dent. 2015 Dec;43(12):1385–93. doi: 10.1016/j.jdent.2015.10.011. PMID: 26493112. Exclusion reason: Used as source document26493112
375 Seppa L, Leppanen T, Hausen H. Fluoride varnish versus acidulated phosphate fluoride gel: a 3-year clinical trial. Caries research. 1995;29(5):327–30. doi: 10.1159/000262086. PMID: 8521431. Exclusion reason: Ineligible comparator8521431
376 Seppa L, Pollanen L, Hausen H. Caries-preventive effect of fluoride varnish with different fluoride concentrations. Caries research. 1994;28(1):64–7. doi: 10.1159/000261623. PMID: 8124700. Exclusion reason: Ineligible comparator8124700
377 Seppa L, Tolonen T. Caries preventive effect of fluoride varnish applications performed two or four times a year. Scand J Dent Res. 1990;98(2):102–5. doi: 10.1111/j.1600-0722.1990.tb00947.x. PMID: 2343272. Exclusion reason: Ineligible comparator2343272
378 Seppa L, Tuutti H, Luoma H. Three-year report on caries prevention of using fluoride varnishes for caries risk children in a community with fluoridated water. Scand J Dent Res. 1982 Apr;90(2):89–94. doi: 10.1111/j.1600-0722.1982.tb01529.x. PMID: 6951261. Exclusion reason: Ineligible comparator6951261
379 Sintes JL, Elias-Boneta A, Stewart B, Anticaries efficacy of a sodium monofluorophosphate dentifrice containing xylitol in a dicalcium phosphate dihydrate base. A 30-month caries clinical study in Costa Rica. Am J Dent. 2002;15(4):215–9. PMID: 12572637. Exclusion reason: Ineligible intervention12572637
380 Sintes JL, Escalante C, Stewart B, Enhanced anticaries efficacy of a 0.243% sodium fluoride/10% xylitol/silica dentifrice: 3-year clinical results. Am J Dent. 1995;8(5):231–5. PMID: 8634157. Exclusion reason: Ineligible intervention8634157
381 Skold L, Sundquist B, Eriksson B, Four-year study of caries inhibition of intensive Duraphat application in 11–15-year-old children. Community Dent Oral Epidemiol. 1994;22(1):8–12. doi: 10.1111/j.1600-0528.1994.tb01561.x. PMID: 8143448. Exclusion reason: Ineligible comparator8143448
382 Skold UM. Approximal caries increment in relation to baseline approximal caries prevalence among adolescents in Sweden with and without a school-based fluoride varnish programme. Community Dent Health. 2016;33(4):281–5. doi: 10.1922/CDH_3951Skold05. PMID: 28537365. Exclusion reason: Ineligible comparator28537365
383 Skold UM, Lindvall AM, Rasmusson CG, Caries incidence in adolescents with low caries prevalence after cessation of weekly fluoride rinsing. Acta Odontol Scand. 2001;59(2):69–73. doi: 10.1080/000163501750157135. PMID: 11370752. Exclusion reason: Ineligible intervention11370752
384 Smail-Faugeron V, Fron-Chabouis H, Courson F. Methodological quality and implications for practice of systematic Cochrane reviews in pediatric oral health: a critical assessment. BMC Oral Health. 2014 Apr 09;14:35. doi: 10.1186/1472-6831-14-35. PMID: 24716532. Exclusion reason: Used as source document24716532
385 Smitha M, Paul ST, Nagaraj T, Comparison and Clinical Evaluation of Two Pit and Fissure Sealants on Permanent Mandibular First Molars: an In Vivo Study. J Contemp Dent Pract. 2019;20(10):1151–8. PMID: 31883249. Exclusion reason: Ineligible comparator31883249
386 Sohn W, Ismail AI, Tellez M. Efficacy of educational interventions targeting primary care providers' practice behaviors: an overview of published systematic reviews. J Public Health Dent. 2004;64(3):164–72. doi: 10.1111/j.1752-7325.2004.tb02747.x. PMID: 15341140. Exclusion reason: Ineligible intervention15341140
387 Soldani F, Wu J. School based oral health education. Evid Based Dent. 2018 Jun;19(2):36–7. doi: 10.1038/sj.ebd.6401298. PMID: 29930371. Exclusion reason: Not a study29930371
388 Soldani FA, Lamont T, Jones K, One-to-one oral hygiene advice provided in a dental setting for oral health. Cochrane Database of Systematic Reviews. 2018;10(10):CD007447. doi: 10.1002/14651858.CD007447.pub2. PMID: 30380139. Exclusion reason: Ineligible intervention30380139
389 Soltani R, Sharifirad G, Mahaki B, The Effect of Oral Health Educational Intervention Program among Mothers of Children aged 1–6, Based on the Theory of Planned Behavior. J Dent. 2020 Dec;21(4):292–9. doi: 10.30476/DENTJODS.2020.81811.0. PMID: 33344679. Exclusion reason: Ineligible population33344679
390 Sonesson M, Brechter A, Lindman R, Fluoride varnish for white spot lesion prevention during orthodontic treatment: results of a randomized controlled trial 1 year after debonding. Eur J Orthod. 2021 08 03;43(4):473–7. doi: 10.1093/ejo/cjaa055. PMID: 33009565. Exclusion reason: Ineligible outcome33009565
391 Souza BM, Santos DM S, Braga AS, Effect of a Titanium Tetrafluoride Varnish in the Prevention and Treatment of Carious Lesions in the Permanent Teeth of Children Living in a Fluoridated Region: Protocol for a Randomized Controlled Trial. JMIR Res Protoc. 2018 Jan 26;7(1):e26. doi: 10.2196/resprot.9376. PMID: 29374001. Exclusion reason: Ineligible population29374001
392 Splieth C, Forster M, Meyer G. Additional caries protection by sealing permanent first molars compared to fluoride varnish applications in children with low caries prevalence: 2-year results. Eur J Paediatr Dent. 2001 01/01;2:133–8. Exclusion reason: Ineligible comparator
393 Splieth CH, Berndt C, Alkilzy M, Efficacy of semiannual topical fluoride application in schoolchildren. Quintessence international (Berlin, Germany:. 2011;1985) 42(9):753–60. PMID: 21909500. Exclusion reason: Ineligible study design21909500
394 Stecksen-Blicks C, Holgerson PL, Twetman S. Effect of xylitol and xylitol-fluoride lozenges on approximal caries development in high-caries-risk children. Int J Paediatr Dent. 2008;18(3):170–7. doi: 10.1111/j.1365-263X.2007.00912.x. PMID: CN-00638351. Exclusion reason: Ineligible study design18341562
395 Stein C, Santos NM L, Hilgert JB, Effectiveness of oral health education on oral hygiene and dental caries in schoolchildren: Systematic review and meta-analysis. Community Dentistry & Oral Epidemiology. 2018 02;46(1):30–7. doi: 10.1111/cdoe.12325. PMID: 28815661. Exclusion reason: Ineligible intervention28815661
396 Stephen KW, Kay EJ, Tullis JI. Combined fluoride therapies. A 6-year double-blind school-based preventive dentistry study in Inverness, Scotland. Community Dent Oral Epidemiol. 1990;18(5):244–8. doi: 10.1111/j.1600-0528.1990.tb00068.x. PMID: 2249406. Exclusion reason: Ineligible comparator2249406
397 Stephen KW, Sutherland DA, Trainer J. Fissure sealing by practitioners. First year retention data in Scottish 6-year-old children. Br Dent J. 1976 Jan 20;140(2):45–51. doi: 10.1038/sj.bdj.4803701. PMID: 1061598. Exclusion reason: Poor quality1061598
398 Subedi K, Shrestha A, Bhagat T, Effectiveness of oral health education intervention among 12–15-year-old school children in Dharan, Nepal: a randomized controlled trial. BMC oral health. 2021;21(1):525. doi: 10.1186/s12903-021-01877-6. Exclusion reason: Ineligible intervention34649553
399 Sudhanthar S, Lapinski J, Turner J, Improving oral health through dental fluoride varnish application in a primary care paediatric practice. BMJ Open Quality. 2019;8(2):e000589. doi: 10.1136/bmjoq-2018-000589. PMID: 31259286. Exclusion reason: Ineligible population31259286
400 Tai BJ, Jiang H, Du MQ, Assessing the effectiveness of a school-based oral health promotion programme in Yichang City, China. Community Dent Oral Epidemiol. 2009;37(5):391–8. doi: 10.1111/j.1600-0528.2009.00484.x. PMID: 19624698. Exclusion reason: Ineligible intervention19624698
401 Tao DY, Shu CB, Lo EC, A randomized trial on the inhibitory effect of chewing gum containing tea polyphenol on caries. Journal of clinical pediatric dentistry. 2013;38(1):67–70. doi: 10.17796/jcpd.38.1.c0tm02w572488064. PMID: 24579286. Exclusion reason: Ineligible intervention24579286
402 Tavener JA, Davies GM, Davies RM, The prevalence and severity of fluorosis and other developmental defects of enamel in children who received free fluoride toothpaste containing either 440 or 1450 ppm F from the age of 12 months. Community Dent Health. 2004;21(3):217–23. PMID: 15470832. Exclusion reason: Ineligible population15470832
403 Tellez M, Gomez J, Pretty I, Evidence on existing caries risk assessment systems: are they predictive of future caries? Community Dentistry & Oral Epidemiology. 2013 Feb;41(1):67–78. doi: 10.1111/cdoe.12003. PMID: 22978796. Exclusion reason: Used as source document22978796
404 Tewari A, Chawla HS, Gopalakrishnan NS. Acidulated phosphate fluoride--3 1/2 years clinical trial on the prevention of dental caries. J Indian Soc Pedod Prev Dent. 1986 Mar;4(1):15–24. PMID: 3471879. Exclusion reason: Ineligible criteria for SRs3471879
405 Tewari A, Chawla HS, Utreja AK. Dental caries preventive effect of sodium fluoride and acidulated fluoride phosphate. 1 1/2 years clinical trial. J Indian Dent Assoc. 1983 Apr;55(4):133–8. PMID: 6582134. Exclusion reason: Ineligible criteria for SRs6582134
406 Tomasin L, Pusinanti L, Zerman N. The role of fluoride tablets in the prophylaxis of dental caries. A literature review. Ann Stomatol (Roma). 2015 Jan-Mar;6(1):1–5. PMID: 26161245. Exclusion reason: Used as source document26161245
407 Treide A, Treide B. The anticaries effectiveness of newly developed fluoride-containing gels following 3 years of clinical use in preschool children. Stomatol DDR. 1988;38(10):708–12. Exclusion reason: Ineligible population3269091
408 Tsai C, Raphael S, Agnew C, Health promotion interventions to improve oral health of adolescents: A systematic review and meta-analysis. Community Dentistry & Oral Epidemiology. 2020 Dec;48(6):549–60. doi: 10.1111/cdoe.12567. PMID: 32767825. Exclusion reason: Ineligible intervention32767825
409 Tsiklakis K, Mitsea A, Tsichlaki A, A systematic review of relative indications and contraindications for prescribing panoramic radiographs in dental paediatric patients. European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2020 Aug;21(4):387–406. doi: 10.1007/S40368-019-00478-w. PMID: 31602555. Exclusion reason: Ineligible intervention31602555
410 Tubert-Jeannin S, Auclair C, Amsallem E, Fluoride supplements (tablets, drops, lozenges or chewing gums) for preventing dental caries in children. Cochrane Database of Systematic Reviews. 2011 Dec 07;2011(12):CD007592. doi: 10.1002/14651858.CD007592.pub2. PMID: 22161414. Exclusion reason: Used as source document22161414
411 Turton B, Durward C, Crombie F, SEAL Cambodia-Evaluation of a modified protocol for placement of Fuji VII R Fissure Sealants at one and two years. J Dent. 2019 05;84:95–100. doi: 10.1016/j.jdent.2019.04.004. PMID: 30978439. Exclusion reason: Ineligible country30978439
412 Tut OK, Milgrom PM. Topical iodine and fluoride varnish combined is more effective than fluoride varnish alone for protecting erupting first permanent molars: a retrospective cohort study. J Public Health Dent. 2010;70(3):249–52. doi: 10.1111/j.1752-7325.2010.00163.x. PMID: 20337902. Exclusion reason: Ineligible study design20337902
413 Twetman S. Antimicrobials in future caries control? A review with special reference to chlorhexidine treatment. Caries Research. 2004 May-Jun;38(3):223–9. doi: 10.1159/000077758. PMID: 15153692. Exclusion reason: Ineligible intervention15153692
414 Twetman S. Caries risk assessment in children: how accurate are we? European Archives of Paediatric Dentistry: Official Journal of the European Academy of Paediatric Dentistry. 2016 Feb;17(1):27–32. doi: 10.1007/S40368-015-0195-7. PMID: 26189019. Exclusion reason: Ineligible study design26189019
415 Utreja D, Simratvir M, Kaur A, An evaluation of the Cariogram as a predictor model. Int Dent J. 2010 Aug;60(4):282–4. PMID: 20949759. Exclusion reason: Ineligible study design20949759
416 van Eck AA, Theuns HM, Groeneveld A. Effect of annual application of polyurethane lacquer containing silane-fluoride. Community Dentistry & Oral Epidemiology. 1984 Aug;12(4):230–2. doi: 10.1111/j.1600-0528.1984.tb01445.x. PMID: 6590174. Exclusion reason: Ineligible criteria for SRs6590174
417 van Rijkom HM, Truin GJ, van ť Hof MA. A meta-analysis of clinical studies on the caries-inhibiting effect of fluoride gel treatment. Caries Research. 1998;32(2):83–92. doi: 10.1159/000016436. PMID: 9544855. Exclusion reason: Used as source document9544855
418 van Wyk PJ, Kroon J, White JG. Evaluation of a fissure sealant program as part of community-based teaching and training. J Dent Educ. 2004;68(1):50–4. doi: 10.1002/j.0022-0337.2004.68.1.tb03734.x. PMID: 14761173. Exclusion reason: Ineligible study design14761173
419 Vanobbergen J, Declerck D, Mwalili S, The effectiveness of a 6-year oral health education programme for primary schoolchildren. Community Dent Oral Epidemiol. 2004;32(3):173–82. doi: 10.1111/j.1600-0528.2004.00151.x. PMID: 15151687. Exclusion reason: Ineligible setting15151687
420 Vanobbergen J, Martens L, Lesaffre E, The value of a baseline caries risk assessment model in the primary dentition for the prediction of caries incidence in the permanent dentition. Caries Research. 2001 Nov-Dec;35(6):442–50. doi: 10.1159/000047488. PMID: 11799285. Exclusion reason: Ineligible intervention11799285
421 Vasikaran V, Soni A, Watson M. Bringing together child health professionals and dental experts to tackle oral health in children. Br J Gen Pract. 2020 Jun;70(suppl 1)doi: 10.3399/bjgp20X711017. PMID: 32554633. Exclusion reason: Not a study32554633
422 Verma RK, Khare VV, Velaga DC, Effect of different fluoride varnishes in prevention of caries on mandibular permanent first molars in pediatric patient-an original research. Turkish journal of physiotherapy and rehabilitation. 2021;32(3):10470. Exclusion reason: Abstract only
423 Vermaire JH, Poorterman JH, van Herwijnen L, A three-year randomized controlled trial in 6-year-old children on caries-preventive strategies in a general dental practice in the Netherlands. Caries research. 2014;48(6):524–33. doi: 10.1159/000358342. PMID: 24924292. Exclusion reason: Ineligible comparator24924292
424 Walsh MM. Effects of school-based dental health education on knowledge, attitudes and behavior of adolescents in San Francisco. Community Dent Oral Epidemiol. 1985;13(3):143–7. doi: 10.1111/j.1600-0528.1985.tb00430.x. PMID: 3860334. Exclusion reason: Ineligible intervention3860334
425 Wang K, Yu KF, Liu P, Can mHealth promotion for parents help to improve their children's oral health? A systematic review. J Dent. 2022;123:104185. doi: 10.1016/j.jdent.2022.104185. Exclusion reason: Used as source document35691452
426 Wang Y, Li J, Sun W, Effect of non-fluoride agents on the prevention of dental caries in primary dentition: A systematic review. PLoS ONE. 2017;12(8):e0182221. doi: 10.1371/journal.pone.0182221. PMID: 28787448. Exclusion reason: Ineligible population28787448
427 Watt SB, Marshman Z. Can motivational interviewing help prevent dental caries in secondary school children? Evid Based Dent. 2022;23(2):56. doi: 10.1038/s41432-022-0261-z. Exclusion reason: Ineligible setting35750726
428 Watthanasaen S, Merchant AT, Luengpailin S, Xylitol-containing Chewing Gum for Caries Prevention in Students with Disabilities: a Randomised Trial. Oral health prev. 2017;15(6):519–27. doi: 10.3290/j.ohpd.a39668. PMID: 29319061. Exclusion reason: Ineligible intervention29319061
429 Weintraub JA. Pit and fissure sealants in high-caries-risk individuals. J Dent Educ. 2001 Oct;65(10):1084–90. doi: 10.1002/j.0022-0337.2001.65.10.tb03453.x. PMID: 11699981. Exclusion reason: Used as source document11699981
430 Weintraub JA, Ramos-Gomez F, Jue B, Fluoride varnish efficacy in preventing early childhood caries. Journal of dental research. 2006;85(2):172–6. doi: 10.1177/154405910608500211. PMID: CN-00562253. Exclusion reason: Ineligible population16434737
431 Werner H, Hakeberg M, Dahlström L, Psychological Interventions for Poor Oral Health: A Systematic Review. J Dent Res. 2016 May;95(5):506–14. doi: 10.1177/0022034516628506. PMID: 26826109. Exclusion reason: Used as source document26826109
432 Weyant RJ, Tracy SL, Anselmo TT, Topical fluoride for caries prevention: executive summary of the updated clinical recommendations and supporting systematic review. J Am Dent Assoc. 2013 Nov;144(11):1279–91. doi: 10.14219/jada.archive.2013.0057. PMID: 24177407. Exclusion reason: Used as source document24177407
433 Williams B, Price R, Winter GB. Fissure sealants. A 2-year clinical trial. Br Dent J. 1978 Dec 19;145(12):359–64. doi: 10.1038/sj.bdj.4804184. PMID: 363134. Exclusion reason: Ineligible comparator363134
434 Wong MC, Glenny AM, Tsang BW, Topical fluoride as a cause of dental fluorosis in children. Cochrane Database Syst Rev. 2010 Jan 20;2010(1):CD007693. doi: 10.1002/14651858.CD007693.pub2. PMID: 20091645. Exclusion reason: Ineligible population20091645
435 Wright JT, Crall JJ, Fontana M, Evidence-based clinical practice guideline for the use of pit-and-fissure sealants: A report of the American Dental Association and the American Academy of Pediatric Dentistry. J Am Dent Assoc. 2016 08;147(8):672–82.e12. doi: 10.1016/j.adaj.2016.06.001. PMID: 27470525. Exclusion reason: Used as source document27470525
436 Wright JT, Tampi MP, Graham L, Sealants for preventing and arresting pit-and-fissure occlusal caries in primary and permanent molars: A systematic review of randomized controlled trials-a report of the American Dental Association and the American Academy of Pediatric Dentistry. J Am Dent Assoc. 2016 08;147(8):631–45.e18. doi: 10.1016/j.adaj.2016.06.003. PMID: 27470524. Exclusion reason: Used as source document27470524
437 Wright JT, Tampi MP, Graham L, Sealants for Preventing and Arresting Pit-and-fissure Occlusal Caries in Primary and Permanent Molars. Pediatric dentistry. 2016;38(4):282–308. doi: 10.1016/j.adaj.2016.06.003. PMID: 27557916. Exclusion reason: Used as source document27557916
438 Wu L, Lo EC M, McGrath C, Motivational interviewing for caries prevention in adolescents: a randomized controlled trial. Clin Oral Investig. 2021 Jul 13;13:13. doi: 10.1007/S00784-021-04037-w. PMID: 34254214. Exclusion reason: Ineligible intervention34254214
439 Xhemnica L, Sulo D, Rroco R, Fluoride varnish application: a new prophylactic method in Albania. Effect on enamel carious lesions in permanent dentition. Eur J Paediatr Dent. 2008;9(2):93–6. PMID: 18605892. Exclusion reason: Ineligible criteria for SRs18605892
440 Xiang B, Wong HM, Perfecto AP, The application of theory-guided oral health interventions in adolescents: a systematic review and meta-analysis of randomized controlled trials. Psychol Health. 2020 Aug 05:1–16. doi: 10.1080/08870446.2020.1801679. PMID: 32755399. Exclusion reason: Ineligible intervention32755399
441 Xiang B, Wong HM, Perfecto AP, The effectiveness of behavioral interventions to improve oral health in adolescents at different periods of follow-up: A systematic review and metaanalysis. Patient Educ Couns. 2020 04;103(4):725–33. doi: 10.1016/j.pec.2019.11.030. PMID: 31813713. Exclusion reason: Ineligible intervention31813713
442 Yang G, Lin JH, Wang JH, [Evaluation of the clinical effect of fluoride varnish in preventing caries of primary teeth]. Hua Xi Kou Qiang Yi Xue Za Zhi. 2008 Apr;26(2):159–61. PMID: 18605454. Exclusion reason: Ineligible population18605454
443 Yu L, Yu X, Li Y, Is it necessary for children to receive professional fluoride in addition to regular fluoride toothpaste? Protocol for a systematic review. BMJ open. 2020 09 21;10(9):e037422. doi: 10.1136/bmjopen-2020-037422. PMID: 32958490. Exclusion reason: Ineligible study design32958490
444 Zhang LD, Zhou Y, Zhu YQ. [Evaluation of effects of fluoride varnish on prevention of first permanent molar caries]. Shanghai Kou Qiang Yi Xue/Shanghai Journal of Stomatology. 2017 Dec;26(6):641–5. doi: 10.19439/j.sjos.2017.06.015. PMID: 29691562. Exclusion reason: Not in English29691562
445 Zhang SY, Dong H, Yu M. [The effects of different interventions on 12-year-old children's permanent teeth caries and filling rate in Shanghai Jiading district]. Shanghai Kou Qiang Yi Xue/Shanghai Journal of Stomatology. 2015 Jun;24(3):341–4. PMID: 26166526. Exclusion reason: Not in English26166526
446 Zhou N, Wong HM, Wen YF, Efficacy of caries and gingivitis prevention strategies among children and adolescents with intellectual disabilities: a systematic review and meta-analysis. J Intellect Disabil Res. 2019 Jun;63(6):507–18. doi: 10.1111/jir.12576. PMID: 30575187. Exclusion reason: Ineligible intervention30575187
447 Zimmer S, Bizhang M, Seemann R, The effect of a preventive program, including the application of low-concentration fluoride varnish, on caries control in high-risk children. Clin Oral Investig. 2001;5(1):40–4. doi: 10.1007/s007840000091. PMID: CN-00347953. Exclusion reason: Ineligible population
448 Zimmer S, Robke FJ, Roulet JF. Caries prevention with fluoride varnish in a socially deprived community. Community Dent Oral Epidemiol. 1999;27(2):103–8. doi: 10.1111/j.1600-0528.1999.tb01998.x. PMID: 10226719. Exclusion reason: Ineligible criteria for SRs10226719

## Appendix A6 Criteria for Assessing Internal Validity of Individual Studies

Design | Criteria | Definition of good | Definition of fair | Definition of poor
Systematic reviews | - Comprehensiveness of sources considered/search strategy used; - Standard appraisal of included studies; - Validity of conclusions; - Recency and relevance (especially important for systematic reviews) | Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions | Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies | Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies
RCTS and cohort studies | - Initial assembly of comparable groups:; ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups; ○ For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts; - Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination); - Important differential loss to follow up or overall high loss to follow up; - Measurements: equal, reliable, and valid (includes masking of outcome assessment); - Clear definition of interventions; - All important outcomes considered; - Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (follow up ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs. | Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with follow up; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs. | Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.
Diagnostic Accuracy Studies | - Screening test relevant, available for primary care, and adequately described; - Credible reference standard, performed regardless of test results; - Reference standard interpreted independently of screening test; - Indeterminate results handled in a reasonable manner; - Spectrum of patients included in study; - Sample size; - Reliable screening test | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients | Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Source: U.S. Preventive Services Task Force. Procedure Manual. Accessed at https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-appendix-vi-criteria-assessing-internal-validity-individual-studies

## Appendix A7 Expert Reviewers of the Draft Report

Steven Levy, DDS, MPH, Professor, Department of Preventive and Community Dentistry, College of Dentistry, University of Iowa

Charlotte Lewis, MD, MPH, Associate Professor, Seattle Children's, University of Washington

Robert Weyant, MD, MDM, DrPH, Associate Dean, University of Pittsburgh School of Dental Medicine; Chair, Department of Dental Public Health

Christine Riedy, PhD, MPH, Chair and Associate Professor, Department of Oral Health Policy and Epidemiology, Harvard School of Dental Medicine

Richard Niederman, DMD, Professor, New York University College of Dentistry

Federal Partners

- The Centers for Disease Control and Prevention (1 reviewer)
- The National Institute of Child Health and Human Development (3 reviewers)
- The National Institute of Dental and Craniofacial Research (3 reviewers)