# References

1 Nelson HD, Fu R, Cantor A, Pappas M, Daeges M, Humphrey L. Effectiveness of Breast Cancer Screening: Systematic Review and Meta-analysis to Update the 2009 U.S. Preventive Services Task Force Recommendation. Ann Intern Med. 2016;164(4):244–255.26756588
2 U.S. Food and Drug Administration. MQSA National Statistics. Published Available at: https://www.fda.gov/radiation-emitting-products/mqsa-insights/mqsa-national-statistics. Accessed 2/23/2021.
3 Giampietro RR, Cabral MVG, Lima SAM, Weber SAT, Dos Santos Nunes-Nogueira V. Accuracy and Effectiveness of Mammography versus Mammography and Tomosynthesis for Population-Based Breast Cancer Screening: A Systematic Review and Meta-Analysis. Sci Rep. 2020;10(1):7991.32409756
4 Marinovich ML, Hunter KE, Macaskill P, Houssami N. Breast Cancer Screening Using Tomosynthesis or Mammography: A Meta-analysis of Cancer Detection and Recall. J Natl Cancer Inst. 2018;110(9):942–949.30107542
5 Houssami N, Zackrisson S, Blazek K, . Meta-analysis of prospective studies evaluating breast cancer detection and interval cancer rates for digital breast tomosynthesis versus mammography population screening. Eur J Cancer. 2021;148:14–23.33706172
6 Kerlikowske K, Su YR, Sprague BL, . Association of Screening With Digital Breast Tomosynthesis vs Digital Mammography With Risk of Interval Invasive and Advanced Breast Cancer. JAMA. 2022;327(22):2220–2230.35699706
7 Siu AL, Force USPST. Screening for Breast Cancer: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2016;164(4):279–296.26757170
8 Kerlikowske K, Zhu W, Tosteson AN, . Identifying women with dense breasts at high risk for interval cancer: a cohort study. Ann Intern Med. 2015;162(10):673–681.25984843
9 Food and Drug Administration. Mammography Quality Standards Act. Document 88 FR 15126, pages 15126–15171, 21 CFR 900, document number 2023-04550. Available at: https://www.federalregister.gov/documents/2023/03/10/2023-04550/mammography-quality-standards-act. Published 03/10/2023. Accessed 11/21/2023.
10 Doubeni CA, Simon M, Krist AH. Addressing Systemic Racism Through Clinical Preventive Service Recommendations From the US Preventive Services Task Force. JAMA. 2021;325(7):627–628.33492333
11 Lin JS, Hoffman L, Bean SI, . Addressing Racism in Preventive Services: Methods Report to Support the US Preventive Services Task Force. JAMA. 2021.
12 U.S. Preventive Services Task Force, Davidson KW, Mangione CM, . Actions to Transform US Preventive Services Task Force Methods to Mitigate Systemic Racism in Clinical Preventive Services. JAMA. 2021.
13 Giaquinto AN, Sung H, Miller KD, . Breast Cancer Statistics, 2022. CA Cancer J Clin. 2022.
14 Dietze EC, Sistrunk C, Miranda-Carboni G, O’Regan R, Seewaldt VL. Triple-negative breast cancer in African-American women: disparities versus biology. Nat Rev Cancer. 2015;15(4):248–254.25673085
15 Lawson MB, Bissell MCS, Miglioretti DL, . Multilevel Factors Associated With Time to Biopsy After Abnormal Screening Mammography Results by Race and Ethnicity. JAMA Oncol. 2022;8(8):1115–1126.35737381
16 Mandelblatt JS, Stout NK, Schechter CB, . Collaborative Modeling of the Benefits and Harms Associated With Different U.S. Breast Cancer Screening Strategies. Ann Intern Med. 2016;164(4):215–225.26756606
17 Lowry KP, Trentham-Dietz A, Schechter CB, . Long-Term Outcomes and Cost-Effectiveness of Breast Cancer Screening With Digital Breast Tomosynthesis in the United States. J Natl Cancer Inst. 2020;112(6):582–589.31503283
18 Trentham-Dietz A, Kerlikowske K, Stout NK, . Tailoring Breast Cancer Screening Intervals by Breast Density and Risk for Women Aged 50 Years or Older: Collaborative Modeling of Screening Outcomes. Ann Intern Med. 2016;165(10):700–712.27548583
19 van den Broek JJ, Schechter CB, van Ravesteyn NT, . Personalizing Breast Cancer Screening Based on Polygenic Risk and Family History. J Natl Cancer Inst. 2021;113(4):434–442.32853342
20 Caswell-Jin JL, Sun LP, Munoz D, . Contributions of screening, early-stage treatment, and metastatic treatment to breast cancer mortality reduction in the United States. (under review). 2023.
21 van Ravesteyn NT, Schechter CB, Near AM, . Race-specific impact of natural history, mammography screening, and adjuvant treatment on breast cancer mortality rates in the United States. Cancer Epidemiol Biomarkers Prev. 2011;20(1):112–122.21119071
22 Chapman CH, Schechter CB, Cadham CJ, . Identifying Equitable Screening Mammography Strategies for Black Women in the United States Using Simulation Modeling. Annals of Internal Medicine. 2021;174(12):1637–1646.34662151
23 Oeffinger KC, Fontham ET, Etzioni R, . Breast Cancer Screening for Women at Average Risk: 2015 Guideline Update From the American Cancer Society. JAMA. 2015;314(15):1599–1614.26501536
24 Caughey AB, Krist AH, Wolff TA, . USPSTF Approach to Addressing Sex and Gender When Making Recommendations for Clinical Preventive Services. JAMA. 2021;326(19):1953–1961.34694343
25 Alagoz O, Ergun MA, Cevik M, . The University of Wisconsin Breast Cancer Epidemiology Simulation Model: An Update. Med Decis Making. 2018;38(1_suppl):99s–111s.29554470
26 Huang X, Li Y, Song J, Berry DA. A Bayesian Simulation Model for Breast Cancer Screening, Incidence, Treatment, and Mortality. Med Decis Making. 2018;38(1_suppl):78s–88s.28627297
27 Lee SJ, Li X, Huang H, Zelen M. The Dana-Farber CISNET Model for Breast Cancer Screening Strategies: An Update. Med Decis Making. 2018;38(1_suppl):44s–53s.29554465
28 Munoz DF, Xu C, Plevritis SK. A Molecular Subtype-Specific Stochastic Simulation Model of US Breast Cancer Incidence, Survival, and Mortality Trends from 1975 to 2010. Med Decis Making. 2018;38(1_suppl):89s–98s.29554473
29 Schechter CB, Near AM, Jayasekera J, Chandler Y, Mandelblatt JS. Structure, Function, and Applications of the Georgetown-Einstein (GE) Breast Cancer Simulation Model. Med Decis Making. 2018;38(1_suppl):66s–77s.29554462
30 van den Broek JJ, van Ravesteyn NT, Heijnsdijk EA, de Koning HJ. Simulating the Impact of Risk-Based Screening and Treatment on Breast Cancer Outcomes with MISCAN-Fadia. Med Decis Making. 2018;38(1_suppl):54s–65s.29554469
31 Cancer Intervention and Surveillance Modeling Network, National Cancer Institute. Breast Cancer Modeling. Available at: https://cisnet.cancer.gov/breast/. Accessed August 26, 2021.
32 Mandelblatt JS, Cronin KA, Bailey S, . Effects of mammography screening under different screening schedules: model estimates of potential benefits and harms. Ann Intern Med. 2009;151(10):738–747.19920274
33 Gangnon RE, Sprague BL, Stout NK, . The contribution of mammography screening to breast cancer incidence trends in the United States: an updated age-period-cohort model. Cancer Epidemiol Biomarkers Prev. 2015;24(6):905–912.25787716
34 Caumo F, Zorzi M, Brunelli S, . Digital Breast Tomosynthesis with Synthesized Two-Dimensional Images versus Full-Field Digital Mammography for Population Screening: Outcomes from the Verona Screening Program. Radiology. 2018;287(1):37–46.29237146
35 Yoon JH, Kim EK, Kim GR, . Comparing recall rates following implementation of digital breast tomosynthesis to synthetic 2D images and digital mammography on women with breast-conserving surgery. Eur Radiol. 2020;30(11):6072–6079.32529566
36 Zuckerman SP, Conant EF, Keller BM, . Implementation of Synthesized Two-dimensional Mammography in a Population-based Digital Breast Tomosynthesis Screening Program. Radiology. 2016;281(3):730–736.27467468
37 Zuckerman SP, Sprague BL, Weaver DL, Herschorn SD, Conant EF. Multicenter Evaluation of Breast Cancer Screening with Digital Breast Tomosynthesis in Combination with Synthetic versus Digital Mammography. Radiology. 2020;297(3):545–553.33048032
38 Alabousi M, Wadera A, Kashif Al-Ghita M, . Performance of Digital Breast Tomosynthesis, Synthetic Mammography, and Digital Mammography in Breast Cancer Screening: A Systematic Review and Meta-Analysis. J Natl Cancer Inst. 2021;113(6):680–690.33372954
39 American College of Radiology. The American College of Radiology Breast Imaging Reporting and Data Systems (BI-RADS). 4th ed. Reston, VA: American College of Radiology; 2003.
40 Munoz DF, Plevritis SK. Estimating Breast Cancer Survival by Molecular Subtype in the Absence of Screening and Adjuvant Treatment. Med Decis Making. 2018;38(1_suppl):32s–43s.29554464
41 Plevritis SK, Munoz D, Kurian AW, . Association of Screening and Treatment With Breast Cancer Mortality by Molecular Subtype in US Women, 2000-2012. JAMA. 2018;319(2):154–164.29318276
42 Caswell-Jin JL, Plevritis SK, Tian L, . Change in Survival in Metastatic Breast Cancer with Treatment Advances: Meta-Analysis and Systematic Review. JNCI Cancer Spectr. 2018;2(4):pky062.30627694
43 Mandelblatt JS, Near AM, Miglioretti DL, . Common Model Inputs Used in CISNET Collaborative Breast Cancer Modeling. Med Decis Making. 2018;38(1_suppl):9S–23S.29554466
44 Early Breast Cancer Trialists’ Collaborative Group. Effects of chemotherapy and hormonal therapy for early breast cancer on recurrence and 15-year survival: an overview of the randomised trials. Lancet. 2005;365(9472):1687–1717.15894097
45 Early Breast Cancer Trialists’ Collaborative G, Peto R, Davies C, . Comparisons between different polychemotherapy regimens for early breast cancer: meta-analyses of long-term outcome among 100,000 women in 123 randomised trials. Lancet. 2012;379(9814):432–444.22152853
46 Gangnon RE, Stout NK, Alagoz O, Hampton JM, Sprague BL, Trentham-Dietz A. Contribution of Breast Cancer to Overall Mortality for US Women. Med Decis Making. 2018;38(1_suppl):24s–31s.29554467
47 Warner ET, Tamimi RM, Hughes ME, . Racial and Ethnic Differences in Breast Cancer Survival: Mediating Effect of Tumor Characteristics and Sociodemographic and Treatment Factors. J Clin Oncol. 2015;33(20):2254–2261.25964252
48 Hanmer J, Kaplan RM. Update to the Report of Nationally Representative Values for the Noninstitutionalized US Adult Population for Five Health-Related Quality-of-Life Scores. Value Health. 2016;19(8):1059–1062.27987633
49 Hanmer J, Lawrence WF, Anderson JP, Kaplan RM, Fryback DG. Report of Nationally Representative Values for the Noninstitutionalized US Adult Population for 7 Health-Related Quality-of-Life Scores. Medical Decision Making. 2006;26(4):391–400.16855127
50 de Haes JC, de Koning HJ, van Oortmarssen GJ, van Agt HM, de Bruyn AE, van Der Maas PJ. The impact of a breast cancer screening programme on quality-adjusted life-years. Int J Cancer. 1991;49(4):538–544.1917155
51 Stout NK, Rosenberg MA, Trentham-Dietz A, Smith MA, Robinson SM, Fryback DG. Retrospective cost-effectiveness analysis of screening mammography. J Natl Cancer Inst. 2006;98(11):774–782.16757702
52 Mark DH. Visualizing cost-effectiveness analysis. JAMA. 2002;287(18):2428–2429.11988064
53 Knudsen AB, Rutter CM, Peterse EFP, . Colorectal Cancer Screening: An Updated Modeling Study for the US Preventive Services Task Force. JAMA. 2021;325(19):1998–2011.34003219
54 Collaborative Group on Hormonal Factors in Breast Cancer. Familial breast cancer: collaborative reanalysis of individual data from 52 epidemiological studies including 58,209 women with breast cancer and 101,986 women without the disease. Lancet. 2001;358(9291):1389–1399.11705483
55 Nelson HD, Zakher B, Cantor A, . Risk factors for breast cancer for women aged 40 to 49 years: a systematic review and meta-analysis. Ann Intern Med. 2012;156(9):635–648.22547473
56 Shiyanbola OO, Arao RF, Miglioretti DL, . Emerging Trends in Family History of Breast Cancer and Associated Risk. Cancer Epidemiol Biomarkers Prev. 2017;26(12):1753–1760.28986348
57 Tice JA, Miglioretti DL, Li CS, Vachon CM, Gard CC, Kerlikowske K. Breast Density and Benign Breast Disease: Risk Assessment to Identify Women at High Risk of Breast Cancer. J Clin Oncol. 2015;33(28):3137–3143.26282663
58 Trentham-Dietz A, Sprague BL, Hampton JM, . Modification of breast cancer risk according to age and menopausal status: a combined analysis of five population-based case-control studies. Breast Cancer Res Treat. 2014;145(1):165–175.24647890
59 Mukama T, Kharazmi E, Sundquist K, Sundquist J, Brenner H, Fallah M. Familial risk of breast cancer by dynamic, accumulative, and static definitions of family history. Cancer. 2020;126(12):2837–2848.32154920
60 Palmer JR, Boggs DA, Adams-Campbell LL, Rosenberg L. Family history of cancer and risk of breast cancer in the Black Women’s Health Study. Cancer Causes Control. 2009;20(9):1733–1737.19760028
61 Palmer JR, Zirpoli G, Bertrand KA, . A Validated Risk Prediction Model for Breast Cancer in US Black Women. J Clin Oncol. 2021;39(34):3866–3877.34623926
62 Lansdorp-Vogelaar I, Gulati R, Mariotto AB, . Personalizing age of cancer screening cessation based on comorbid conditions: model estimates of harms and benefits. Ann Intern Med. 2014;161(2):104–112.25023249
63 Cho H, Klabunde CN, Yabroff KR, . Comorbidity-adjusted life expectancy: a new tool to inform recommendations for optimal screening strategies. Ann Intern Med. 2013;159(10):667–676.24247672
64 DenseBreast-info. State Legislation Map. Availble at: https://densebreast-info.org/legislative-information/state-legislation-map/. Published Accessed 7/15/2022. Accessed.
65 Munsell MF, Sprague BL, Berry DA, Chisholm G, Trentham-Dietz A. Body mass index and breast cancer risk according to postmenopausal estrogen-progestin use and hormone receptor status. Epidemiol Rev. 2014;36:114–136.24375928
66 Engmann NJ, Golmakani MK, Miglioretti DL, Sprague BL, Kerlikowske K, Breast Cancer Surveillance C. Population-Attributable Risk Proportion of Clinical Risk Factors for Breast Cancer. JAMA Oncol. 2017;3(9):1228–1236.28152151
67 Carlos RC, Obeng-Gyasi S, Cole SW, . Linking Structural Racism and Discrimination and Breast Cancer Outcomes: A Social Genomics Approach. J Clin Oncol. 2022;40(13):1407–1413.35108027
68 Gee GC, Walsemann KM, Brondolo E. A life course perspective on how racism may be related to health inequities. Am J Public Health. 2012;102(5):967–974.22420802
69 Jones NL, Gilman SE, Cheng TL, Drury SS, Hill CV, Geronimus AT. Life Course Approaches to the Causes of Health Disparities. Am J Public Health. 2019;109(S1):S48–S55.30699022
70 Paraskevi T. Quality of life outcomes in patients with breast cancer. Oncol Rev. 2012;6(1):e2.25992204
71 Fryback DG, Dunham NC, Palta M, . US norms for six generic health-related quality-of-life indexes from the National Health Measurement study. Med Care. 2007;45(12):1162–1170.18007166
72 Holford TR, Cronin KA, Mariotto AB, Feuer EJ. Chapter 4: Changing Patterns in Breast Cancer Incidence Trends. JNCI Monographs. 2006;2006(36):19–25.
73 Early Breast Cancer Trialists’ Collaborative G, Darby S, McGale P, . Effect of radiotherapy after breast-conserving surgery on 10-year recurrence and 15-year breast cancer death: meta-analysis of individual patient data for 10,801 women in 17 randomised trials. Lancet. 2011;378(9804):1707–1716.22019144
74 Early Breast Cancer Trialists’ Collaborative G, Davies C, Godwin J, . Relevance of breast cancer hormone receptors and other factors to the efficacy of adjuvant tamoxifen: patient-level meta-analysis of randomised trials. Lancet. 2011;378(9793):771–784.21802721
75 Early Breast Cancer Trialists’ Collaborative Group. Aromatase inhibitors versus tamoxifen in early breast cancer: patient-level meta-analysis of the randomised trials. Lancet. 2015;386(10001):1341–1352.26211827
76 Early Breast Cancer Trialists’ Collaborative Group. Long-term outcomes for neoadjuvant versus adjuvant chemotherapy in early breast cancer: meta-analysis of individual patient data from ten randomised trials. Lancet Oncol. 2018;19(1):27–39.29242041
77 Cho H, Mariotto AB, Mann BS, Klabunde CN, Feuer EJ. Assessing non-cancer-related health status of US cancer patients: other-cause survival and comorbidity prevalence. Am J Epidemiol. 2013;178(3):339–349.23825168
78 Mandelblatt J, Cronin K, de Koning H, Miglioretti DL, Schechter C, Stout N. Collaborative Modeling of U.S. Breast Cancer Screening Strategies. Publication No. 14-05201-EF-4. Washington, DC: AHRQ;2015.
79 Trentham-Dietz A, Chapman CH, Bird J, Gangnon RE. Recent Changes in the Patterns of Breast Cancer as a Proportion of All Deaths According to Race and Ethnicity. Epidemiology. 2021;32(6):904–913.34172689