# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tracy Wolff, MD, MPH, AHRQ Scientific Director for the U.S. Preventive Services Task Force Program; Howard Tracer, MD, AHRQ Medical Officer; Jillian Henderson, Elizabeth Webber, Heidi Nelson, and other members of the Kaiser Permanente EPC; members of the U.S. Preventive Services Task Force who contributed to the decision analysis workplan; Doug Owens, MD, MS (Stanford University), Ya-Chen Tina Shih, PhD (MD Anderson Cancer Center), Jennifer Croswell, MD, MPH (Healthcare Delivery Research Program, National Cancer Institute), Sarah M. Temkin, MD (Office of Research on Women’s Health, National Institutes of Health), and an anonymous federal expert for their content expertise and review of the draft report; Julie McGregor, Jennie Martin, and Victoria Foster for project coordination; Linn Abraham and Thomas Lawler for assistance with data; and Amy Knudsen, Claudia Seguin, Barak Davidi, and Hannah Johnson for assistance with graphing.