# Chapter 4 Discussion

This updated decision analysis for the USPSTF builds upon the prior work conducted in 2009 and 2016 to reflect the most currently available evidence. Important differences from past iterations include consideration of DBT and continuing screening until age 79 versus age 74. Past efforts assumed that all breast cancer cases received the most effective treatment for their age and the stage and subtype of their tumors; here we employed a dissemination model input to reflect the variation in treatment received by patients in the United States. Results remained consistent with previous decision analyses, showing that the underlying model structure—that has remained consistent throughout the history of the CISNET program—affects modeling findings more than incremental changes in model parameters.

In general, the models consistently found the same or slightly increased health benefits and fewer false-positive recalls for DBT as compared with DM. As with previous decision analyses, screening biennially at ages 50–74 was efficient and resulted in about 7 breast cancer deaths averted over the lifetimes of 1,000 female persons screened compared to no screening. One additional death was averted if the starting age was 40, but screening biennially at ages 40–74 was inferior to strategies that screened until age 79 in terms of numbers of mammograms to achieve a reduction in breast cancer mortality or a gain in life-years.

Similar strategies were found to be efficient for female persons overall and those with increased breast cancer risk due to dense breasts or elevated relative risk. However, as breast cancer risk increased, gains with more intensive screening strategies resulted in greater numbers of breast cancer deaths averted and life-years gained. Due to concerns that dense breast tissue can mask detection of breast cancer by a mammogram, the majority of states require that mammography facilities include a note in their letters to patients about breast density that may include information about the presence of dense tissue on the person’s mammogram.^64^ Given the increased societal awareness of the potential for dense breast tissue to impact breast cancer detection, patients and healthcare professionals are increasingly asking whether more intensive screening is warranted for female persons with dense breasts. Evaluation of supplemental screening for patients with a negative mammogram was beyond the scope of this decision analysis.

Approximately 11% to 16% of female persons have a first-degree family history of breast cancer, defined as having their mother and/or at least one sister and/or daughter diagnosed with breast cancer.^56^ Risk of breast cancer has been established to be elevated among female persons with a first-degree family history of breast cancer, if the family member was diagnosed at younger ages, and if multiple family members have been diagnosed.^54,56^ Studies of risk associated with a positive family history of breast cancer among Black female persons have found estimates in the 1.5 to 2.0 range, similar to studies of female persons of all races combined or primarily White female persons.^60,61^ To examine the balance of benefits and harms of different screening strategies according to different levels of family history of breast cancer, screening strategies were evaluated in the models after applying a relative risk value to the underlying risk of breast cancer for each modeled person’s lifetime. The two relative risk values—1.5 and 2.0—represent a range of elevations in risk among female persons with a first-degree family history of breast cancer. This range of elevated risk also captures risk associated with other risk factors, including obesity, later age at first full-term pregnancy, history of benign breast disease, and frequent alcohol consumption.^18,58,65,66^ Models did not incorporate any assumptions about differences in tumor natural history, subtype, or treatment efficacy for female persons with elevated risk.

This report extends findings published in 2021 for one model (GE) that evaluated strategies for reducing breast cancer mortality disparities between Black and White female persons.^22^ Our models are intended to generate findings for individuals who self-identify as Black, defining race as a social construct where the social/political environment influences biological processes over the lifecourse.^67–69^ Models required a decrement applied to treatment benefits for Black patients to calibrate mortality; this decrement was necessary in addition to racial differences in screening-related model input parameters to reflect the greater mortality in Black as compared with White breast cancer patients.^13^ Findings in this report show that, due in part to a higher breast cancer mortality, especially among younger female persons, Black female persons experienced greater LYG per mammogram than those overall when everyone followed the same screening strategy. However, the breast cancer mortality disparity persisted when the same screening strategy was applied to Black female persons and the overall population. More intensive screening—without any changes to the decrement in treatment benefit experienced by Black patients—could potentially reduce the Black/White disparity in breast cancer mortality. As described by Chapman et al^22^, intensive screening as a strategy for reducing breast cancer disparities should be viewed as a short-term solution within the control of individual patients until healthcare systems, policy makers, and clinicians remedy treatment disparities. Models were not available to examine screening among race or ethnicity groups other than Black female persons and the overall female population.

Models differ in meaningful ways in structure and assumptions; for example, some models incorporated a benefit to screening due to within-stage shift (Model E, S, and W), while others required a stage shift (Model D and GE) and assigned greater benefit for screen-detected than clinically-detected cases (Model M). Some of the modeling teams modeled tumor growth starting with lesions classified as DCIS (Model E and W), while other models did not explicitly model tumor growth, instead modeling categorical stages of disease (Model D and GE), used a fully Bayesian approach (Model M), or limited tumors to invasive breast cancer (Model S). Some models included tumors with limited malignant potential (Model E, GE, and W), and one model included a small percentage of early-invasive staged cases that grow so slowly that these tumors never lead to death from breast cancer (Model W). These different modeling assumptions allow the CISNET breast cancer modelers to provide policy makers and clinicians with a range of plausible results expected from adopting various screening strategies for different population risk groups about the benefits and harms of detecting and treating tumors with a range of growth features. Overall, using six models to project a range of plausible screening outcomes provides implicit cross-validation, with the range of results from the models as a measure of uncertainty.

Among the five models that included DCIS as well invasive breast cancer, three models found that the overall number of overdiagnosed cases exceeded the number of breast cancer deaths averted (Models E, M, and W). The upper range for all estimates of overdiagnosis was based on results from Model M (MD Anderson Cancer Center) and Model W (Wisconsin-Harvard). Model M generated higher overdiagnosis based on the assumption that incidence in the absence of screening has essentially remained flat since 1975–1979, with almost all of the increases over time attributable to screening. The other models, including Model W, used some form of an age–period–cohort model for incidence in the absence of screening, where some of the increases in incidence were due to screening and some to changes in risk factors (e.g., use of postmenopausal hormone therapy). While this model structure generated lower rates of overdiagnosis for Models D and GE, Model W had higher rates of overdiagnosis to facilitate calibration to U.S. breast cancer rates during the 1980s, when screening mammography disseminated through the general population and incidence rates dramatically increased. Other sources of variation across models were related to assumptions about the proportions of DCIS cases that never progress to invasive cancer or the number of early invasive cancers that might be nonprogressive. In general, models that assumed higher proportions of nonprogressive DCIS or invasive breast cancer generated higher estimates of overdiagnosis than models that assumed less nonprogressive disease. The underlying incidence in the absence of screening and the proportion and types of tumors that were nonprogressive are unknown and unobservable; therefore, the different results across models based on their respective assumptions provided a range of possible overdiagnosis.

Two sensitivity analyses were conducted to examine the impact of input parameters related to treatment assignment and age-related quality of life disutilities. While other model inputs related to screening performance, for example, relied on rigorous data collected from diverse populations, the inputs for treatment assignment and age-related disutilities relied on data that have greater limitations. Studies report wide variation in quality-of-life experiences related to the impacts of aging and, for patients, breast cancer screening, diagnostic work-up, and treatment.^70,71^ This variation was not captured in our base analysis. Although the sensitivity analysis using the SF-6D instead of the EQ-5D for age-related disutilities resulted in lower QALY values, the same screening strategies were efficient. Furthermore, the sensitivity analysis assigning the single most effective breast cancer therapy to all breast cancer patients showed slightly greater percent breast cancer mortality reduction compared with the base analysis that reflected variation in treatment assignment across patients with the same diagnosis. In the scenario where all patients receive the most effective therapy, breast cancer mortality is reduced among those detected through screening as well as those diagnosed clinically. Consequently, little change is observed for breast cancer deaths averted, LYG, and QALYs gained compared to the base analysis. Since our prior modeling work for the USPSTF in 2009^32^ and 2016^16^ assumed the single most effective therapy assigned to all breast cancer patients, this sensitivity analysis increased confidence that different findings are likely due to changes in other factors such as improved screening performance rather than differences in breast cancer treatment assignment.

Some analyses are based on findings from fewer than six models, which complicated efforts to compare results across topics. Reasons for the inconsistency in the number of models were pragmatic in nature. For example, some models were well-poised to examine certain questions related to racial disparities,^22^ breast density,^18^ and comorbidities^62^ due to programming completed in previous projects; not all models had capacity to complete analyses for all topics.

## Conclusion

This collaborative modeling analysis suggests that several mammography screening strategies reduce breast cancer mortality and increase life expectancy in average-risk female persons. Strategies with biennial screening, start ages at 40 or 45, and cessation age at 79 resulted in greater incremental gains in survival and mortality reduction per mammogram compared with most strategies involving annual screening, start age at 50, and cessation age at 74. More intensive screening for women with greater risk of diagnosis or death can maintain similar benefit-to-harm trade-offs and reduce mortality disparities.