# Chapter 3 Results

## Probability of a Breast Cancer Diagnosis or Death

For the 1980 birth cohort of all female persons without mammography screening, the models predicted a median 12.7% lifetime probability of a breast cancer diagnosis (range across models, 11.8% to 14.9%). (All analyses assume persons diagnosed with breast cancer received treatment.) Without screening, the median probability of a breast cancer death was 2.73% (range across six models, 2.34% to 3.74%; among models D, GE, M, and W, median 2.83% with the same range). Thus, if a screening strategy leads to a 25.8% reduction in breast cancer mortality (the value for screening biennially during ages 50–74 from the 2016 decision analysis for the USPSTF^16^), the probability of a breast cancer death would be reduced from 2.73% to 2.03%, or 7.1 breast cancer deaths averted per 1,000 female persons screened.

For Black female persons, the models predicted a 11.8% median lifetime probability of a breast cancer diagnosis (range, 11.0% to 14.6%) and a 3.93% median probability of a breast cancer death (range, 3.20% to 4.82%) without screening. Models predicted a median 39% higher breast cancer mortality rate for Black female persons compared to female persons overall in the absence of screening (based on four models). If a screening strategy reduced breast cancer mortality by 25.8%, the models predicted that the probability of a breast cancer death would be reduced from 3.93% to 2.91%, and 10.1 breast cancer deaths would be averted among 1,000 Black female persons.

## Question 1 Trade-Offs for Average-Risk Female Persons

Benefits of screening strategies including reductions in breast cancer mortality and gains in life-years, deaths averted, and QALYs increased with increasing numbers of DM (Table 4, Appendix Table 6) and DBT (Table 5, Appendix Table 7) examinations. Reductions in breast cancer mortality increased from a median across models of 24.3% for screening biennially at ages 50–74 with DM (range across models, 18.3% to 27.5%) to a median 41.7% reduction for screening annually at ages 40–79 with DM (range, 37.2% to 42.9%) or DBT (range, 39.2% to 43.0%).

Table 4 Median Lifetime Benefits (and Range Across Five Models) of Screening Strategies With Digital Mammography for a Cohort of 1,000 40-Year-Old Female Persons Compared With No Screening According to Screening Interval, Starting Age, and Stopping Age

Interval and Age Group^a^ | Breast Cancer Mortality Reduction, % | Breast Cancer Deaths Averted | Life-Years Gained | QALYs Gained^b^
Biennial
50-74 | 24.3 (18.3-27.5) | 6.9 (4.8-8.6) | 114.6 (109.8-165.0) | 80.7 (72.3-132.4)
45-74 | 26.4 (20.4-29.3) | 7.8 (5.1-9.2) | 140.0 (125.0-187.7) | 97.5 (82.2-149.5)
40-74 | 28.4 (22.3-31.7) | 8.4 (5.6-10.1) | 170.1 (141.2-214.1) | 118.8 (91.8-163.8)
Hybrid
A45-49, B50-74 | 29.3 (22.4-30.5) | 8.6 (5.7-9.6) | 151.3 (140.8-194.5) | 104.7 (92.4-153.1)
A45-54, B55-74 | 29.3 (23.0-30.2) | 8.8 (5.8-9.4) | 159.3 (148.6-195.5) | 109.8 (98.3-152.8)
A40-49, B50-74 | 31.7 (24.4-33.1) | 9.3 (6.2-10.7) | 178.9 (161.9-234.6) | 122.2 (104.4-167.2)
Annual
50-74 | 29.4 (24.7-31.7) | 9.2 (6.8-9.5) | 153.2 (134.0-181.4) | 104.2 (89.0-140.3)
45-74 | 33.4 (29.8-35.4) | 10.4 (7.5-11.8) | 187.3 (163.6-230.1) | 125.0 (108.5-162.2)
40-74 | 35.2 (31.8-37.6) | 11.0 (8.0-13.1) | 208.7 (200.7-275.5) | 138.0 (133.6-194.0)
Biennial
50-79 | 26.9 (22.2-30.2) | 7.9 (5.6-9.4) | 122.7 (118.5-172.8) | 84.7 (77.5-138.9)
45-79 | 31.7 (24.8-33.3) | 8.9 (6.3-11.9) | 145.6 (137.8-202.5) | 100.6 (90.0-159.2)
40-79 | 32.9 (25.3-34.9) | 9.1 (6.4-12.3) | 176.8 (149.8-233.9) | 123.2 (97.0-170.3)
Hybrid
A45-49, B50-79 | 31.8 (25.4-33.1) | 9.4 (6.4-11.7) | 156.7 (149.5-209.4) | 107.9 (97.7-159.5)
A45-54, B55-79 | 33.9 (27.5-34.2) | 10.0 (6.9-12.4) | 168.8 (158.7-217.2) | 115.9 (106.1-162.5)
A40-49, B50-79 | 34.9 (27.4-36.2) | 10.1 (6.9-13.1) | 187.9 (170.5-257.0) | 128.3 (109.6-183.4)
Annual
50-79 | 33.7 (32.1-35.8) | 10.5 (7.9-12.2) | 172.7 (145.8-192.7) | 112.4 (96.1-148.7)
45-79 | 38.1 (35.1-39.5) | 11.6 (8.9-14.8) | 202.9 (172.0-256.1) | 132.0 (113.1-180.0)
40-79 | 41.7 (37.2-42.9) | 12.2 (9.4-16.1) | 224.3 (211.4-300.6) | 144.2 (140.0-211.2)

Abbreviations: A, annual; B, biennial.

a All strategies show results for Models D, E, GE, M, and W.

b Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

Table 5 Median Lifetime Benefits (and Range Across Six Models) of Screening Strategies With Digital Breast Tomosynthesis for a Cohort of 1,000 40-Year-Old Female Persons Compared With No Screening According to Screening Interval, Starting Age, and Stopping Age

Interval and Age Group^a^ | Breast Cancer Mortality Reduction, % | Breast Cancer Deaths Averted | Life-Years Gained | QALYs Gained^b^
Biennial
50-74 | 25.4 (18.8-29.4) | 6.7 (5.1-9.2) | 120.8 (115.1-175.8) | 86.1 (77.9-143.0)
45-74 | 27.5 (21.7-31.2) | 7.5 (5.5-9.8) | 141.3 (133.9-200.1) | 100.4 (89.9-161.3)
40-74 | 30.0 (24.0-33.7) | 8.2 (6.1-10.6) | 165.2 (152.4-221.9) | 116.8 (101.4-177.0)
Hybrid
A45-49, B50-74 | 29.5 (23.9-32.5) | 8.0 (6.0-10.2) | 153.5 (146.3-207.2) | 107.8 (101.3-165.5)
A45-54, B55-74 | 29.9 (24.4-32.1) | 8.2 (6.2-10.0) | 161.1 (148.2-207.9) | 110.7 (105.2-165.1)
A40-49, B50-74 | 32.2 (26.1-34.4) | 8.8 (6.6-11.0) | 181.2 (163.9-240.1) | 125.7 (115.5-179.2)
Annual
50-74 | 30.6 (24.7-32.8) | 8.6 (7.0-10.1) | 155.6 (137.1-191.7) | 109.0 (93.7-151.4)
45-74 | 34.1 (31.4-36.5) | 9.7 (7.9-11.8) | 193.3 (165.7-230.1) | 132.0 (112.8-173.8)
40-74 | 37.0 (33.6-38.9) | 10.3 (8.5-13.1) | 216.6 (190.1-274.9) | 146.1 (132.3-196.5)
Biennial
50-79 | 28.0 (23.6-32.2) | 7.6 (6.0-10.1) | 129.3 (119.6-184.1) | 91.7 (83.7-150.1)
45-79 | 32.1 (26.5-35.5) | 8.6 (6.7-12.1) | 153.4 (147.7-213.1) | 110.2 (98.5-172.1)
40-79 | 33.3 (27.2-36.5) | 8.9 (6.9-12.5) | 173.9 (161.7-237.8) | 124.2 (107.2-184.2)
Hybrid
A45-49, B50-79 | 32.5 (27.2-35.3) | 8.9 (6.9-11.9) | 160.5 (152.8-215.4) | 111.5 (107.1-172.5)
A45-54, B55-79 | 34.1 (29.2-36.4) | 9.2 (7.4-12.6) | 172.7 (161.0-220.8) | 118.4 (111.6-175.9)
A40-49, B50-79 | 35.3 (29.4-37.2) | 9.5 (7.4-13.3) | 188.7 (173.4-260.1) | 130.7 (121.4-188.1)
Annual
50-79 | 34.5 (32.6-36.9) | 9.8 (8.0-12.2) | 173.2 (148.2-203.6) | 118.4 (102.5-160.8)
45-79 | 39.1 (37.1-40.8) | 10.9 (9.0-14.8) | 207.1 (176.1-255.8) | 140.8 (119.5-183.2)
40-79 | 41.7 (39.2-43.0) | 11.5 (9.9-16.1) | 229.7 (200.4-300.7) | 154.3 (139.5-214.6)

Abbreviations: A, annual; B, biennial.

a All strategies show results for Models D, E, GE, M, S, and W.

b Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

When comparing the least-intensive strategy (biennial 50–74) to the most intensive strategy (annual 40–79), the median number of mammograms tripled for both DM (Table 6) and DBT (Table 7). False-positive recalls increased from 873 (range, 855 to 878) with DBT biennially at ages 50–74 to 2,595 (range, 2,550 to 2,621) with DM annually at ages 40–79. The number of overdiagnosed cases increased from a median of 10 (range, 4 to 29; out of 143 invasive breast cancer cases, data not shown) for biennial 50–74 with DM to 25 (range, 7 to 56; out of 156 invasive breast cancer cases, data not shown) for annual 40–79 with DBT, with a wide range across models and strategies.

Table 6 Median Lifetime Harms (and Range Across Five Models) of Screening Strategies With Digital Mammography for a Cohort of 1,000 40-Year-Old Female Persons Compared With No Screening According to Screening Interval, Starting Age, and Stopping Age

Interval and Age Group^a^ | Mammograms | False-Positive Recalls | Benign Biopsies | Overdiagnosed Cases^b^
Biennial
50-74 | 11,192 (10,999-11,278) | 1,021 (1,003-1,027) | 148 (146-149) | 10 (4-29)
45-74 | 13,283 (13,078-13,380) | 1,230 (1,212-1,238) | 173 (170-174) | 11 (4-30)
40-74 | 16,092 (15,863-16,215) | 1,540 (1,520-1,551) | 210 (207-212) | 12 (4-33)
Hybrid
A45-49, B50-74 | 15,992 (15,807-16,164) | 1,416 (1,400-1,430) | 189 (187-191) | 19 (4-33)
A45-54, B55-74 | 18,006 (17,804-18,197) | 1,514 (1,497-1,530) | 195 (193-197) | 19 (4-33)
A40-49, B50-74 | 20,898 (20,705-21,133) | 1,896 (1,879-1,916) | 236 (234-239) | 21 (4-35)
Annual
50-74 | 21,439 (21,010-21,650) | 1,543 (1,513-1,557) | 192 (188-194) | 16 (5-39)
45-74 | 26,272 (25,776-26,526) | 1,943 (1,907-1,960) | 233 (229-235) | 18 (5-43)
40-74 | 31,178 (30,649-31,493) | 2,423 (2,385-2,446) | 281 (276-283) | 19 (5-45)
Biennial
50-79 | 12,456 (12,223-12,560) | 1,105 (1,084-1,113) | 160 (157-161) | 12 (6-34)
45-79 | 15,176 (14,907-15,297) | 1,356 (1,333-1,366) | 191 (187-192) | 14 (6-37)
40-79 | 17,354 (17,081-17,494) | 1,624 (1,601-1,636) | 222 (219-223) | 14 (6-37)
Hybrid
A45-49, B50-79 | 17,242 (17,026-17,443) | 1,499 (1,481-1,516) | 200 (198-203) | 22 (6-37)
A45-54, B55-79 | 19,876 (19,627-20,112) | 1,639 (1,618-1,658) | 213 (210-215) | 24 (6-40)
A40-49, B50-79 | 22,150 (21,921-22,412) | 1,979 (1,960-2,002) | 248 (245-251) | 24 (6-40)
Annual
50-79 | 24,563 (24,014-24,831) | 1,716 (1,678-1,733) | 212 (208-214) | 19 (7-46)
45-79 | 29,389 (28,767-29,702) | 2,115 (2,072-2,136) | 253 (248-256) | 21 (7-50)
40-79 | 34,289 (33,633-34,667) | 2,595 (2,550-2,621) | 301 (295-304) | 23 (7-52)

Abbreviations: A, annual; B, biennial.

a All strategies show results for Models D, E, GE, M, and W.

b Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario.

Table 7 Median Lifetime Harms (and Range Across Six Models) of Screening Strategies With Digital Breast Tomosynthesis for a Cohort of 1,000 40-Year-Old Female Persons Compared With No Screening According to Screening Interval, Starting Age, and Stopping Age

Interval and Age Group^a^ | Mammograms | False-Positive Recalls | Benign Biopsies | Overdiagnosed Cases^b^
Biennial
50-74 | 11,208 (10,976-11,278) | 873 (855-878) | 136 (133-137) | 12 (4-33)
45-74 | 13,299 (13,051-13,380) | 1,080 (1,061-1,086) | 164 (161-165) | 13 (4-34)
40-74 | 16,116 (15,826-16,214) | 1,376 (1,354-1,384) | 201 (198-203) | 14 (4-37)
Hybrid
A45-49, B50-74 | 16,053 (15,775-16,164) | 1,242 (1,221-1,250) | 184 (180-185) | 19 (4-37)
A45-54, B55-74 | 18,072 (17,772-18,197) | 1,317 (1,296-1,326) | 193 (189-194) | 20 (4-37)
A40-49, B50-74 | 20,979 (20,662-21,133) | 1,691 (1,667-1,703) | 238 (233-240) | 21 (4-39)
Annual
50-74 | 21,500 (20,963-21,650) | 1,277 (1,246-1,285) | 186 (182-187) | 18 (5-42)
45-74 | 26,349 (25,716-26,526) | 1,647 (1,610-1,657) | 234 (229-235) | 20 (5-46)
40-74 | 31,273 (30,572-31,492) | 2,096 (2,055-2,110) | 288 (283-290) | 21 (5-48)
Biennial
50-79 | 12,488 (12,193-12,560) | 937 (916-943) | 144 (141-145) | 14 (6-38)
45-79 | 15,218 (14,871-15,297) | 1,176 (1,153-1,183) | 176 (173-177) | 16 (6-41)
40-79 | 17,397 (17,037-17,494) | 1,440 (1,415-1,449) | 210 (206-211) | 17 (6-42)
Hybrid
A45-49, B50-79 | 17,325 (16,987-17,443) | 1,306 (1,282-1,315) | 192 (188-193) | 22 (6-42)
A45-54, B55-79 | 19,980 (19,585-20,112) | 1,413 (1,387-1,423) | 205 (202-207) | 24 (6-44)
A40-49, B50-79 | 22,255 (21,870-22,412) | 1,755 (1,728-1,768) | 247 (242-248) | 24 (6-44)
Annual
50-79 | 24,687 (23,953-24,831) | 1,405 (1,367-1,417) | 202 (197-204) | 22 (7-50)
45-79 | 29,517 (28,692-29,701) | 1,774 (1,730-1,789) | 250 (244-252) | 24 (7-54)
40-79 | 34,441 (33,538-34,666) | 2,224 (2,175-2,240) | 304 (298-307) | 25 (7-56)

Abbreviations: A, annual; B, biennial.

a All strategies show results for Models D, E, GE, M, S, and W.

b Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario. Model S (Stanford University) is excluded because it does not include DCIS.

Use of DBT instead of DM reduced breast cancer mortality reduction by about 1 percentage point and averted less than 1 additional breast cancer death (Table 8), while also reducing false-positive recall by approximately 150 to 300 per 1,000 persons over their lifetimes, depending on strategy (all with stopping age 74).

Table 8 Incremental Benefits and Harms Across Five Models for a Cohort of 1,000 40-Year-Old Female Persons Screened With Digital Breast Tomosynthesis (Median and Range) Compared With Digital Mammography (Median Only) vs. No Screening According to Interval and Start Age With Stop Age 74 Years

Strategy and Age Group^a^ | Breast Cancer Mortality Reduction, % | | Breast Cancer Deaths Averted | | Life-Years Gained | | QALYs Gained^b^
Strategy and Age Group^a^ | DM vs. No Screening | DBT vs. DM | DM vs. No Screening | DBT vs. DM | DM vs. No Screening | DBT vs. DM | DM vs. No Screening | DBT vs. DM
Biennial
50-74 | 24.3 | +1.0 (0.5-1.8) | 6.9 | +0.3 (0.2-0.6) | 114.6 | +5.5 (3.7-10.8) | 80.7 | +5.6 (4.3-10.5)
45-74 | 26.4 | +1.1 (0.5-1.9) | 7.8 | +0.3 (0.2-0.6) | 140.0 | +5.0 (2.7-12.4) | 97.5 | +4.9 (3.6-11.9)
40-74 | 28.4 | +1.1 (0.5-2.1) | 8.4 | +0.3 (0.2-0.7) | 170.1 | +5.8 (3.9-13.8) | 118.8 | +5.6 (4.7-13.2)
Hybrid
A45-49, B50-74 | 29.3 | +0.8 (0.4-2.0) | 8.6 | +0.2 (0.1-0.6) | 151.3 | +4.9 (3.0-12.6) | 104.7 | +5.4 (4.0-12.3)
A45-54, B55-74 | 29.3 | +0.8 (0.4-1.9) | 8.8 | +0.2 (0.1-0.6) | 159.3 | +3.9 (2.6-12.4) | 109.8 | +4.8 (3.9-12.3)
A40-49, B50-74 | 31.7 | +0.8 (0.7-2.1) | 9.3 | +0.2 (0.2-0.7) | 178.9 | +5.6 (4.0-13.9) | 122.2 | +6.4 (4.9-13.7)
Annual
50-74 | 29.4 | +1.1 (0-1.7) | 9.2 | +0.3 (0-0.5) | 153.2 | +5.1 (0.4-10.3) | 104.2 | +5.9 (2.7-11.1)
45-74 | 33.4 | +1.2 (0-1.9) | 10.4 | +0.3 (0-0.6) | 187.3 | +5.6 (−0.1-12.2) | 125.0 | +6.5 (2.6-12.9)
40-74 | 35.2 | +1.3 (−0.1-2) | 11.0 | +0.4 (0-0.6) | 208.7 | +6.5 (−1.4-13.5) | 138.0 | +7.5 (2.1-14.3)
Biennial | Mammograms | | False-Positive Recalls | | Benign Biopsies | | Overdiagnosed Cases, n^c^
Biennial | DM vs. No Screening | DBT vs. DM | DM vs. No Screening | DBT vs. DM | DM vs. No Screening | DBT vs. DM | DM vs. No Screening | DBT vs. DM
50-74 | 11,192 | 0 (−24-0) | 1,021 | −149 (−150, −148) | 148 | −12 (−12, −12) | 10 | 0 (0-3)
45-74 | 13,283 | 0 (−27-0) | 1,230 | −152 (−154, −150) | 173 | −9 (−10, −9) | 11 | 0 (0-3)
40-74 | 16,092 | 0 (−37-1) | 1,540 | −167 (−169, −166) | 210 | −9 (−10, −9) | 12 | 0 (0-4)
Hybrid
A45-49, B50-74 | 15,992 | 0 (−32-0) | 1,416 | −180 (−183, −178) | 189 | −6 (−7, −6) | 19 | 0 (0-4)
A45-54, B55-74 | 18,006 | −1 (−33-0) | 1,514 | −203 (−206, −201) | 195 | −3 (−4, −3) | 19 | 0 (0-3)
A40-49, B50-74 | 20,898 | 0 (−44-2) | 1,896 | −212 (−217, −211) | 236 | +1 (−1, 1) | 21 | 0 (0-4)
Annual
50-74 | 21,439 | 0 (−47-1) | 1,543 | −271 (−272, −266) | 192 | −6 (−6, −6) | 16 | 0 (0-3)
45-74 | 26,272 | −1 (−59-0) | 1,943 | −302 (−304, −297) | 233 | 0 (−1, 0) | 18 | 0 (0-3)
40-74 | 31,178 | 0 (−77-2) | 2,423 | −334 (−337, −330) | 281 | +7 (5, 7) | 19 | 0 (0-4)

a Results summarized over five models (D, E, GE, M, W); model S not included in the table. Range of values for DM shown in Table 4 and Table 6.

b Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

c Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario.

Stopping screening at age 79 instead of age 74 generally resulted in an additional 3% to 5% mortality reduction, 1 additional breast cancer death averted, and 64 to 173 additional false-positive recalls per 1,000 persons, depending on strategy (Table 9).

Table 9 Impact of Screening Continuation to Age 79 (Median and Range Across Models) vs. 74 (Median Across Models) on Screening Benefits and Harms for a Cohort of 1,000 40-Year-Old Female Persons Screened With Digital Breast Tomosynthesis or Digital Mammography vs. No Screening

Strategy and Starting Age^a^ | Breast Cancer Mortality Reduction, % | | Breast Cancer Deaths Averted | | Life-Years Gained | | QALYs Gained
Strategy and Starting Age^a^ | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74
Digital Breast Tomosynthesis
Biennial
50 | 25.4 | +2.9 (2.6-6.1) | 6.7 | +0.8 (0.6-2.3) | 120.8 | +8.8 (−5.8-20.1) | 86.1 | +6.5 (−4.3-14.5)
45 | 27.5 | +4.6 (3.8-9.0) | 7.5 | +1.2 (1.1-3.4) | 141.3 | +13.4 (9.0-30.1) | 100.4 | +9.7 (6.0-21.8)
40 | 30.0 | +3.0 (2.6-6.0) | 8.2 | +0.8 (0.7-2.3) | 165.2 | +8.8 (6.1-19.8) | 116.8 | +6.5 (4.0-14.3)
Hybrid
A45-49, B50 | 29.5 | +3.2 (2.5-6.0) | 8.0 | +0.8 (0.7-2.3) | 153.5 | +7.4 (3.2-20.1) | 107.8 | +5.2 (1.7-14.5)
A45-54, B55 | 29.9 | +4.4 (3.3-9.1) | 8.2 | +1.2 (0.8-3.4) | 161.1 | +12.9 (9.5-30.2) | 110.7 | +8.9 (6.2-21.8)
A40-49, B50 | 32.2 | +2.9 (2.2-6.0) | 8.8 | +0.8 (0.6-2.3) | 181.2 | +9.0 (6.5-20.0) | 125.7 | +6.4 (4.3-14.5)
Annual
50 | 30.6 | +4.2 (3.6-7.9) | 8.6 | +1.2 (0.9-3.0) | 155.6 | +12.7 (−2.7-25.6) | 109.0 | +9.1 (−2.8-18.0)
45 | 34.1 | +4.4 (4.1-7.9) | 9.7 | +1.3 (1.0-3.0) | 193.3 | +11.5 (5.5-25.8) | 132.0 | +8.2 (3.4-18.1)
40 | 37.0 | +4.3 (4.1-7.9) | 10.3 | +1.2 (1.0-3.0) | 216.6 | +13.4 (9.6-25.8) | 146.1 | +9.6 (5.9-18.1)
Digital Mammography
Biennial
50 | 24.3 | +3.2 (2.5-6.0) | 6.9 | +0.8 (0.7-2.2) | 114.6 | +7.7 (5.6-19.7) | 80.7 | +5.3 (3.6-14.0)
45 | 26.4 | +4.6 (3.7-8.9) | 7.8 | +1.1 (1.1-3.3) | 140.0 | +12.2 (5.6-29.6) | 97.5 | +7.8 (3.1-21.1)
40 | 28.4 | +3.1 (2.5-6.0) | 8.4 | +0.8 (0.7-2.2) | 170.1 | +7.7 (6.0-19.8) | 118.8 | +5.2 (3.9-14.1)
Hybrid
A45-49, B50 | 29.3 | +3.0 (2.5-6.0) | 8.6 | +0.8 (0.7-2.2) | 151.3 | +7.7 (5.4-19.7) | 104.7 | +5.3 (3.3-14.0)
A45-54, B55 | 29.3 | +4.6 (3.9-8.9) | 8.8 | +1.1 (1.1-3.3) | 159.3 | +12.2 (9.5-29.6) | 109.8 | +7.8 (6.0-21.1)
A40-49, B50 | 31.7 | +3.1 (2.6-6.2) | 9.3 | +0.8 (0.7-2.3) | 178.9 | +8.6 (6.3-22.4) | 122.2 | +6.1 (3.9-16.2)
Annual
50 | 29.4 | +4.8 (4.1-7.8) | 9.2 | +1.2 (1.0-2.9) | 153.2 | +11.8 (9.5-25.3) | 104.2 | +8.4 (5.6-17.3)
45 | 33.4 | +4.9 (4.1-7.9) | 10.4 | +1.2 (1.0-2.9) | 187.3 | +11.3 (8.4-25.9) | 125.0 | +8.4 (4.7-17.9)
40 | 35.2 | +5.0 (4.1-7.8) | 11.0 | +1.2 (1.1-2.9) | 208.7 | +11.3 (9.7-25.1) | 138.0 | +8.4 (5.7-17.2)
Digital Breast Tomosynthesis | Mammograms | | False-Positive Recalls | | Benign Biopsies | | Overdiagnosed Cases, n^b^
Digital Breast Tomosynthesis | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74
Biennial
50 | 11,208 | +1,281 (1,218-1,298) | 873 | +64 (61-66) | 136 | +8 (8-9) | 12 | +2 (1-5)
45 | 13,299 | +1,915 (1,820-1,950) | 1,080 | +96 (92-99) | 164 | +13 (12-13) | 13 | +3 (2-8)
40 | 16,116 | +1,277 (1,211-1,306) | 1,376 | +64 (61-66) | 201 | +8 (8-9) | 14 | +2 (1-5)
Hybrid
A45-49, B50 | 16,053 | +1,277 (1,212-1,295) | 1,242 | +64 (61-65) | 184 | +8 (8-9) | 19 | +3 (1-5)
A45-54, B55 | 18,072 | +1,912 (1,813-1,947) | 1,317 | +95 (91-99) | 193 | +13 (12-13) | 20 | +4 (2-8)
A40-49, B50 | 20,979 | +1,275 (1,208-1,300) | 1,691 | +64 (61-66) | 238 | +8 (8-9) | 21 | +3 (1-5)
Annual
50 | 21,500 | +3,177 (2,990-3,233) | 1,277 | +127 (120-131) | 186 | +16 (15-16) | 18 | +4 (2-8)
45 | 26,349 | +3,171 (2,975-3,234) | 1,647 | +127 (120-131) | 234 | +16 (15-16) | 20 | +4 (2-8)
40 | 31,273 | +3,167 (2,966-3,242) | 2,096 | +127 (119-132) | 288 | +16 (15-17) | 21 | +4 (2-8)
Digital Mammography
Biennial
50 | 11,192 | +1,279 (1,224-1,294) | 1,021 | +84 (81-86) | 148 | +12 (11-12) | 10 | +2 (1-4)
45 | 13,283 | +1,913 (1,830-1,939) | 1,230 | +126 (122-129) | 173 | +18 (17-18) | 11 | +3 (2-7)
40 | 16,092 | +1,276 (1,219-1,294) | 1,540 | +84 (81-86) | 210 | +12 (11-12) | 12 | +2 (1-4)
Hybrid
A45-49, B50 | 15,992 | +1,276 (1,219-1,294) | 1,416 | +84 (81-86) | 189 | +12 (11-12) | 19 | +3 (1-4)
A45-54, B55 | 18,006 | +1,907 (1,823-1,939) | 1,514 | +125 (121-129) | 195 | +18 (17-18) | 19 | +4 (2-7)
A40-49, B50 | 20,898 | +1,276 (1,215-1,294) | 1,896 | +84 (81-86) | 236 | +12 (11-12) | 21 | +3 (1-4)
Annual
50 | 21,439 | +3,172 (3,004-3,214) | 1,543 | +173 (166-178) | 192 | +20 (19-21) | 16 | +4 (2-7)
45 | 26,272 | +3,164 (2,991-3,214) | 1,943 | +172 (165-178) | 233 | +20 (19-21) | 18 | +4 (2-7)
40 | 31,178 | +3,162 (2,984-3,214) | 2,423 | +172 (165-178) | 281 | +20 (19-21) | 19 | +4 (2-7)

a Results for DM are summarized over five models (D, E, GE, M, W); DBT results include six models (D, E, GE, M, S, W). Range of values for stopping age 74 shown in Tables 4–7.

b Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario. Model S (Stanford University) is excluded because it does not include DCIS.

The majority of models identified five screening strategies as efficient or near-efficient for both primary metrics (percent mortality reduction and LYG), all with DBT, including: biennial (B) 50-74; B45-79; B40-79; B40-49 with annual (A) 50-79; and A40-79 (Table 10; table shows strategies efficient or near-efficient for either metric by most models). Compared with less-intensive screening strategies (or no screening), screening with B50-74 and B45-79 required fewer than 150 additional mammograms in most models to increase LYG by 1 life-year (Figure 5) and fewer than 1,000 additional mammograms in most models to decrease breast cancer mortality by 1 percentage point more (Figure 6). (Note: Considering the reciprocal, 1 LYG/150 mammograms is equal to 2.4 life-days gained per mammogram.) Compared with B 50-74 (the recommendation in 2016), starting screening at age 40 or 45 averted about 2 additional breast cancer deaths while screening annually at ages 40–79 averted about 5 additional breast cancer deaths (Figure 7, Appendix Table 8).

Table 10 Incremental Ratios for Breast Cancer Mortality (Change in the Number of Mammograms/Change in Percent Breast Cancer Mortality Reduction) and Life-Years Gained (Change in the Number of Mammograms/Change in LYG) From Six Models for a Cohort of 1,000 40-Year-Old Female Persons According to Screening Strategy

Strategy^a^ | Screens, n^b^ | Δ mammograms / Δ % mortality reduction | | | | | | Δ mammograms / Δ LYG
Strategy^a^ | Screens, n^b^ | D | E | GE | M | S | W | D | E | GE | M | S | W
DBT B50-74 | 11,208 | 384 | 441 | ^c^ | 426 | 440 | 540^d^ | 64 | 94 | ^c^ | 91 | 90 | 95
DBT B50-79 | 12,448 | 457 | 488 | ^c^ | 428 | 507 | 517 | ^c^ | ^c^ | ^c^ | 119^d^ | ^c^ | 130^d^
DBT B45-74 | 13,299 | ^c^ | ^c^ | ^c^ | ^c^ | ^c^ | ^c^ | 87 | 101 | 76^d^ | 102^d^ | 178^d^ | 116
DBT B45-79 | 15,218 | 813 | 795 | 474 | 621 | 733 | 912 | 148^d^ | 209^d^ | 74^d^ | ^c^ | 143 | 132
DBT B40-74 | 16,116 | ^c^ | ^c^ | ^c^ | ^c^ | ^c^ | ^c^ | 130 | 179 | 74^d^ | 93 | ^c^ | 203^d^
DBT B40-79 | 17,397 | 2,142 | 2,612^d^ | 1,795 | 907 | 1,780 | 3,110^d^ | 155 | 206 | 73 | 194 | 169 | 154
DBT A40-49, B50-79 | 22,255 | 7,236^d^ | 5,959^d^ | 2,532^d^ | 5,527^d^ | 4,673^d^ | ^c^ | 736^d^ | 215 | 219 | 407 | 725^d^ | 218^d^
DBT A45-79 | 29,517 | 4,310^d^ | 1,564 | 2,024^d^ | ^c^ | 2,155 | 1,377 | ^c^ | ^c^ | ^c^ | ^c^ | ^c^ | 222^d^
DBT A40-79 | 34,441 | 3,649 | 2,169 | 1,816^d^ | 2,686 | 2,295 | 2,218 | 658 | 323 | 302 | 577 | 510 | 217

Abbreviations: A, annual; B, biennial; D, Dana-Farber Cancer Institute; DBT, digital breast tomosynthesis; DM, digital mammography; E, Erasmus Medical Center; GE, Georgetown Lombardi Comprehensive Cancer Center-Albert Einstein College of Medicine; M, University of Texas MD Anderson Cancer Center; S, Stanford University; W, University of Wisconsin-Madison and Harvard Pilgrim Health Care Institute.

a Ratios for each strategy are calculated relative to the next efficient or near-efficient strategy with fewer mammograms, not necessarily shown in the table (varied across models). B50-74 is compared with no screening. The ratio for the strategy with the fewest number of mammograms (B50-74) is calculated relative to no screening. DBT strategies are shown that were efficient or near-efficient in 5 or more out of 6 models for either incremental ratio. Zero DM strategies were efficient or near-efficient in 4 or more out of 5 models for either incremental ratio.

b Median number of mammograms across models. Strategies are ranked from the least to the most mammograms.

c Strategies that are inferior (also referred to as less efficient or dominated) within a specific model; a strategy is classified as such if another strategy results in an equal or higher benefit (percent reduction in breast cancer mortality or life-years gained) with fewer harms (number of screening examinations).

d Near-efficient strategy. Strategies were considered near-efficient if they were within 2.2 days per person for LYG and 1.27 percentage points for percent breast cancer mortality reduction of the efficient frontier.

Figure 5 Efficiency Frontiers for the Estimated Lifetime Number of Mammograms and Life-Years Gained for a Cohort of 1,000 Female Persons by Model and Screening Strategy

Dot plots of life-years gained by the number of mammograms for 36 mammography screening strategies for female persons overall. Six panels are shown, one for each CISNET model. In general, life-years gained increases with greater numbers of mammograms, with the gain per additional mammogram greater for biennial strategies than for annual ones.

Figure 6 Efficiency Frontiers for the Estimated Lifetime Number of Mammograms and Percent Breast Cancer Mortality Reduction for a Cohort of 1,000 Female Persons by Model and Screening Strategy

Dot plots of the percent reduction in breast cancer mortality by the number of mammograms for 36 mammography screening strategies for female persons overall. Six panels are shown, one for each CISNET model. In general, the percent breast cancer mortality reduction increases with greater numbers of mammograms, with the breast cancer mortality reduction per additional mammogram greater for biennial strategies than for annual ones.

Figure 7 Estimated Median Lifetime Numbers of Breast Cancer Deaths Averted for a Cohort of 1,000 Female Persons Undergoing Screening Across Five Models and Varying Modalities, Screening Intervals, and Ages to Start and Stop Screening

Note: Blue bars represent the initial strategy, with the orange bars showing the incremental gain in breast cancer deaths averted by changing modality, screening more frequently, starting screening earlier, and/or stopping screening later. Comparison strategies limited to efficient and near-efficient screening strategies. Results shown as medians across five models (D, E, GE, M, and W).

Bar chart of the additional number of breast cancer deaths averted for several mammography screening strategies compared with biennial screening at ages 50-74 for female persons overall. Starting biennial screening earlier or stopping later averts 1 to 3 additional breast cancer deaths. Screening annually instead of biennially averts up to about five additional breast cancer deaths.

The percent of invasive breast cancer cases diagnosed in advanced stages generally decreased with more intensive screening (Figure 8). For example, the median percentage of advanced cases for annual screening with DBT during ages 40–79 was 12.5% (range across four models, 10.9% to 14.8%, AJCC staging) versus 21.8% for biennial screening during ages 50–74 (range, 19.0% to 23.1%).

Figure 8 Percent of Invasive Breast Cancer Cases Diagnosed in an Advanced Stage According to AJCC Version 6 (IIB or Higher) or SEER Summary (Regional or Distant) Staging Scheme by Model and Mammogram Modality

Abbreviations: AJCC, American Joint Committee on Cancer; DM, digital mammography; DBT, digital breast tomosynthesis; SEER, Surveillance, Epidemiology, and End Results.

Dot plot of the percent of breast cancer cases diagnosed in advanced stages for six CISNET models and 36 screening strategies for female persons overall. Generally fewer cases were diagnosed in advanced stages for more intensive screening strategies.

## Question 2 Trade-Offs of Screening Strategies for Black Female Persons

The analyses described above for female persons of all races were repeated by four models of breast cancer in Black female persons.

### Overall Trade-Offs of Screening Strategies for Black Female Persons

Trade-offs between benefits and harms of different screening strategies for Black female persons followed similar patterns as for all female persons combined. However, strategies resulted in more breast cancer deaths averted and LYG for Black female persons compared with the same strategies for female persons overall for DM (Table 11, Appendix Table 9) and for DBT (Table 12, Appendix Table 10). For each screening strategy, false-positive recalls, benign biopsies, and the number of overdiagnosed cases were also higher among Black female persons compared with outcomes for female persons overall for both DM (Table 13) and DBT (Table 14).

Table 11 Median Lifetime Benefits (and Range Across Four Models) of Screening Strategies With Digital Mammography for a Cohort of 1,000 40-Year-Old Black Female Persons Compared With No Screening According to Screening Interval, Starting Age, and Stopping Age

Interval and Age Group^a^ | Breast Cancer Mortality Reduction, % | Breast Cancer Deaths Averted | Life-Years Gained | QALYs Gained^b^
Biennial
50-74 | 22.7 (18.5-25.2) | 8.5 (6.5-12.2) | 163.5 (121.7-211.9) | 116.5 (82.6-153.6)
45-74 | 25.0 (19.1-28.0) | 9.0 (7.4-13.5) | 183.2 (153.0-262.2) | 131.1 (103.2-191.4)
40-74 | 27.9 (20.8-31.0) | 10.0 (8.1-14.9) | 214.0 (174.0-297.5) | 153.9 (113.6-216.3)
Hybrid
A45-49, B50-74 | 26.2 (20.8-30.2) | 9.5 (7.9-14.6) | 196.5 (153.9-281.7) | 138.1 (103.5-204.5)
A45-54, B55-74 | 26.0 (21.1-29.3) | 9.6 (7.8-14.1) | 202.7 (159.9-278.7) | 141.8 (106.8-200.9)
A40-49, B50-74 | 28.7 (22.3-32.5) | 10.3 (8.7-15.7) | 223.0 (195.8-318.4) | 156.8 (126.3-228.7)
Annual
50-74 | 27.6 (24.2-31.8) | 10.8 (7.7-15.4) | 211.1 (145.6-266.5) | 146.3 (94.2-189.9)
45-74 | 30.1 (28.3-36.8) | 11.8 (9.0-17.8) | 243.6 (186.4-336.0) | 167.5 (121.8-240.5)
40-74 | 32.4 (30.4-39.1) | 12.4 (10.2-18.9) | 266.4 (227.8-373.2) | 183.8 (149.9-265.1)
Biennial
50-79 | 25.6 (22.4-30.0) | 9.9 (7.5-14.5) | 176.8 (131.3-233.2) | 125.4 (88.9-168.5)
45-79 | 29.2 (24.4-35.2) | 10.8 (8.9-17.0) | 202.0 (164.3-294.4) | 142.6 (112.1-214.0)
40-79 | 30.8 (24.6-35.8) | 11.0 (9.6-17.3) | 225.4 (189.0-318.5) | 161.7 (123.1-231.0)
Hybrid
A45-49, B50-79 | 28.9 (24.6-35.0) | 10.8 (8.8-16.9) | 209.5 (166.9-303.1) | 146.8 (112.3-219.5)
A45-54, B55-79 | 30.2 (26.4-36.5) | 11.4 (9.2-17.6) | 221.5 (172.7-311.1) | 154.2 (114.9-223.7)
A40-49, B50-79 | 31.6 (26.1-37.5) | 11.5 (9.9-18.1) | 232.6 (210.6-343.5) | 163.2 (135.7-246.7)
Annual
50-79 | 33.0 (28.3-38.3) | 12.9 (9.0-18.5) | 232.3 (160.0-295.0) | 159.9 (102.9-209.0)
45-79 | 35.4 (32.3-43.3) | 13.9 (10.3-20.9) | 264.8 (189.3-364.4) | 181.1 (121.7-259.6)
40-79 | 37.0 (35.9-45.5) | 14.5 (11.5-22.0) | 287.5 (239.5-401.3) | 194.2 (156.5-284.0)

Abbreviations: A, annual; B, biennial.

a All strategies show results for Models D, GE, M, and W.

b Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

Table 12 Median Lifetime Benefits (and Range Across Four Models) of Screening Strategies With Digital Breast Tomosynthesis for a Cohort of 1,000 40-Year-Old Black Female Persons Compared With No Screening According to Screening Interval, Starting Age, and Stopping Age

Interval and Age Group^a^ | Breast Cancer Mortality Reduction, % | Breast Cancer Deaths Averted | Life-Years Gained | QALYs Gained^b^
Biennial
50-74 | 24.1 (19.8-27.1) | 9.2 (7.1-12.6) | 176.7 (127.8-219.8) | 130.6 (91.3-163.8)
45-74 | 26.8 (20.5-28.9) | 9.7 (8.0-13.9) | 199.0 (157.3-270.4) | 147.0 (113.2-202.5)
40-74 | 29.9 (22.4-31.9) | 10.7 (8.7-15.4) | 228.9 (189-305.7) | 171.5 (130.1-228.4)
Hybrid
A45-49, B50-74 | 28.1 (22.3-31.1) | 10.3 (8.4-15.0) | 212.9 (167.3-288.8) | 156.3 (119.2-215.6)
A45-54, B55-74 | 27.9 (22.6-30.1) | 10.3 (8.3-14.5) | 219.1 (165.4-285.8) | 160.5 (117.2-212.5)
A40-49, B50-74 | 30.9 (24.0-33.6) | 11.1 (9.4-16.2) | 239.4 (213.1-329.5) | 177.0 (146.0-244.6)
Annual
50-74 | 29.3 (25.5-32.4) | 11.5 (8.2-15.6) | 224.7 (154.2-271.3) | 163.3 (107.3-200.1)
45-74 | 32.1 (30.0-37.3) | 12.6 (9.6-18.0) | 260.8 (196.2-340.3) | 188.8 (137.3-251.8)
40-74 | 34.4 (32.2-39.6) | 13.3 (10.7-19.1) | 286.2 (243.7-377.7) | 205.6 (171.8-278.2)
Biennial
50-79 | 27.6 (24.1-31.0) | 10.7 (8.0-15.0) | 191.2 (142.0-241.7) | 140.9 (101.4-179.6)
45-79 | 31.2 (26.4-36.3) | 11.7 (9.3-17.5) | 219.4 (172.7-303.6) | 161.3 (123.7-226.6)
40-79 | 33.0 (26.6-36.8) | 12 (10.2-17.8) | 238.5 (205.4-328.1) | 178.5 (141.0-244.6)
Hybrid
A45-49, B50-79 | 31.1 (26.5-35.9) | 11.7 (9.3-17.3) | 227.1 (177.0.-310.7) | 166.3 (126.0-231.4)
A45-54, B55-79 | 32.4 (28.5-37.5) | 12.4 (9.7-18.1) | 239.6 (180.7-318.7) | 174.8 (127.7-236.3)
A40-49, B50-79 | 33.9 (28.2-38.4) | 12.4 (10.5-18.5) | 253.1 (225.4-351.4) | 185.6 (157.0-260.4)
Annual
50-79 | 35.1 (29.7-39.0) | 13.8 (9.5-18.8) | 247.6 (164.5-300.2) | 179.0 (113.7-220.5)
45-79 | 37.9 (34.0-43.9) | 14.9 (10.9-21.2) | 283.6 (209.5-369.0) | 204.5 (146.0-272.1)
40-79 | 39.6 (37.9-46.2) | 15.5 (12.1-22.3) | 309.0 (253.9-406.8) | 221.2 (178.1-298.8)

Abbreviations: A, annual; B, biennial.

a All strategies show results for Models D, GE, M, and W.

b Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

Table 13 Lifetime Harms (and Range Across Four Models) of Screening With Digital Mammography Compared With No Screening for a Cohort of 1,000 40-Year-Old Black Female Persons According to Interval, Start Age, and Stop Age

Strategy | Mammograms | False-Positive Recalls | Benign Biopsies | Overdiagnosed Cases^a^
Biennial
50-74 | 10,905 (10,834-10,939) | 1,263 (1,255-1,265) | 188 (187-188) | 16 (5-26)
45-74 | 13,009 (12,937-13,055) | 1,517 (1,511-1,524) | 218 (217-219) | 16 (5-27)
40-74 | 15,801 (15,706-15,856) | 1,880 (1,869-1,887) | 262 (261-263) | 18 (6-29)
Hybrid
A45-49, B50-74 | 15,743 (15,655-15,797) | 1,755 (1,748-1,764) | 234 (232-234) | 18 (5-29)
A45-54, B55-74 | 17,772 (17,677-17,840) | 1,887 (1,879-1,897) | 238 (237-240) | 18 (5-29)
A40-49, B50-74 | 20,677 (20,559-20,758) | 2,328 (2,315-2,338) | 285 (283-286) | 18 (6-31)
Annual
50-74 | 20,935 (20,733-20,988) | 1,960 (1,942-1,964) | 231 (229-232) | 19 (6-34)
45-74 | 25,760 (25,524-25,846) | 2,452 (2,433-2,462) | 277 (274-278) | 20 (6-37)
40-74 | 30,694 (30,409-30,793) | 3,024 (2,998-3,036) | 328 (325-329) | 21 (6-39)
Biennial
50-79 | 12,072 (11,978-12,115) | 1,387 (1,375-1,387) | 206 (204-206) | 18 (7-31)
45-79 | 14,755 (14,650-14,818) | 1,703 (1,691-1,705) | 245 (243-245) | 20 (8-33)
40-79 | 16,966 (16,847-17,032) | 2,004 (1,989-2,007) | 280 (278-281) | 20 (7-34)
Hybrid
A45-49, B50-79 | 16,907 (16,796-16,973) | 1,879 (1,868-1,885) | 252 (250-252) | 20 (7-34)
A45-54, B55-79 | 19,518 (19,386-19,595) | 2,072 (2,059-2,078) | 265 (263-266) | 22 (8-36)
A40-49, B50-79 | 21,846 (21,698-21,919) | 2,451 (2,434-2,459) | 303 (301-304) | 21 (7-35)
Annual
50-79 | 23,830 (23,548-23,907) | 2,216 (2,188-2,218) | 260 (257-260) | 23 (8-42)
45-79 | 28,644 (28,329-28,765) | 2,707 (2,678-2,715) | 305 (302-306) | 24 (9-44)
40-79 | 33,578 (33,209-33,711) | 3,280 (3,243-3,287) | 357 (353-358) | 25 (9-46)

Abbreviations: A, annual; B, biennial.

a Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been diagnosed in the absence of screening. Overdiagnosis is calculated by subtracting the number of diagnosed cases detected in the no-screening scenario from the number of diagnosed cases detected in the screening scenario.

Table 14 Lifetime Harms (and Range Across Four Models) of Screening With Digital Breast Tomosynthesis Compared With No Screening for a Cohort of 1,000 40-Year-Old Black Female Persons According to Interval, Start Age, and Stop Age

Strategy | Mammograms | False-Positive Recalls | Benign Biopsies | Overdiagnosed Cases^a^
Biennial
50-74 | 10,905 (10,820-10,939) | 814 (807-816) | 158 (157-159) | 16 (5-28)
45-74 | 13,009 (12,919-13,055) | 997 (991-1,002) | 189 (188-190) | 16 (5-29)
40-74 | 15,801 (15,681-15,856) | 1,253 (1,243-1,257) | 233 (231-233) | 18 (6-32)
Hybrid
A45-49, B50-74 | 15,743 (15,634-15,797) | 1,144 (1,138-1,150) | 206 (205-207) | 18 (5-31)
A45-54, B55-74 | 17,771 (17,655-17,839) | 1,217 (1,211-1,225) | 212 (210-213) | 18 (5-31)
A40-49, B50-74 | 20,676 (20,529-20,757) | 1,534 (1,523-1,541) | 260 (258-261) | 18 (6-33)
Annual
50-74 | 20,934 (20,702-20,988) | 1,209 (1,195-1,211) | 200 (198-200) | 19 (6-36)
45-74 | 25,759 (25,482-25,846) | 1,538 (1,524-1,546) | 247 (245-249) | 20 (6-39)
40-74 | 30,693 (30,354-30,792) | 1,929 (1,908-1,936) | 302 (299-303) | 21 (6-41)
Biennial
50-79 | 12,073 (11,961-12,115) | 887 (878-888) | 171 (169-171) | 18 (7-33)
45-79 | 14,755 (14,625-14,818) | 1,107 (1,097-1,109) | 208 (206-208) | 20 (8-37)
40-79 | 16,965 (16,817-17,032) | 1,326 (1,314-1,329) | 245 (243-246) | 20 (7-37)
Hybrid
A45-49, B50-79 | 16,907 (16,771-16,973) | 1,217 (1,208-1,222) | 218 (217-219) | 20 (7-36)
A45-54, B55-79 | 19,517 (19,357-19,595) | 1,327 (1,317-1,332) | 230 (228-231) | 22 (8-39)
A40-49, B50-79 | 21,846 (21,663-21,919) | 1,608 (1,593-1,612) | 273 (270-273) | 21 (7-39)
Annual
50-79 | 23,827 (23,506-23,907) | 1,353 (1,334-1,355) | 221 (218-221) | 23 (8-44)
45-79 | 28,646 (28,276-28,765) | 1,683 (1,663-1,688) | 268 (265-269) | 24 (9-47)
40-79 | 33,577 (33,141-33,711) | 2,074 (2,046-2,077) | 323 (318-323) | 25 (9-49)

Abbreviations: A, annual; B, biennial.

a Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been diagnosed in the absence of screening. Overdiagnosis is calculated by subtracting the number of diagnosed cases detected in the no-screening scenario from the number of diagnosed cases detected in the screening scenario.

Among screening strategies stopping at age 74, median estimates from the models showed that use of DBT instead of DM among Black female persons resulted in less than 1 additional breast cancer death averted, about 9 to 17 additional LYG, and 449 to 1,095 fewer false-positive recalls for 1,000 Black female persons screened, depending on strategy (Table 15).

Table 15 Change in Benefits and Harms Across Four Models for a Cohort of 1,000 40-Year-Old Black Female Persons Screened With Digital Breast Tomosynthesis (Median and Range^a^) Instead of Digital Mammography (Median) vs. No Screening According to Interval and Start Age With Stop Age 74 Years

Strategy and Age Group | Breast Cancer Mortality Reduction, % | | Breast Cancer Deaths Averted | | Life-Years Gained | | QALYs Gained^b^
Strategy and Age Group | DM vs. No Screening | DBT vs. DM | DM vs. No Screening | DBT vs. DM | DM vs. No Screening | DBT vs. DM | DM vs. No Screening | DBT Vs. DM
Biennial
50-74 | 22.7 | +1.5 (0.9-2.2) | 8.5 | +0.5 (0.4-0.9) | 163.5 | +8.9 (6.1-16.5) | 116.5 | +10.6 (8.6-17.4)
45-74 | 25.0 | +1.4 (0.9-2.4) | 9.0 | +0.5 (0.4-0.9) | 183.2 | +10.4 (4.3-18.9) | 131.1 | +12.4 (8.1-20.0)
40-74 | 27.9 | +1.6 (0.9-2.5) | 10.0 | +0.6 (0.4-1.0) | 214.0 | +11.9 (8.2-21.1) | 153.9 | +14.5 (12.1-22.7)
Hybrid
A45-49, B50-74 | 26.2 | +1.4 (0.8-2.4) | 9.5 | +0.5 (0.4-1.0) | 196.5 | +13.5 (7.1-19.3) | 138.1 | +15.5 (11.0-21.2)
A45-54, B55-74 | 26.0 | +1.5 (0.8-2.4) | 9.6 | +0.5 (0.4-0.9) | 202.7 | +10.5 (5.5-19.0) | 141.8 | +13.8 (10.4-21.4)
A40-49, B50-74 | 28.7 | +1.8 (1.1-2.6) | 10.3 | +0.6 (0.5-1.0) | 223.0 | +14.4 (11.2-21.4) | 156.8 | +17.9 (15.9-24.4)
Annual
40-74 | 27.6 | +1.4 (0.5-2.1) | 10.8 | +0.5 (0.3-0.8) | 211.1 | +10.0 (4.8-16.0) | 146.3 | +13.8 (10.2-19.4)
45-74 | 30.1 | +1.7 (0.5-2.3) | 11.8 | +0.6 (0.2-0.9) | 243.6 | +12.7 (4.3-18.8) | 167.5 | +17.4 (11.3-23.2)
40-74 | 32.4 | +1.7 (0.5-2.5) | 12.4 | +0.6 (0.2-1.0) | 266.4 | +17.4 (4.5-20.8) | 183.8 | +21.0 (13.1-23.4)
Biennial | Mammograms | | False-Positive Recalls | | Benign Biopsies | | Overdiagnosed Cases^c^
Biennial | DM vs No Screening | DBT vs DM | DM vs No Screening | DBT vs DM | DM vs No Screening | DBT vs DM | DM vs No Screening | DBT vs DM
50-74 | 10,905 | 0 (−14-0) | 1,263 | −449 (−450, −448) | 188 | −30 (−30, −30) | 16 | 0 (0-2)
45-74 | 13,009 | 0 (−18-0) | 1,517 | −520 (−522, −520) | 218 | −28 (−29, −28) | 16 | 0 (0-2)
40-74 | 15,801 | 0 (−24-0) | 1,880 | −627 (−630, −626) | 262 | −30 (−30, −29) | 18 | 0 (0-3)
Hybrid
A45-49, B50-74 | 15,743 | 0 (−21-0) | 1,755 | −611 (−614, −610) | 234 | −28 (−28, −28) | 18 | 0 (0-2)
A45-54, B55-74 | 17,772 | −1 (−22-0) | 1,887 | −670 (−673, −668) | 238 | −27 (−27, −27) | 18 | 0 (0-2)
A40-49, B50-74 | 20,677 | −1 (−31-0) | 2,328 | −794 (−797, −791) | 285 | −25 (−25, −25) | 18 | 0 (0-3)
Annual
40-74 | 20,935 | −1 (−31-0) | 1,960 | −751 (−753, −746) | 231 | −31 (−31, −31) | 19 | 0 (0-2)
45-74 | 25,760 | −1 (−42-0) | 2,452 | −913 (−917, −908) | 277 | −29 (−29, −29) | 20 | 0 (0-2)
40-74 | 30,694 | −1 (−55-0) | 3,024 | −1,095 (−1,100, −1,090) | 328 | −26 (−27, −26) | 21 | 0 (0-3)

a Results summarized over four models (D, GE, M, W). Range of values for DM shown in Table 11 and Table 13.

b Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

c Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario.

Considering the incremental benefit of stopping screening at age 79 instead of 74, the median additional benefit for Black female persons for percent breast cancer mortality reduction ranged 3.3 to 5.5 percentage points across strategies (Table 16). Continuing screening until age 79 added between 72 and 253 false-positive recalls during the lifetimes of 1,000 Black female persons.

Table 16 Changes in Benefits and Harms for a Cohort of 1,000 40-Year-Old Black Female Persons Screened With Digital Breast Tomosynthesis or Digital Mammography vs. No Screening Until Age 79 (Median and Range Across Four Models^a^) Instead of Age 74 (Median Across Four Models)

Type of Mammography, Strategy, and Starting Age^a^ | Breast Cancer Mortality Reduction, % | | Breast Cancer Deaths Averted | | Life-Years Gained | | QALYs Gained
Type of Mammography, Strategy, and Starting Age^a^ | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74
Digital Breast Tomosynthesis
Biennial
50 | 24.1 | +3.7 (2.8-4.9) | 9.2 | +1.4 (0.9-2.4) | 176.7 | +15.4 (12.4-21.9) | 130.6 | +10.6 (9.5-15.8)
45 | 26.8 | +5.2 (4.3-7.4) | 9.7 | +2.0 (1.4-3.6) | 199.0 | +20.5 (15.3-33.2) | 147.0 | +14.3 (10.5-24.0)
40 | 29.9 | +3.7 (3.1-4.9) | 10.7 | +1.4 (1-2.4) | 228.9 | +14.5 (6.9-22.5) | 171.5 | +10.2 (4.6-16.2)
Hybrid
A45-49, B50 | 28.1 | +3.6 (3.0-4.9) | 10.3 | +1.4 (1.0-2.4) | 212.9 | +14.1 (9.6-21.9) | 156.3 | +10.0 (6.8-15.8)
A45-54, B55 | 27.9 | +5.2 (4.4-7.3) | 10.3 | +2.0 (1.4-3.5) | 219.1 | +20.4 (15.2-32.9) | 160.5 | +14.3 (10.5-23.8)
A40-49, B50 | 30.9 | +3.7 (3.0-4.9) | 11.1 | +1.4 (1.0-2.4) | 239.4 | +14.4 (10.9-21.9) | 177.0 | +10.2 (7.7-15.8)
Annual
50 | 29.3 | +5.4 (4.2-7.5) | 11.5 | +2.3 (1.3-3.2) | 224.7 | +22.6 (10.3-29.5) | 163.3 | +15.7 (6.3-20.4)
45 | 32.1 | +5.4 (4.0-7.4) | 12.6 | +2.3 (1.3-3.2) | 260.8 | +22.5 (13.3-29.3) | 188.8 | +15.7 (8.7-20.3)
40 | 34.4 | +5.5 (4.2-7.4) | 13.3 | +2.3 (1.4-3.2) | 286.2 | +22.7 (10.2-29.2) | 205.6 | +15.6 (6.3-20.6)
Digital Mammography
Biennial
50 | 22.7 | +3.4 (2.9-4.8) | 8.5 | +1.3 (1.0-2.3) | 163.5 | +13.3 (9.6-21.4) | 116.5 | +9.0 (6.2-15.0)
45 | 25.0 | +4.8 (4.2-7.2) | 9.0 | +1.9 (1.3-3.5) | 183.2 | +18.8 (11.3-32.2) | 131.1 | +12.5 (7.0-22.6)
40 | 27.9 | +3.4 (2.9-4.8) | 10.0 | +1.3 (0.9-2.3) | 214.0 | +13.3 (11.2-21.1) | 153.9 | +8.9 (7.4-14.7)
Hybrid
A45-49, B50 | 26.2 | +3.3 (2.6-4.8) | 9.5 | +1.3 (0.8-2.3) | 196.5 | +14.0 (10.9-21.4) | 138.1 | +9.1 (7.8-15.0)
A45-54, B55 | 26.0 | +4.8 (4.2-7.2) | 9.6 | +1.9 (1.4-3.5) | 202.7 | +18.8 (12.8-32.4) | 141.8 | +12.5 (8.1-22.8)
A40-49, B50 | 28.7 | +3.3 (2.9-5.0) | 10.3 | +1.3 (0.9-2.4) | 223.0 | +13.2 (7.6-25.1) | 156.8 | +8.9 (4.6-18.0)
Annual
50 | 27.6 | +5.3 (3.9-6.9) | 10.8 | +2.1 (1.3-3.1) | 211.1 | +21.2 (14.5-28.4) | 146.3 | +13.6 (8.7-19.1)
45 | 30.1 | +5.2 (3.9-6.9) | 11.8 | +2.1 (1.3-3.1) | 243.6 | +21.2 (2.9-28.4) | 167.5 | +13.6 (−0.1-19.1)
40 | 32.4 | +5.2 (3.9-6.8) | 12.4 | +2.1 (1.3-3.1) | 266.4 | +21.1 (11.7-28.1) | 183.8 | +11.8 (3.6-18.9)
Digital Breast Tomosynthesis | Mammograms | | False-Positive Recalls | | Benign Biopsies | | Overdiagnosed Cases^b^
Digital Breast Tomosynthesis | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74 | 74 vs. no screening | 79 vs. 74
Biennial
50 | 10,905 | +1,164 (1,141-1,183) | 814 | +72 (71-74) | 158 | +12 (12-13) | 16 | +3 (2-5)
45 | 13,009 | +1,744 (1,707-1,767) | 997 | +108 (106-111) | 189 | +18 (18-19) | 16 | +4 (3-8)
40 | 15,801 | +1,163 (1,136-1,177) | 1,253 | +72 (71-74) | 233 | +12 (12-13) | 18 | +3 (2-5)
Hybrid
A45-49, B50 | 15,743 | +1,163 (1,137-1,178) | 1,144 | +72 (71-74) | 206 | +12 (12-13) | 18 | +2 (2-5)
A45-54, B55 | 17,771 | +1,742 (1,702-1,763) | 1,217 | +108 (106-110) | 212 | +18 (18-19) | 18 | +4 (3-7)
A40-49, B50 | 20,676 | +1,163 (1,134-1,176) | 1,534 | +72 (70-74) | 260 | +12 (12-13) | 18 | +3 (2-5)
Annual
50 | 20,934 | +2,888 (2,804-2,929) | 1,209 | +143 (139-146) | 200 | +20 (20-21) | 19 | +4 (2-8)
45 | 25,759 | +2,885 (2,794-2,924) | 1,538 | +143 (138-146) | 247 | +20 (20-21) | 20 | +4 (2-8)
40 | 30,693 | +2,883 (2,787-2,919) | 1,929 | +143 (138-146) | 302 | +20 (20-21) | 21 | +4 (2-8)
Digital Mammography
Biennial
50 | 10,905 | +1,164 (1,144-1,181) | 1,263 | +122 (120-125) | 188 | +18 (18-18) | 16 | +2 (2-5)
45 | 13,009 | +1,744 (1,713-1,766) | 1,517 | +183 (180-187) | 218 | +27 (26-27) | 16 | +4 (3-7)
40 | 15,801 | +1,163 (1,141-1,178) | 1,880 | +122 (120-125) | 262 | +18 (18-18) | 18 | +3 (2-5)
Hybrid
A45-49, B50 | 15,743 | +1,163 (1,141-1,178) | 1,755 | +122 (120-125) | 234 | +18 (18-18) | 18 | +3 (2-5)
A45-54, B55 | 17,772 | +1,743 (1,709-1,763) | 1,887 | +183 (179-187) | 238 | +27 (26-27) | 18 | +4 (3-7)
A40-49, B50 | 20,677 | +1,163 (1,139-1,176) | 2,328 | +122 (120-125) | 285 | +18 (18-18) | 18 | +3 (2-5)
Annual
50 | 20,935 | +2,889 (2,815-2,931) | 1,960 | +253 (247-259) | 231 | +29 (28-29) | 19 | +4 (2-7)
45 | 25,760 | +2,884 (2,806-2,919) | 2,452 | +253 (246-258) | 277 | +29 (28-29) | 20 | +4 (2-7)
40 | 30,694 | +2,883 (2,800-2,919) | 3,024 | +253 (245-258) | 328 | +29 (28-29) | 21 | +4 (2-7)

a Results summarized over four models (D, GE, M, W). Range of values for stopping age 74 are shown in Tables 11–14.

b Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario.

Among at least three of four models of breast cancer for Black female persons, seven screening strategies were efficient or near-efficient for LYG (Figure 9) or breast cancer mortality reduction (Figure 10). These strategies were a subset of those found efficient or near-efficient for female persons overall; three strategies were efficient or near-efficient for both metrics, including B45-79, B40-79, and A40-79 (Table 17; table shows strategies efficient or near-efficient for either metric by at least three of four models). Expanding biennial screening from ages 50–74 to ages 40–79 averted 3 additional breast cancer deaths (Figure 11; Appendix Table 11).

Figure 9 Efficiency Frontiers for the Estimated Lifetime Number of Mammograms and Life-Years Gained for a Cohort of 1,000 Black Female Persons by Model and Screening Strategy

Dot plots of life-years gained by the number of mammograms for 36 mammography screening strategies for Black female persons. Four panels are shown, one for each CISNET model. In general, life-years gained increases with greater numbers of mammograms, with the gain per additional mammogram greater for biennial strategies than for annual ones.

Figure 10 Efficiency Frontiers for the Estimated Lifetime Number of Mammograms and Percent Breast Cancer Mortality Reduction for a Cohort of 1,000 Black Female Persons by Model and Screening Strategy

Dot plots of the percent reduction in breast cancer mortality by the number of mammograms for 36 mammography screening strategies for Black female persons. Four panels are shown, one for each CISNET model. In general, the percent breast cancer mortality reduction increases with greater numbers of mammograms, with the breast cancer mortality reduction per additional mammogram greater for biennial strategies than for annual ones.

Table 17 Incremental Ratios From Four Models for Breast Cancer Mortality (Change in the Number of Mammograms/Change in % Mortality Reduction) and Life-Years Gained (Change in the Number of Mammograms/Change in LYG) for a Cohort of 1,000 40-Year-Old Black Female Persons According to Screening Modality, Interval, Start Age, and Stop Age

Strategy (all DBT)^a^ | Screens, n^b^ | Δ mammograms / Δ % mortality reduction | | | | Δ mammograms / Δ LYG
Strategy (all DBT)^a^ | Screens, n^b^ | D | GE | M | W | D | GE | M | W
B50-74 | 10,905 | 403^d^ | ^c^ | 492^d^ | ^c^ | 54 | 50^d^ | ^c^ | 75^d^
B50-79 | 12,073 | 400 | 391 | 484 | 497 | 93^d^ | ^c^ | ^c^ | 71
B45-74 | 13,009 | ^c^ | ^c^ | ^c^ | ^c^ | 77 | 48 | ^c^ | 1,507^d^
B45-79 | 14,755 | 860 | 515 | 632 | 1,146^d^ | 95 | 53 | c | 114
B40-74 | 16,116 | ^c^ | ^c^ | ^c^ | ^c^ | 165^d^ | ^c^ | 77 | ^c^
B40-79 | 16,965 | 2,536 | 3,919^d^ | 840 | ^c^ | 117 | 90 | 171 | 157^d^
A40-49, B50-74 | 20,979 | ^c^ | ^c^ | ^c^ | ^c^ | ^c^ | ^c^ | 960^d^ | ^c^
A40-49, B50-79 | 21,846 | 5,887^d^ | ^c^ | 4,526^d^ | ^c^ | 476^d^ | 210 | 330 | ^c^
A45-79 | 28,646 | 3,356^d^ | 1,825 | ^c^ | 1,969 | ^c^ | ^c^ | ^c^ | 143
A40-74 | 31,273 | ^c^ | ^c^ | ^c^ | ^c^ | ^c^ | ^c^ | 482^d^ | ^c^
A40-79 | 33,577 | 3,159 | 2,148 | 2,685 | 3,074 | 428 | 213 | 412 | 190

Abbreviations: A, annual; B, biennial; D, Dana-Farber Cancer Institute; DBT, digital breast tomosynthesis; GE, Georgetown Lombardi Comprehensive Cancer Center-Albert Einstein College of Medicine; M, University of Texas MD Anderson Cancer Center; W, University of Wisconsin-Madison and Harvard Pilgrim Health Care Institute.

a Ratios for each strategy are calculated relative to the next efficient or near-efficient strategy with fewer mammograms, not necessarily shown in the table (varied across models). B50-74 is compared with no screening. The ratio for the strategy with the fewest number of mammograms (B50-74) is calculated relative to no screening. Ratios shown for strategies that were efficient or near-efficient in 3 or 4 out of 4 models for either incremental ratio. No strategies for digital mammography were efficient in at least 3 models.

b Median number of mammograms across models. Strategies are ranked from the least to the most mammograms.

c Strategies that are inferior (also referred to as less efficient or dominated) within a specific model; a strategy is classified as such if another strategy results in an equal or higher benefit (percentage of decline in mortality or life-years gained) with fewer harms (number of screening examinations).

d Near-efficient strategy. Strategies were considered near-efficient if they were within 3.2 days per person for LYG or 1.21 percentage points for percent breast cancer mortality of the efficiency frontier.

Figure 11 Estimated Median Lifetime Numbers of Breast Cancer Deaths Averted for a Cohort of 1,000 40-Year-Old Black Female Persons Undergoing Screening Across Four Models and Varying Modalities, Screening Intervals, Ages to Start Screening, and Ages to Stop Screening

Abbreviations: DBT, digital breast tomosynthesis; DM, digital mammography.

Note: Blue bars represent the initial strategy, with the orange bars showing the incremental gain in breast cancer deaths averted by changing modality, screening more frequently, starting screening earlier, and/or stopping screening later. Comparison strategies limited to efficient and near-efficient screening strategies for Black female persons.

Bar chart of the additional number of breast cancer deaths averted for several mammography screening strategies compared with biennial screening at ages 50-74 for Black female persons. Starting biennial screening earlier or stopping later averts about 2 to 3 additional breast cancer deaths. Screening annually from ages 40 to 79 instead of biennially from 50 to 74 averts up to about 6 to 7 additional breast cancer deaths.

More intensive screening strategies resulted in lower percentages of cases diagnosed in advanced stages. The percentage of cases diagnosed in advanced stages was slightly lower for DBT compared with DM for the same strategy (Figure 12); for example, for biennial screening at ages 50–74, 27.4% (range, 26.2% to 31.2%) of Black breast cancer cases were diagnosed in an advanced stage with DM, while 25.4% (range, 25.0% to 29.7%) of cases were advanced at diagnosis with DBT.

Figure 12 Percent of Invasive Breast Cancer Cases Diagnosed in Advanced AJCC Version 6 Stages IIB, III, and IV Combined for a Cohort of 1,000 40-Year-Old Black Female Persons by Model and Screening Strategy

Note: Figure limited to the three models (D, GE, M) of breast cancer in Black female persons with AJCC stage for breast cancer cases.

Dot plot of the percent of breast cancer cases diagnosed in advanced stages for three CISNET models and 36 screening strategies for Black female persons. Generally fewer cases were diagnosed in advanced stages for more intensive screening strategies.

### Disparities in Outcomes for Black Compared With All Female Persons

Compared to corresponding values for each screening strategy among all female persons, quantities for two harm-to-benefit ratios (false-positive recalls per breast cancer death averted and the number of mammograms per breast cancer death averted) were lower for Black female persons (Appendix Table 12). For example, for biennial screening at ages 50–74, models estimated 132.8 (range across models, 95.6 to 166.5) false-positive recalls per breast cancer death averted for all female persons and 90.3 (range, 64.7 to 115.0) for Black female persons. Corresponding results for the number of mammograms per breast cancer death averted (also referred to as the “number needed to screen”) were 1,709 (range, 1,228 to 2,137) for all female persons and 1,209 (range, 869 to 1,539) for Black female persons for biennial screening at ages 50–74. Values for the number of mammograms to obtain a 1 percentage point reduction in breast cancer mortality for Black female persons were similar to values for female persons overall for each screening strategy.

Using a fourth ratio—LYG per mammogram (times 1,000)—as a measure of benefit-to-harm showed that two of the four models (D and W) resulted in B50-74 with the highest value of LYG/mammogram among the efficient strategies; all four models found that A40-79 had the lowest values among all efficient strategies (Figure 13). All four models estimated higher values for Black female persons as compared with female persons overall for each screening strategy. Thus, several of the efficient strategies resulted in greater values of this ratio for Black female persons than observed for B50-74 as well as B40-74 for all female persons; all four models found greater values of LYG/mammogram for B45-79 and B40-79 among Black female persons compared with the values for B50-74 and B40-74 among female persons overall.

Figure 13 Benefit-to-Harm Measured as Life-Years Gained per Mammogram (Times 1,000) From Four Models of All Female Persons and Black Female Persons According to Screening Strategy

Abbreviations: A, annual; B, biennial; LYG, life-years gained.

Note: Limited to efficient or near-efficient strategies among most models along with biennial screening during ages 40–74. All strategies use digital breast tomosynthesis. Green shading indicates strategies for Black female persons with greater values of LYG/mammogram than for biennial screening at ages 40–74 (light blue triangle) or 50–74 (green line) among female persons overall.

Dot plot of life-years gained per mammogram for 6 screening strategies and 4 CISNET models, comparing results for all versus Black female persons. In general, life-years gained per mammogram were higher for the same strategy for Black female persons than for female persons overall.

If all female persons receive the same screening strategy (with perfect adherence), models estimate that Black female persons will have 41% to 43% greater breast cancer mortality than the average population (Table 18; limited to strategies found to be efficient or near-efficient for female persons overall; see table cells with grey shading). However, if Black female persons are screened with a more-intensive strategy such as B45-79 and female persons overall are screened with B50-74 (both with DBT), then the elevated breast cancer mortality rate for Black female persons would be reduced from 42% to 30% higher than for female persons overall.

Table 18 Ratios of Breast Cancer Deaths and Life-Years in a Cohort of 1,000 Black Female Persons vs. a Cohort of 1,000 Female Persons Overall by Digital Breast Tomosynthesis Screening Strategy

Screening Strategy^a^ | All Female Persons | Screening Strategies for Black Female Persons
Screening Strategy^a^ | All Female Persons | No screening | B50-74^c^ | B40-74^c^ | A40-49, B50-74^c^ | B45-79 | B40-79 | A40-49, B50-79^c^ | A40-74^c^ | A40-79
Breast Cancer Deaths | | 39.3 | 30.0 | 28.8 | 28.3 | 27.5 | 27.3 | 26.8 | 26.0 | 23.7
No screening | 28.3 | 1.39 | 1.06 | 1.02 | 1.00 | 0.97 | 0.97 | 0.95 | 0.92 | 0.84
B50-74 | 21.1 | 1.86 | 1.42 | 1.36 | 1.34 | 1.30 | 1.29 | 1.27 | 1.23 | 1.12
B40-74^b^ | 20.0 | 1.97 | 1.50 | 1.44 | 1.42 | 1.38 | 1.37 | 1.34 | 1.30 | 1.19
A40-49, B50-74^b^ | 19.6 | 2.01 | 1.53 | 1.47 | 1.44 | 1.41 | 1.39 | 1.37 | 1.33 | 1.21
B45-79 | 19.4 | 2.03 | 1.55 | 1.48 | 1.46 | 1.42 | 1.41 | 1.39 | 1.34 | 1.23
B40-79 | 19.1 | 2.05 | 1.57 | 1.50 | 1.48 | 1.44 | 1.43 | 1.40 | 1.36 | 1.24
A40-49, B50-79 | 18.7 | 2.10 | 1.60 | 1.53 | 1.51 | 1.47 | 1.46 | 1.43 | 1.39 | 1.27
A40-74^b^ | 18.2 | 2.16 | 1.65 | 1.58 | 1.55 | 1.51 | 1.50 | 1.47 | 1.43 | 1.30
A40-79 | 16.9 | 2.33 | 1.78 | 1.71 | 1.68 | 1.63 | 1.62 | 1.59 | 1.54 | 1.41
| | No screening | B50-74^c^ | B45-79 | B40-74^c^ | B40-79 | A40-49, B50-74^c^ | A40-49, B50-79^c^ | A40-74^c^ | A40-79
Life-Years | | 41.783 | 41.994 | 42.058 | 42.063 | 42.080 | 42.080 | 42.097 | 42.116 | 42.139
No screening | 43.670 | 0.957 | 0.962 | 0.963 | 0.963 | 0.964 | 0.964 | 0.964 | 0.964 | 0.965
B50-74 | 43.789 | 0.954 | 0.959 | 0.960 | 0.961 | 0.961 | 0.961 | 0.961 | 0.962 | 0.962
B45-79 | 43.850 | 0.953 | 0.958 | 0.959 | 0.959 | 0.960 | 0.960 | 0.960 | 0.960 | 0.961
B40-74^b^ | 43.866 | 0.953 | 0.957 | 0.959 | 0.959 | 0.959 | 0.959 | 0.960 | 0.960 | 0.961
B40-79 | 43.879 | 0.952 | 0.957 | 0.959 | 0.959 | 0.959 | 0.959 | 0.959 | 0.960 | 0.960
A40-49, B50-74^b^ | 43.882 | 0.952 | 0.957 | 0.958 | 0.959 | 0.959 | 0.959 | 0.959 | 0.960 | 0.960
A40-49, B50-79 | 43.897 | 0.952 | 0.957 | 0.958 | 0.958 | 0.959 | 0.959 | 0.959 | 0.959 | 0.960
A40-74^b^ | 43.907 | 0.952 | 0.956 | 0.958 | 0.958 | 0.958 | 0.958 | 0.959 | 0.959 | 0.960
A40-79 | 43.927 | 0.951 | 0.956 | 0.957 | 0.958 | 0.958 | 0.958 | 0.958 | 0.959 | 0.959

a Calculations use the median values for breast cancer deaths from four models (D, GE, M, and W). Strategies limited to efficient and near-efficient strategies for both percent breast cancer mortality reduction and life-years gained versus no screening in most models for all female persons, listed in Table 10, along with selected other strategies.

b Not efficient or near-efficient for both breast cancer mortality reduction and life-years gained versus no screening in most models for all female persons.

c Strategy not efficient nor near-efficient for both breast cancer mortality reduction and life-years gained versus no screening in at least 3 of 4 models for Black female persons, as shown in Table 17.

## Question 3 Trade-Offs of Density-Specific Screening Strategies

Screening strategies were evaluated by five models for separate cohorts of female persons overall and four models for Black female persons assigned one of the four breast density categories at age 40. For all four density levels among female persons overall, two DBT screening strategies were efficient or near-efficient for both primary metrics in most models, including B40-79 and A40-79 (Table 19, Figure 14, Figure 15). Additional strategies were efficient or near-efficient for both metrics in most models for density a (B50-79, B45-79), density b (B50-74, B50-79, B45-79, and hybrid A40-49 with B50-79), density c (B50-74, B45-79, and hybrid A40-49 with B50-79), and density d (B50-74). For Black female persons, two screening strategies were efficient or near-efficient for all four density levels (B45-79 and A40-79), with B50-79 efficient for density a and b; B40-79 efficient for density b, c, and d; and A45-79 efficient for density a. Regardless of density level, strategies that started screening at age 40 or included annual screening required more than 1,000 additional mammograms to reduce breast cancer mortality by another 1 percentage point compared to the next less efficient strategy with fewer mammograms.

Table 19 Range of Incremental Ratios of Breast Cancer Mortality (Change in the Number of Mammograms/Change in Percent Breast Cancer Mortality Reduction) and Life-Years Gained (Change in the Number of Mammograms/Change in LYG) Across Models for a Cohort of 1,000 40-Year-Old Female Persons According to Efficient Digital Breast Tomosynthesis Screening Strategies and Breast Density

Strategy^a^ | Δ mammograms / Δ % mortality reduction | | | | Δ mammograms / Δ LYG
Strategy^a^ | Almost entirely fatty | Scattered fibroglandular | Hetero-geneously dense | Extremely dense | Almost entirely fatty | Scattered fibro-glandular | Hetero-geneously dense | Extremely dense
All Female Persons
DBT B50-74 | ^b^ | 374-541 | 385-532 | 395-544 | 108-163 | 78-115 | 59-88 | 50-79
DBT B50-79 | 390-493 | 418-513 | 463-511 | 481-550 | 193-326 | 111-202 | ^b^ | ^b^
DBT B45-79 | 483-1,021 | 460-881 | 476-936 | 487-984 | 119-331 | 82-223 | 71-192 | ^b^
DBT B40-79 | 2,426-25,253 | 1,228-3,867 | 817-3,283 | 660-2,787 | 194-680 | 95-257 | 69-2,819 | 59-325
DBT A40-49, B50-79 | ^b^ | 2,733-7,619 | 2,260-8,922 | ^b^ | 371-1,897 | 250-958 | 190-644 | 139-580
DBT A40-79 | 2,290-3,783 | 1,875-3,575 | 1,771-3,644 | 1,584-3,705 | 470-1,676 | 269-817 | 204-599 | 166-507
Black Female Persons
DBT B50-79 | 354-468 | 376-493 | 401-497 | 406-513 | 78-140 | 55-101 | ^b^ | ^b^
DBT B45-79 | 623-1,221 | 569-1,087 | 483-1,133 | 491-1,185 | 92-220 | 54-126 | 52-100 | 45-88
DBT B40-79 | ^b^ | 1,183-8,269 | 725-2,834 | 670-2,619 | 194-330 | 113-140 | 74-126 | 61-249
DBT A45-79 | 2,077-3,762 | 1,938-3,317 | 1,759-3,377 | 1,559-3,229 | 283-1,587 | ^b^ | ^b^ | ^b^
DBT A40-79 | 3,077-4,037 | 2,583-3,289 | 1,934-3,125 | 1,875-3,176 | 408-857 | 231-507 | 161-417 | 143-327

Abbreviations: A, annual; B, biennial; DBT, digital breast tomosynthesis.

a Results shown for five models (D, E, GE, M, and W) for female persons overall and four models (D, GE, M, and W) for Black female persons. DBT strategies are shown that were efficient or near-efficient in at least 4 of 5 models for both incremental ratios within a density category for female persons overall, and at least 3 of 4 models for both incremental ratios within a density category of breast cancer in Black female persons. Density-specific strategies were not evaluated for digital mammography. A strategy is classified as more efficient than a comparison strategy if it resulted in greater health benefits for a given increase in the number of mammograms (or other harm). Strategies were considered near-efficient if they were within 2.2 days per person for LYG and 1.27 percentage points for percent breast cancer mortality reduction of the efficient frontier for all female persons, and within 3.2 days per person for LYG and 1.21 percentage points for percent breast cancer mortality reduction of the efficient frontier for Black female persons. Strategies are ranked from the least to the most mammograms. Ratios for each strategy are calculated relative to the next efficient or near-efficient strategy with fewer mammograms, not necessarily shown in the table (varied across models). The ratio for the strategy with the fewest number of mammograms (B50-74) is calculated relative to no screening.

b DBT strategies that were efficient or near-efficient in fewer than 4 of 5 models within a density category for all female persons, or fewer than 3 of 4 models of breast cancer in Black female persons.

Table 20 Median (and Range) of Benefits and Harms Across Five Models of Efficient Screening Strategies With Digital Breast Tomosynthesis for a Cohort of 1,000 40-Year-Old Female Persons According to Breast Density and Screening Strategy

BI-RADS Breast Density | Strategy | Mortality Reduction (%) | Breast Cancer Deaths Averted | Life-Years Gained | QALYs Gained^a^
Almost entirely fatty | B50-74 | 25.9 (21.6-33.0) | 4.9 (3.1-5.7) | 82.6 (70.1-107.5) | 58.8 (46.1-89.5)
Almost entirely fatty | B50-79 | 30.8 (25.8-36.5) | 5.6 (3.7-6.5) | 88.7 (76.9-113.3) | 62.8 (50.3-94.7)
Almost entirely fatty | B45-79 | 34.2 (28.5-39.3) | 6.2 (4.1-7.8) | 99.7 (87.5-132.1) | 70.4 (57.1-104.0)
Almost entirely fatty | B40-79 | 34.9 (28.8-39.8) | 6.4 (4.2-7.9) | 108.5 (94.4-143.3) | 76.5 (61.4-108.9)
Almost entirely fatty | A40-49, B50-79 | 35.6 (30.2-40.3) | 6.9 (4.4-8.1) | 120.3 (103.0-151.0) | 84.1 (66.8-109.5)
Almost entirely fatty | A40-79 | 42.6 (40.1-46.1) | 7.6 (5.9-9.7) | 143.6 (120.9-173.1) | 99.3 (81.3-122.8)
Scattered fibroglandular | B50-74 | 26.3 (20.5-30.5) | 6.7 (4.3-7.7) | 106.2 (97.5-146.6) | 75.7 (64.7-119.3)
Scattered fibroglandular | B50-79 | 29.2 (24.3-33.6) | 7.4 (5.1-8.9) | 113.2 (106.0-153.9) | 80.0 (70.1-125.7)
Scattered fibroglandular | B45-79 | 33.6 (27.3-36.7) | 8.3 (5.7-11.1) | 134.2 (125.1-188.7) | 94.6 (82.5-141.4)
Scattered fibroglandular | B40-79 | 34.4 (27.9-37.5) | 8.6 (5.9-11.3) | 150.2 (136.6-211.6) | 105.4 (89.7-154.0)
Scattered fibroglandular | A40-49, B50-79 | 36.6 (29.7-38.2) | 9.4 (6.3-11.8) | 167.8 (152.8-225.6) | 116.2 (99.7-162.5)
Scattered fibroglandular | A40-79 | 42.4 (40.0-45.0) | 10.7 (8.4-14.2) | 200.1 (175.5-259.1) | 137.0 (117.5-184)
Hetero-geneously dense | B50-74 | 25.3 (18.3-29.1) | 7.2 (5.6-9.9) | 126.6 (114.9-189.8) | 90.6 (80.8-154.0)
Hetero-geneously dense | B50-79 | 27.8 (23.6-31.8) | 8.7 (6.4-10.8) | 135.6 (131.7-198.6) | 95.4 (90.6-161.6)
Hetero-geneously dense | B45-79 | 32.0 (26.5-35.4) | 9.7 (7.2-12.5) | 169.7 (158.1-232.4) | 119.9 (106.3-187.4)
Hetero-geneously dense | B40-79 | 33.5 (27.5-36.6) | 10.0 (7.5-13.1) | 199.8 (169.9-252.5) | 141.4 (116.8-201.6)
Hetero-geneously dense | A40-49, B50-79 | 35.6 (29.6-37.3) | 10.9 (8.1-14.0) | 210.9 (193.5-277.0) | 146.6 (132.5-204.1)
Hetero-geneously dense | A40-79 | 42.0 (39.3-43.1) | 13.4 (10.4-16.9) | 257.5 (234.0-319.3) | 170.1 (159.1-227.2)
Extremely dense | B50-74 | 23.5 (17.7-27.9) | 8.3 (6.4-11.4) | 143.3 (132.1-218.9) | 99.7 (94.2-177.9)
Extremely dense | B50-79 | 25.7 (22.6-30.4) | 9.4 (7.3-12.4) | 155.2 (144.9-228.6) | 110.9 (104.0-186.2)
Extremely dense | B45-79 | 30.8 (25.2-33.6) | 10.5 (8.2-14.5) | 194.3 (171.7-264.6) | 139.2 (122.4-214.0)
Extremely dense | B40-79 | 32.4 (26.1-36.5) | 10.8 (8.4-15.2) | 241.5 (185.3-292.4) | 174.6 (130.9-229.3)
Extremely dense | A40-49, B50-79 | 34.8 (28.5-37.9) | 11.9 (9.2-16.4) | 254.6 (213.3-327.4) | 181.3 (148.4-239.9)
Extremely dense | A40-79 | 39.9 (38.0-43.0) | 14.6 (12.3-20.2) | 297.1 (256.8-385.8) | 200.9 (177.1-279.9)
| Strategy | Screens^b^ | False-Positive Recalls | Benign Biopsies | Overdiagnosed Cases^c^
Almost entirely fatty | B50-74 | 11,499 (11,410-11,630) | 523 (519-528) | 84 (84-85) | 8 (4-22)
Almost entirely fatty | B50-79 | 12,849 (12,724-13,004) | 568 (563-575) | 92 (91-93) | 10 (5-26)
Almost entirely fatty | B45-79 | 15,604 (15,464-15,788) | 675 (669-682) | 104 (103-105) | 11 (5-29)
Almost entirely fatty | B40-79 | 17,765 (17,634-17,966) | 785 (780-793) | 116 (115-117) | 11 (5-29)
Almost entirely fatty | A40-49, B50-79 | 22,675 (22,548-22,918) | 899 (893-908) | 124 (124-126) | 16 (5-29)
Almost entirely fatty | A40-79 | 35,273 (34,914-35,685) | 1,130 (1,120-1,143) | 148 (146-149) | 17 (6-36)
Scattered fibroglandular | B50-74 | 13,391 (13,244-13,533) | 788 (780-797) | 116 (114-117) | 11 (4-27)
Scattered fibroglandular | B50-79 | 12,601 (12,430-12,751) | 849 (840-859) | 124 (122-125) | 13 (6-32)
Scattered fibroglandular | B45-79 | 15,324 (15,125-15,508) | 1,057 (1,042-1,068) | 145 (144-147) | 14 (7-35)
Scattered fibroglandular | B40-79 | 17,495 (17,293-17,697) | 1,269 (1,255-1,282) | 166 (164-167) | 15 (6-36)
Scattered fibroglandular | A40-49, B50-79 | 22,370 (22,160-22,630) | 1,521 (1,508-1,540) | 192 (191-194) | 21 (6-37)
Scattered fibroglandular | A40-79 | 34,675 (34,111-35,102) | 1,929 (1,907-1,954) | 240 (237-243) | 22 (7-49)
Hetero-geneously dense | B50-74 | 11,129 (10,882-11,214) | 940 (919-946) | 148 (144-148) | 13 (5-36)
Hetero-geneously dense | B50-79 | 12,377 (12,081-12,491) | 1,007 (983-1,013) | 157 (153-157) | 15 (6-41)
Hetero-geneously dense | B45-79 | 15,084 (14,751-15,223) | 1,282 (1,257-1,291) | 195 (191-196) | 17 (7-45)
Hetero-geneously dense | B40-79 | 17,261 (16,915-17,408) | 1,583 (1,556-1,595) | 234 (230-236) | 17 (6-46)
Hetero-geneously dense | A40-49, B50-79 | 22,059 (21,730-22,317) | 1,946 (1,920-1,967) | 278 (275-281) | 26 (7-48)
Hetero-geneously dense | A40-79 | 34,070 (33,265-34,481) | 2,456 (2,408-2,482) | 343 (336-346) | 27 (8-61)
Extremely dense | B50-74 | 10,981 (10,695-11,031) | 955 (931-958) | 161 (157-162) | 14 (5-38)
Extremely dense | B50-79 | 12,196 (11,851-12,276) | 1,024 (994-1,025) | 170 (166-170) | 17 (7-44)
Extremely dense | B45-79 | 14,883 (14,489-14,989) | 1,257 (1,223-1,276) | 208 (203-209) | 19 (7-48)
Extremely dense | B40-79 | 17,059 (16,663-17,180) | 1,566 (1,528-1,570) | 258 (253-260) | 20 (7-49)
Extremely dense | A40-49, B50-79 | 21,820 (21,445-22,057) | 1,915 (1,871-1,921) | 300 (295-303) | 29 (7-52)
Extremely dense | A40-79 | 33,623 (32,677-33,989) | 2,452 (2,374-2,461) | 369 (358-370) | 31 (9-66)

Abbreviations: a=almost entirely fatty; A=annual; b= scattered areas of fibroglandular density; B=biennial; BI-RADS=Breast Imaging-Reporting and Data System; c= heterogeneously dense; d=extremely dense.

a Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

b As risk increases, more persons develop and die of breast cancer, therefore the number of lifetime screening mammograms decreases.

c Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario.

Table 21 Median (and Range) of Benefits and Harms Across Four Models of Efficient Screening Strategies With Digital Breast Tomosynthesis for a Cohort of 1,000 40-Year-Old Black Female Persons According to Breast Density and Screening Strategy

BI-RADS Breast Density | Strategy | Mortality Reduction (%) | Breast Cancer Deaths Averted | Life-Years Gained | QALYs Gained^a^
Almost entirely fatty | B50-79 | 30.7 (26.4-35.2) | 7.0 (5.9-10.2) | 124.0 (106.6-163.7) | 92.9 (75.1-122.5)
Almost entirely fatty | B45-79 | 34.4 (28.6-38.5) | 7.6 (6.6-11.5) | 140.2 (120.7-193.4) | 105.8 (83.6-145.2)
Almost entirely fatty | B40-79 | 35.1 (28.5-38.6) | 7.8 (6.6-11.5) | 150.4 (127.3-202.3) | 113.6 (88.1-151.8)
Almost entirely fatty | A45-79 | 41.5 (35.1-45.4) | 9.5 (7.6-13.6) | 175.9 (136.9-228.1) | 127.8 (97.5-169.4)
Almost entirely fatty | A40-79 | 42.9 (37.4-47.0) | 9.8 (8.1-14.1) | 188.1 (156.0-244.3) | 136.2 (111.4-181.0)
Scattered fibroglandular | B50-79 | 29.1 (24.5-32.5) | 9.7 (7.4-14.5) | 172.6 (133.2-233.4) | 127.3 (95.9-174.1)
Scattered fibroglandular | B45-79 | 32.7 (27.0-37.3) | 10.6 (8.6-16.6) | 196.9 (163.8-283.4) | 145.0 (118.1-212.1)
Scattered fibroglandular | B40-79 | 34.0 (27.1-37.5) | 10.8 (9.1-16.7) | 214.9 (183.2-302.6) | 161.3 (126.2-226.2)
Scattered fibroglandular | A45-79 | 39.3 (35.2-44.5) | 13.4 (10.0-19.8) | 253.6 (186.4-339.3) | 183.1 (130.6-250.9)
Scattered fibroglandular | A40-79 | 40.9 (38.3-46.4) | 14.0 (10.9-20.7) | 274.8 (226.5-368.7) | 197.3 (159.8-271.7)
Hetero-geneously dense | B50-79 | 26.7 (23.8-30.0) | 11.7 (8.4-15.6) | 209.9 (156.1-252.1) | 154.4 (111.4-186.7)
Hetero-geneously dense | B45-79 | 30.6 (26.2-35.6) | 12.9 (9.9-18.5) | 242.8 (191.2-324.5) | 178.2 (136.9-241.5)
Hetero-geneously dense | B40-79 | 32.6 (26.6-36.4) | 13.2 (11.0-18.9) | 267.0 (229.5-354.3) | 199.3 (157.1-263.3)
Hetero-geneously dense | A45-79 | 37.2 (33.5-43.4) | 16.3 (11.6-22.6) | 313.9 (222.4-398.1) | 225.8 (153.9-292.5)
Hetero-geneously dense | A40-79 | 39.0 (37.6-46) | 17.1 (13.0-23.9) | 343.7 (277.6-443.6) | 245.1 (193.8-324.5)
Extremely dense | B50-79 | 25.6 (22.7-29.1) | 13.0 (9.8-18.0) | 234.0 (181.1-294.2) | 172.9 (129.8-218.6)
Extremely dense | B45-79 | 29.4 (25.0-34.5) | 14.3 (11.7-21.4) | 269.1 (225.9-378.4) | 198.8 (163.2-283.2)
Extremely dense | B40-79 | 31.5 (25.3-35.4) | 14.7 (12.9-21.9) | 304.9 (257.6-414.8) | 229.5 (178.0-310.1)
Extremely dense | A45-79 | 35.2 (33.5-43.3) | 18.3 (13.5-26.8) | 352.5 (260.0-478.4) | 255.4 (181.7-354.4)
Extremely dense | A40-79 | 38.0 (35.8-45.9) | 19.2 (15.4-28.4) | 385.4 (336.8-533.4) | 277.3 (238.7-394.0)
| | Screens^b^ | False-Positive Recalls | Benign Biopsies | Overdiagnosed Cases^c^
Almost entirely fatty | B50-79 | 12,459 (12,363-12,489) | 435 (432-437) | 105 (104-105) | 12 (6-24)
Almost entirely fatty | B45-79 | 15,189 (15,077-15,229) | 510 (506-511) | 120 (119-121) | 13 (6-26)
Almost entirely fatty | B40-79 | 17,386 (17,272-17,439) | 575 (571-577) | 133 (132-133) | 13 (6-26)
Almost entirely fatty | A45-79 | 29,534 (29,265-29,618) | 718 (711-720) | 137 (135-137) | 15 (7-31)
Almost entirely fatty | A40-79 | 34,486 (34,191-34,592) | 833 (825-835) | 154 (153-155) | 15 (7-32)
Scattered fibroglandular | B50-79 | 12,206 (12,109-12,217) | 776 (773-781) | 149 (149-150) | 17 (7-29)
Scattered fibroglandular | B45-79 | 14,908 (14,785-14,931) | 947 (942-953) | 175 (175-177) | 18 (7-32)
Scattered fibroglandular | B40-79 | 17,113 (16,979-17,150) | 1,107 (1,101-1,114) | 200 (199-201) | 18 (7-32)
Scattered fibroglandular | A45-79 | 28,955 (28,613-28,997) | 1,412 (1,404-1,424) | 223 (222-225) | 21 (8-43)
Scattered fibroglandular | A40-79 | 33,894 (33,497-33,962) | 1,696 (1,685-1,709) | 260 (258-262) | 22 (9-44)
Hetero-geneously dense | B50-79 | 11,964 (11,828-12,021) | 1,003 (996-1,011) | 192 (190-193) | 20 (7-38)
Hetero-geneously dense | B45-79 | 14,631 (14,482-14,714) | 1,284 (1,264-1,292) | 241 (237-242) | 22 (8-41)
Hetero-geneously dense | B40-79 | 16,844 (16,671-16,928) | 1,561 (1,543-1,570) | 289 (285-291) | 22 (7-41)
Hetero-geneously dense | A45-79 | 28,390 (27,972-28,553) | 1,969 (1,938-1,989) | 315 (309-318) | 26 (9-52)
Hetero-geneously dense | A40-79 | 33,314 (32,816-33,491) | 2,465 (2,434-2,487) | 386 (381-390) | 27 (9-54)
Extremely dense | B50-79 | 11,741 (11,633-11,822) | 1,105 (1,093-1,126) | 207 (205-211) | 23 (8-40)
Extremely dense | B45-79 | 14,385 (14,260-14,498) | 1,344 (1,329-1,373) | 246 (243-252) | 26 (8-44)
Extremely dense | B40-79 | 16,604 (16,455-16,717) | 1,640 (1,620-1,648) | 299 (295-301) | 26 (8-44)
Extremely dense | A45-79 | 27,886 (27,489-28,108) | 2,114 (2,077-2,150) | 318 (313-328) | 31 (10-57)
Extremely dense | A40-79 | 32,800 (32,317-33,037) | 2,618 (2,572-2,634) | 387 (380-393) | 32 (10-60)

Abbreviations: a=almost entirely fatty; A=annual; b= scattered areas of fibroglandular density; B=biennial; BI-RADS=Breast Imaging-Reporting and Data System; c= heterogeneously dense; d=extremely dense.

Results shown from four models (D, GE, M, and W).

a Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

b As risk increases, more persons develop and die of breast cancer, therefore the number of lifetime screening mammograms decreases.

c Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario.

Figure 14 Efficiency Frontiers for the Estimated Lifetime Number of Mammograms and Life-Years Gained for a Cohort of 1,000 Female Persons by Breast Density Category and Screening Strategy With Digital Breast Tomosynthesis Using Exemplar Model W

Dot plots of life-years gained by the number of mammograms for 18 mammography screening strategies based on Model W for female persons overall. Four panels are shown, one for each breast density category. In general, life-years gained increases with greater numbers of mammograms and breast density level.

Figure 15 Efficiency Frontiers for the Estimated Lifetime Number of Mammograms and Life-Years Gained for a Cohort of 1,000 Black Female Persons by Breast Density Category and Screening Strategy With Digital Breast Tomosynthesis Using Exemplar Model W

Dot plots of life-years gained by the number of mammograms for 18 mammography screening strategies based on Model W for Black female persons. Four panels are shown, one for each breast density category. In general, life-years gained increases with greater numbers of mammograms and breast density level.

Since greater breast density across categories a, b, c, and d was associated with greater breast cancer risk and lower mammography sensitivity, screening female persons with more dense breasts was associated with slightly lower percent mortality reduction, more breast cancer deaths averted, up to twice as many LYG, but up to twice as many false-positive recalls (limited to efficient and near-efficient strategies).

## Question 4 Trade-Offs of Screening Strategies for Persons With Elevated Risk

Since many female persons have modestly increased risk of breast cancer based on common risk factors, such as a first-degree family history of breast cancer, DBT strategies were evaluated assuming a relative breast cancer risk of 1.5 and 2.0. For the most part, the same DBT strategies were efficient or near-efficient for both relative risk levels (Table 22). For female persons overall with relative risk of 1.5, four strategies were efficient or near-efficient for both breast cancer mortality reduction and LYG metrics: B50-74, B45-79, B40-79, and A40-79. For relative risk of 2.0, three of these were also efficient or near-efficient (B50-74, B40-79, and A40-79), along with one hybrid strategy (A40-49 with B50-79) (Figure 16). For Black female persons, the same three strategies were efficient or near-efficient for both relative risk levels (B45-79, B40-79, and A40-79) (Figure 17).

Table 22 Range of Incremental Ratios for Breast Cancer Mortality (Change in the Number of Mammograms/Change in Percent Breast Cancer Mortality Reduction) and Life-Years Gained (Change in the Number of Mammograms/Change in LYG) Across Six Models for a Cohort of 1,000 40-Year-Old Female Persons According to Efficient Digital Breast Tomosynthesis Screening Strategies and Elevated Relative Risk

DBT Strategy^a^ | Δ mammograms / Δ % mortality reduction | | Δ mammograms / Δ LYG
DBT Strategy^a^ | RR 1.5 | RR 2.0 | RR 1.5 | RR 2.0
All Female Persons
B50-74 | 374-493 | 364-454 | 43-65 | 32-50
B45-79 | 455-854 | 438-832 | 49-144 | ^b^
B40-79 | 821-3,512 | 921-2,009 | 49-237 | 37-118
A40-49, B50-79 | ^b^ | 2,285-7,161 | 143-497 | 108-377
A40-79 | 1,740-3,584 | 1,687-3,518 | 142-439 | 106-535
Black Female Persons
B45-79 | 497-1,081 | 481-1,028 | 36-74 | 27-55
B40-79 | 829-3,423 | 805-2,961 | 60-99 | 45-68
A40-79 | 2,044-3,129 | 1,958-3,058 | 125-313 | 92-216

Abbreviations: A, annual; B, biennial; DBT, digital breast tomosynthesis; RR, relative risk.

a Results shown for five models (D, E, GE, M, and W) for female persons overall and four models (D, GE, M, and W) for Black female persons. DBT strategies are shown that were efficient or near-efficient in at least 4 of 5 models for both incremental ratios within a relative risk category for female persons overall, and at least 3 of 4 models for both incremental ratios within a relative risk category of breast cancer in Black female persons. Relative risk-specific strategies were not evaluated for digital mammography. A strategy is classified as more efficient than a comparison strategy if it resulted in greater health benefits for a given increase in the number of mammograms (or other harm). Strategies were considered near-efficient if they were within 2.2 days per person for LYG and 1.27 percentage points for percent breast cancer mortality reduction of the efficient frontier for all female persons, and within 3.2 days per person for LYG and 1.21 percentage points for percent breast cancer mortality reduction of the efficient frontier for Black female persons. Strategies are ranked from the least to the most mammograms. Ratios for each strategy are calculated relative to the next efficient or near-efficient strategy with fewer mammograms, not necessarily shown in the table (varied across models). The ratio for the strategy with the fewest number of mammograms (B50-74) is calculated relative to no screening.

b DBT strategies that were efficient or near-efficient in fewer than 4 of 5 models within a relative risk category for all female persons, or fewer than 3 of 4 models within a relative risk category of breast cancer for Black female persons.

Figure 16 Efficiency Frontiers for the Estimated Lifetime Number of Mammograms and Life-Years Gained for a Cohort of 1,000 Female Persons by Relative Risk (RR) of Breast Cancer and Screening Strategy With Digital Breast Tomosynthesis Using Exemplar Model W

Dot plots of life-years gained by the number of mammograms for 18 mammography screening strategies based on Model W for female persons overall. Three panels are shown, one for different levels of relative risk including 1.0, 1.5, and 2.0. In general, life-years gained increases with greater numbers of mammograms and higher relative risk level.

Figure 17 Efficiency Frontiers for the Estimated Lifetime Number of Mammograms and Life-Years Gained for a Cohort of 1,000 Black Female Persons by Relative Risk (RR) of Breast Cancer and Screening Strategy With Digital Breast Tomosynthesis Using Exemplar Model W

Dot plots of life-years gained by the number of mammograms for 18 mammography screening strategies based on Model W for Black female persons. Three panels are shown, one for different levels of relative risk including 1.0, 1.5, and 2.0. In general, life-years gained increases with greater numbers of mammograms and higher relative risk level.

Models predicted that female persons overall (Table 23) and Black female persons (Table 24) with elevated relative risk would experience similar percent breast cancer mortality reduction with greater breast cancer deaths averted and more LYG compared to persons with average risk when screened with the same strategy; the number of false-positive recalls was slightly smaller for female persons with elevated risk.

Table 23 Median (and Range) of Lifetime Benefits and Harms Across Six Models of Screening With Digital Breast Tomosynthesis vs. No Screening for a Cohort of 1,000 40-Year-Old Female Persons According to Relative Risk Group and Efficient or Near-Efficient Screening Strategy

Relative Risk Group | Strategy | Mortality Reduction (%) | Breast Cancer Deaths Averted | Life-Years Gained | QALYs Gained^a^
1 (average) | B50-74 | 25.4 (18.8-29.4) | 6.7 (5.1-9.2) | 120.8 (115.1-175.8) | 86.1 (77.9-143.0)
1 (average) | B45-79 | 32.1 (26.5-35.5) | 8.6 (6.7-12.1) | 153.4 (147.7-213.1) | 110.2 (98.5-172.1)
1 (average) | B40-79 | 33.3 (27.2-36.5) | 8.9 (6.9-12.5) | 173.9 (161.7-237.8) | 124.2 (107.2-184.2)
1 (average) | A40-49, B50-79 | 35.3 (29.4-37.2) | 9.5 (7.4-13.3) | 188.7 (173.4-260.1) | 130.7 (121.4-188.1)
1 (average) | A40-79 | 41.7 (39.2-43.0) | 11.5 (9.9-16.1) | 229.7 (200.4-300.7) | 154.3 (139.5-214.6)
1.5 | B50-74 | 25.2 (19.2-29.3) | 9.2 (7.7-10.5) | 172.4 (167.1-256.5) | 127.0 (120.5-212.5)
1.5 | B45-79 | 32.2 (27.7-35.4) | 12.4 (10.0-17.6) | 225.7 (209.0-311.0) | 164.0 (152.4-256.6)
1.5 | B40-79 | 33.4 (28.5-37.1) | 13.0 (10.3-18.3) | 257.4 (218.3-348.7) | 185.1 (162.9-275.8)
1.5 | A40-49, B50-79 | 35.8 (30.8-38.2) | 13.8 (11.1-19.4) | 281.1 (243.2-382.0) | 200.0 (179.5-284.5)
1.5 | A40-79 | 42.2 (40.7-43.5) | 16.5 (14.7-23.5) | 336.5 (290.2-441.2) | 237.4 (212.6-325.8)
2.0 | B50-74 | 25.6 (19.5-29.2) | 12.5 (10.3-13.4) | 220.6 (211.7-332.6) | 162.9 (158.8-278.0)
2.0 | B45-79 | 32.4 (28.6-35.4) | 15.8 (13.1-22.7) | 294.5 (264.3-403.7) | 215.4 (197.3-336.4)
2.0 | B40-79 | 33.8 (29.8-37.8) | 16.7 (13.7-23.7) | 337.9 (292.1-451.4) | 248.7 (217.1-362.8)
2.0 | A40-49, B50-79 | 36.4 (32.2-39.2) | 17.8 (14.8-25.1) | 369.9 (306.5-495.5) | 269.3 (231.9-374.6)
2.0 | A40-79 | 43.0 (40.5-44.3) | 21.2 (19.3-30.3) | 433.2 (363.9-570.9) | 313.0 (273.7-428.7)
| Strategy | Screens^b^ | False-Positive Recalls | Benign Biopsies | Overdiagnosed Cases^c^
1 (average) | B50-74 | 11,208 (10,976-11,278) | 873 (855-878) | 136 (133-137) | 12 (4-33)
1 (average) | B45-79 | 15,218 (14,871-15,297) | 1,176 (1,153-1,183) | 176 (173-177) | 16 (6-41)
1 (average) | B40-79 | 17,397 (17,037-17,494) | 1,440 (1,415-1,449) | 210 (206-211) | 17 (6-42)
1 (average) | A40-49, B50-79 | 22,255 (21,870-22,412) | 1,755 (1,728-1,768) | 247 (242-248) | 24 (6-44)
1 (average) | A40-79 | 34,441 (33,538-34,666) | 2,224 (2,175-2,240) | 304 (298-307) | 25 (7-56)
1.5 | B50-74 | 10,888 (10,570-10,952) | 848 (824-853) | 132 (129-133) | 14 (2-45)
1.5 | B45-79 | 14,779 (14,306-14,840) | 1,145 (1,112-1,152) | 172 (167-173) | 19 (3-57)
1.5 | B40-79 | 16,963 (16,473-17,051) | 1,408 (1,373-1,417) | 205 (200-207) | 20 (3-58)
1.5 | A40-49, B50-79 | 21,766 (21,243-21,942) | 1,719 (1,682-1,734) | 242 (236-244) | 25 (3-61)
1.5 | A40-79 | 33,482 (32,254-33,716) | 2,170 (2,103-2,189) | 297 (288-300) | 28 (4-77)
2.0 | B50-74 | 10,580 (10,186-10,635) | 825 (794-828) | 129 (124-129) | 19 (3-55)
2.0 | B45-79 | 14,355 (13,775-14,409) | 1,115 (1,074-1,120) | 168 (162-168) | 25 (4-69)
2.0 | B40-79 | 16,547 (15,943-16,621) | 1,379 (1,334-1,386) | 201 (195-202) | 25 (4-70)
2.0 | A40-49, B50-79 | 21,296 (20,651-21,485) | 1,686 (1,638-1,702) | 237 (230-239) | 32 (4-74)
2.0 | A40-79 | 32,590 (31,052-32,768) | 2,121 (2,035-2,137) | 290 (279-293) | 36 (5-93)

Abbreviations: A=annual; B=biennial.

a Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

b As risk increases, more persons develop and die of breast cancer, therefore the number of lifetime screening mammograms decreases.

c Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario.

Table 24 Median (and Range) of Lifetime Benefits and Harms Across Four Models of Screening With Digital Breast Tomosynthesis vs. No Screening for a Cohort of 1,000 40-Year-Old Black Female Persons According to Relative Risk Group and Efficient or Near-Efficient Screening Strategy

Relative Risk Group | Strategy | Mortality Reduction (%) | Breast Cancer Deaths Averted | Life-Years Gained | QALYs Gained^a^
1 (average) | B45-79 | 31.2 (26.4-36.3) | 11.7 (9.3-17.5) | 219.4 (172.7-303.6) | 161.3 (123.7-226.6)
1 (average) | B40-79 | 33.0 (26.6-36.8) | 12.0 (10.2-17.8) | 238.5 (205.4-328.1) | 178.5 (141.0-244.6)
1 (average) | A40-79 | 39.6 (37.9-46.2) | 15.5 (12.1-22.3) | 309.0 (253.9-406.8) | 221.2 (178.1-298.8)
1.5 | B45-79 | 31.4 (27.5-36.6) | 17.1 (14.0-25.4) | 321.1 (262.7-443.2) | 241.5 (194.4-336.2)
1.5 | B40-79 | 33.2 (27.9-37.3) | 17.5 (15.2-25.9) | 354.9 (307.1-480.1) | 272.1 (218.1-364.3)
1.5 | A40-79 | 40.1 (38.8-46.7) | 22.7 (18.1-32.4) | 453.7 (375.4-595.2) | 335.2 (274.2-447.4)
2.0 | B45-79 | 31.6 (28.4-36.8) | 22.2 (18.5-32.6) | 419.4 (349.3-572.5) | 319.1 (262.5-437.7)
2.0 | B40-79 | 33.5 (29.0-37.6) | 22.8 (20.1-33.3) | 463.7 (406.7-622.3) | 359.8 (293.9-476.4)
2.0 | A40-79 | 41.0 (39.0-47.0) | 29.5 (23.8-41.7) | 592.6 (499.5-772.0) | 444.8 (372.3-587.1)
| Strategy | Screens^b^ | False-positive Recalls | Benign Biopsies | Overdiagnosed Cases^c^
1 (average) | B45-79 | 14,755 (14,625-14,818) | 1,107 (1,097-1,109) | 208 (206-208) | 20 (8-37)
1 (average) | B40-79 | 16,965 (16,817-17,032) | 1,326 (1,314-1,329) | 245 (243-246) | 20 (7-37)
1 (average) | A40-79 | 33,577 (33,141-33,711) | 2,074 (2,046-2,077) | 323 (318-323) | 25 (9-49)
1.5 | B45-79 | 14,301 (14,170-14,403) | 1,072 (1,062-1,075) | 202 (200-202) | 29 (10-50)
1.5 | B40-79 | 16,523 (16,361-16,629) | 1,292 (1,278-1,295) | 239 (236-240) | 29 (10-51)
1.5 | A40-79 | 32,617 (32,101-32,834) | 2,017 (1,983-2,024) | 314 (309-315) | 35 (12-68)
2.0 | B45-79 | 13,867 (13,737-14,006) | 1,039 (1,028-1,044) | 196 (194-197) | 37 (13-62)
2.0 | B40-79 | 16,098 (15,928-16,243) | 1,260 (1,243-1,263) | 233 (230-234) | 37 (12-63)
2.0 | A40-79 | 31,692 (31,117-31,996) | 1,962 (1,924-1,974) | 306 (300-307) | 45 (15-84)

Abbreviations: A=annual; B=biennial.

a Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

b As risk increases, more persons develop and die of breast cancer, therefore the number of lifetime screening mammograms decreases.

c Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario.

Table 25 Change in Estimated Breast Cancer Screening Outcomes for a Cohort of 1,000 65-Year-Old Female Persons Screened Biennially with Digital Breast Tomosynthesis According to Different Comorbidity Levels and the Age to Stop Screening, Model GE and Model W

Comorbidity Level and Initial Screening Ages^a^ | Comparison Stopping Age | Mortality Reduction, % | | Breast Cancer Deaths Averted | | Life-Years Gained | | QALYs Gained
Comorbidity Level and Initial Screening Ages^a^ | Comparison Stopping Age | GE | W | GE | W | GE | W | GE | W
None
50-74 | 69 | −14.9 | −11.9 | −3.5 | −1.5 | −39.4 | −20.4 | −29.1 | −13.1
50-65 | 74 | 25.5 | 19.3 | 6.1 | 2.5 | 75.6 | 36.2 | 56.1 | 23.4
50-74 | 79 | +8.0 | +6.4 | +1.9 | +0.8 | +16.0 | +8.6 | +11.3 | +4.9
50-74 | 84 | +16.1 | +12.9 | +3.8 | +1.7 | +28.2 | +15.0 | +19.6 | +8.0
Low
50-74 | 69 | −14.8 | −12.1 | −3.1 | −1.4 | −34.1 | −17.3 | −24.8 | −10.7
50-65 | 74 | 26.0 | 20.0 | 5.5 | 2.3 | 65.8 | 30.9 | 48.3 | 19.4
50-74 | 79 | +7.9 | +6.2 | +1.7 | +0.7 | +14.1 | +7.1 | +9.9 | +4.0
50-74 | 84 | +15.8 | +12.4 | +3.3 | +1.4 | +24.7 | +12.4 | +17.1 | +6.4
Moderate
50-74 | 69 | −14.9 | −12.1 | −2.8 | −1.2 | −29.7 | −15.2 | −21.4 | −9.2
50-65 | 74 | 26.5 | 20.4 | 5.0 | 2.1 | 58.0 | 27.4 | 42.2 | 16.8
50-74 | 79 | +7.7 | +6.1 | +1.4 | +0.6 | +12.2 | +6.2 | +8.5 | +3.4
50-74 | 84 | +15.4 | +11.9 | +2.9 | +1.2 | +21.4 | +10.8 | +14.8 | +5.5
Severe
50-74 | 69 | −14.8 | −12.0 | −2.1 | −1.0 | −22.6 | −11.5 | −16.0 | −6.8
50-65 | 74 | 26.8 | 20.8 | 3.8 | 1.7 | 43.6 | 20.8 | 31.1 | 12.1
50-74 | 79 | +7.6 | +5.9 | +1.1 | +0.5 | +9.1 | +4.7 | +6.4 | +2.6
50-74 | 84 | +15.3 | +11.5 | +2.2 | +0.9 | +16.2 | +8.1 | +11.1 | +4.1
Average
50-74 | 69 | −14.9 | −12.0 | −3.2 | −1.4 | −34.7 | −17.4 | −25.4 | −10.9
50-65 | 74 | 26.0 | 19.8 | 5.5 | 2.3 | 66.9 | 31.1 | 49.3 | 19.6
50-74 | 79 | +7.8 | +6.3 | +1.7 | +0.7 | +14.0 | +7.2 | +9.8 | +4.0
50-74 | 84 | +15.8 | +12.5 | +3.3 | +1.4 | +24.7 | +12.5 | +17.1 | +6.5
| | Screens, n^b^ | | False-positive Recalls, n | | Benign Biopsies, n | | Overdiagnosis, n^c^
None | | GE | W | GE | W | GE | W | GE | W
50-74 | 69 | −2,798 | −2,741 | −155 | −152 | −21.9 | −21.4 | −1.3 | −10.5
50-65 | 74 | 4,778 | 4,692 | 266 | 260 | 37.5 | 36.6 | 1.8 | 17.3
50-74 | 79 | +1694 | +1,653 | +85 | +83 | +11.2 | +10.9 | +1.7 | +6.8
50-74 | 84 | +3789 | +3,692 | +191 | +186 | +25.1 | +24.4 | +5.6 | +15.2
Low
50-74 | 69 | −2,674 | −2,593 | −149 | −143 | −21.0 | −20.2 | −2.2 | −10.3
50-65 | 74 | 4,650 | 4,530 | 259 | 251 | 36.5 | 35.4 | 3.1 | 17.3
50-74 | 79 | +1520 | +1,455 | +77 | +73 | +10.1 | +9.6 | +2.1 | +6.1
50-74 | 84 | +3335 | +3,181 | +168 | +160 | +22.1 | +21.1 | +5.5 | +13.3
Moderate
50-74 | 69 | −2,582 | −2,490 | −143 | −138 | −20.2 | −19.4 | −3.1 | −10.2
50-65 | 74 | 4,545 | 4,410 | 253 | 244 | 35.7 | 34.4 | 4.2 | 17.2
50-74 | 79 | +1,376 | +1,307 | +69 | +66 | +9.1 | +8.7 | +2.3 | +5.6
50-74 | 84 | +2,955 | +2,809 | +149 | +141 | +19.6 | +18.6 | +5.3 | +11.9
Severe
50-74 | 69 | −2,108 | −2,010 | −117 | −111 | −16.5 | −15.7 | −3.7 | −8.5
50-65 | 74 | 3,998 | 3,823 | 222 | 212 | 31.4 | 29.8 | 6.5 | 15.7
50-74 | 79 | +1,028 | +975 | +52 | +49 | +6.8 | +6.5 | +1.7 | +4.2
50-74 | 84 | +2,214 | +2,103 | +111 | +106 | +14.7 | +13.9 | +3.9 | +8.9
Average
50-74 | 69 | −2,640 | −2,560 | −147 | −142 | −20.7 | −20.0 | −2.1 | −10.1
50-65 | 74 | 4,602 | 4,480 | 256 | 248 | 36.1 | 35.0 | 3.1 | 17.1
50-74 | 79 | +1,517 | +1,457 | +76 | +73 | +10.1 | +9.7 | +1.9 | +6.1
50-74 | 84 | +3,353 | +3,204 | +169 | +161 | +22.2 | +21.2 | +5.3 | +13.4

a Outcomes for biennial screening at ages 50–74 are relative to biennial screening at ages 50–64. Outcomes for stopping biennial screening at ages 69, 79, and 84 are relative to biennial screening during ages 50–74 within each level of comorbidity.

b Number of mammograms after age 65.

c Overdiagnosed cases are in situ and invasive breast cancer cases that would not have been clinically detected in the absence of screening. Overdiagnosis is calculated by subtracting the number of cases detected in the no-screening scenario from the number of cases detected in the screening scenario.

## Question 5 Trade-Offs of Stopping Ages According to Comorbidity Level

For 65-year-old female persons who had previously screened biennially during ages 50–65 with DBT and had never been diagnosed with breast cancer, models estimated benefits and harms of continuing with biennial screening until one of four ages (69, 74, 79, and 84) for four comorbidity levels. Model GE predicted that about 1 additional breast cancer death would be averted by biennial screening until age 79 for all four comorbidity levels (range, 1.1 to 1.9, depending on comorbidity level). However, model W estimated that 0.5 to 0.8 additional breast cancer deaths would be averted by biennial screening until 79 instead of 74, depending on comorbidity level.

## Sensitivity Analysis

When cases diagnosed with breast cancer received the most effective treatment for their cancer subtype, the percent reduction in breast cancer mortality increased as compared with the scenario where cases received treatment based on dissemination patterns; for example, multiple treatment combinations were possible for cases with the same diagnosis (Appendix Table 13). Conversely, breast cancer deaths averted were similar or slightly lower when all cases received the most effective therapy, whereas the difference in LYG and QALYs gained varied by model and screening strategy.

Among all female persons for different DBT screening strategies, using alternate values for age-related disutilities from the SF-6D resulted in QALYs gained that were a median of 3.7 to 6.6 units smaller than QALYs based on the EQ-5D (Appendix Table 14). Among Black female persons, QALYs gained across the DBT screening strategies were 5.4 to 9.6 units smaller based on the SF-6D. Screening strategies identified as efficient or near-efficient were the same regardless of which age-related utilities were used to calculate an incremental ratio of the change in mammograms divided by the change in QALYs gained for either female persons overall or for Black female persons. Seven strategies were efficient or near-efficient for all female persons (B50-74; B45-74; B45-79; B40-74; B40-79; A40-49 with B50-79; and A40-79), while six screening strategies were efficient or near-efficient for Black female persons (B50-74; B45-74; B45-79; B40-79; A40-49 with B50-79; and A40-79).