# Chapter 2 Methods

## Purpose of the Decision Analysis

The purpose of this comparative effectiveness of different breast cancer screening strategies is to inform the USPSTF as it updates the screening recommendations from 2016. Modeling has the advantage of combining evidence from multiple high-quality data sources and simulating exact screening scenarios to quantify the variation of harms and benefits in groups of female persons based on their age, breast density, comorbidity level, race, and risk factor profile. Use of multiple models strengthens the credibility of model projections and provides a range of plausible effects given different modeling approaches and assumptions for representing unobservable phenomena. Decision makers and other stakeholders can gain confidence in collaborative modeling results if all models demonstrate meaningful, qualitatively similar lifetime mortality reductions due to screening despite differences in model assumptions and structures.

## Scope of the Decision Analysis

The CISNET Breast Working Group, USPSTF members, EPC review team, and AHRQ Medical Officer defined the scope and questions for the decision analysis. The questions were:

1. Compared with no screening, what are the trade-offs of efficient mammography screening strategies for average-risk, asymptomatic female persons when strategies vary by modality, interval, initiation age, and cessation age?
2. Does the answer to question 1 change when breast cancer in Black female persons is modeled? What screening strategies for Black female persons achieve similar trade-offs as observed for female persons overall and reduce mortality disparities?
3. What are the trade-offs of efficient density-specific DBT screening strategies that vary by starting age, stopping age, and interval once a female person decides on the age to start screening?
4. What are the trade-offs of efficient DBT screening strategies that vary by starting age, stopping age, and interval for female persons with modestly elevated risk (e.g., a family history of breast cancer)?
5. Among female persons screened biennially starting at age 50 with DBT, what are the trade-offs of different stop ages within levels of comorbidity?

The analysis was limited to female persons with no personal history of breast cancer, without a confirmed or suspected genetic mutation known to increase risk of breast cancer (e.g., BRCA), and without a personal history of chest radiation therapy at a young age.^23^ Models apply to cisgender women and may not accurately reflect breast cancer risk for transgender persons. Model results are driven by sex (i.e., female) rather than gender identity. We use the term “women” herein, while recognizing that not all individuals at risk of breast cancer and eligible for screening self-identify as women.^24^

## Overview of the Models and Input Parameters

We used six models of breast cancer: Dana-Farber Cancer Institute (Model D), Erasmus University Medical Center (Model E), Georgetown Lombardi Comprehensive Cancer Center-Albert Einstein College of Medicine (Model GE), University of Texas MD Anderson Cancer Center (Model M), Stanford University (Model S), and University of Wisconsin-Madison-Harvard Pilgrim Health Care (Model W). Detailed descriptions of each model are available in a special issue of Medical Decision Making^25–30^ and online.^31^ We have previously twice provided evidence to inform decisions of the USPSTF for breast cancer screening.^16,32^ The six models were independently developed and all replicate breast cancer incidence and mortality in the U.S. female population. The models use common data inputs, but each modeling team makes independent assumptions regarding the natural history of breast cancer and how the data inputs are incorporated into the models; for example, Models E, GE, S, and W are microsimulation models, Model D is an analytic statistical model, and Model M uses a fully Bayesian approach (Table 1).

Table 1 Breast Cancer Model Characteristics, Including a Comparison of Key Model Differences and Similarities

Model Components | D (Dana-Farber)^27^ | E (Erasmus)^30^ | GE (Georgetown-Einstein)^29^ | M (MD Anderson)^26^ | S (Stanford)^28^ | W (Wisconsin-Harvard)^25^
Type of model | Analytic | Simulation | Simulation | Bayesian | Simulation | Simulation
Natural history structure | State transition | Tumor growth leading to fatal metastasis | State transition | None | Tumor growth with stage shift | Tumor growth with some indolent and aggressive cases
Method of construction | Stochastic process, Time to event | Longitudinal, Likelihood optimization, Stochastic process, Time to event | Time to event | Longitudinal, Likelihood optimization, Stochastic process, Time to event | Longitudinal, Likelihood optimization, Stochastic process, Time to event | Longitudinal, Stochastic process, State transition
Breast cancer incidence without screening | Gangnon 2021 APC Model^33^; used as-is | Age distribution of onset and cohort-specific probabilities estimated based on Holford APC,^72^ adjusted based on Gangnon 2021 APC Model^33^; used as a calibration target | Holford APC^72^ 1975-2000 adjusted by Gangnon 2021 APC^33^ after 2000 | Extended 1975 SEER rates; used as a linear model over years with an unknown slope parameter estimated by matching with SEER data | Jointly estimated APC model with postmenopausal hormone therapy effects based on Holford APC Model^72^ | Holford APC^72^ 1975-2000 adjusted by Gangnon 2021 APC^33^ after 2000; APC used as a starting point of calibration to incidence
Breast density | Affects incidence in the absence of screening and mammography performance^a^ | Affects incidence in the absence of screening and mammography performance^a^ | Affects incidence in the absence of screening and mammography performance^a^ | Affects incidence (both in the presence and absence of screening) and mammography performance (specificity) | Not modeled | Affects incidence in the absence of screening and mammography performance^a^
Screening benefit mechanism ^a^ | Stage shift using stage distribution at diagnosis provided by BCSC | Detection at non-fatal (smaller) size based on screening sensitivity provided by the BCSC, which is a calibration target | Tumor detected in earlier stage and at younger age based on screening sensitivity provided by the BCSC, which is a calibration target | Stage shift and beyond stage shift, defined as better survival for screen-detected cases than clinically detected cases of the same stage | Smaller size, stage shift, age shift based on varying a parameter that quantifies the probability that screening will detect a tumor of a given size that matches BCSC sensitivity data | Stage and tumor size shift based on screening sensitivity provided by the BCSC, which is a calibration target
Stage distribution among diagnosed cancers | Assigned based on BCSC data for stage by mode of detection | Stage distribution results from: diameter of clinical detection estimated based on SEER data; threshold diameter of screen detection based on BCSC data; and tumor diameter distribution of invasive tumors linked to AJCC stages | Clinically detected tumors assigned a stage based on BCSC data. Stage of screen-detected tumors determined by Bayes’ theorem with BCSC data as prior distribution, likelihood based on stage dwell time distributions, and achieved lead time | Assigned based on BCSC data | Based on tumor growth parameters and diameter of screen detection that are calibrated to BCSC data, diameter of clinical detection based on SEER data | Stage calibrated to SEER incidence with BCSC data as secondary calibration targets for screen-detected cancers
ER/HER2 subtype distribution | Assigned based on BCSC data | Assigned based on BCSC data | Assigned based on BCSC data | Assigned based on BCSC data | Calibrated to BCSC data, then adjusted based on SEER data by stage, tumor size, and calendar year | Assigned based on BCSC data
Treatment benefit mechanism | Hazard reduction | Cure fraction | Hazard reduction; ability to cure | Hazard reduction, cure fraction | Hazard reduction | Cure fraction^b^
Program | Mathcad | Python | C+ | C#, R, SAS | Python | C+

Abbreviations: APC, age-period-cohort model; BCSC, Breast Cancer Surveillance Consortium; SEER, Surveillance, Epidemiology, and End Results.

a Screening performance includes sensitivity; stage distribution among screen-, interval-, and clinically-detected cases; false-positive recall (specificity); and benign biopsy rates.

b Calibrated to mortality for a subset of treatment related parameters after natural history parameters are calibrated to incidence.

Model Profiles are available at https://resources.cisnet.cancer.gov/registry/site-summary/breast/.

### Breast Cancer Natural History Component

All models begin by representing cohorts of individual female persons and their risk of breast cancer in the absence of screening. Individuals enter the models at ages 0 to 25 (depending on the model) since >99% of breast cancers are diagnosed after age 25 and population screening is unlikely to occur prior to that age. Each individual has a risk of symptomatic detection of breast cancer based on an age-period-cohort function using population trend data from the Surveillance, Epidemiology, and End Results (SEER) Program (Table 2).^33^ Some models use the age-period-cohort function directly, while others use it in calibration or rely on SEER rates from the prescreening era (1975–1979) directly (Table 1).

Table 2 Common Breast Cancer Model Input Parameters: Description and Data Sources

Input | Description | Updated since 2016 | Race-specific | References
Breast cancer incidence without screening | Age-period-cohort model using SEER breast cancer incidence with a period effect for mammography removed | Yes. Recent years added, 1980 instead of 1970 birth cohort. | Yes; incidence varied by race. Same data source. | Gangnon,^33^ Holford^72^
Breast density | Prevalence of breast density (BI-RADS a, b, c, d) by age group (40-44, 45-49, 50-64, 65-74, 75-89) | Yes | Yes; density varied by race. Same data source. | BCSC
Mammography performance | Sensitivity and false-positive recall of initial and subsequent mammography by age (40-44, 45-49, 50-64, ≥65) and screening interval (annual, biennial) and density (a,b,c,d) for DM and DBT | Yes | Screening sensitivity did not vary by race. False-positive recall did vary by race. Same data source. | BCSC^6^
Breast cancer stage distribution (AJCC or SEER Summary Stage) | Stage distributions by mode of detection, age group (40-44, 45-49, 50-64, 65-74, 75-89), screening round/interval (first, annual, biennial) for screen-detected cancers, and density (a, b, c, d) | Yes | Yes; stage distributions varied by race. Same data source. | BCSC
ER/HER2 joint distribution | The distribution of ER/HER2 subtypes by age (40-49, 50-74, 75-89) and stage at diagnosis | Yes | Yes; subtype distributions varied by race. Same data source. | BCSC
Survival in the absence of screening and treatment | 25-y breast cancer survival before systemic treatment by joint ER/HER2 status, age group, AJCC/SEER stage or tumor size | No | No; base survival did not vary by race. | Munoz,^40^ Plevritis^41^
Treatment dissemination | Treatments and rates of use by time period, ER/HER2, stage and age for initial breast cancer diagnosis | Yes | No; treatment assignment did not vary by race. | Caswell-Jin^42^, Mandelblatt,^43^ Plevritis^41^
Treatment effects | Meta-analyses of clinical trial results by ER/HER2 for initial local therapy. Expert opinion for efficacy of systemic primary and metastatic therapy, and of newer targeted therapies. | Yes | Yes; treatment effectiveness reduced for Black patients based on NCCN data.^47^ | Caswell-Jin,^42^ Early Breast Cancer Trialists’ Collaborative,^44,45,73–76^ Plevritis,^41^ Warner^47^
Other-cause mortality | Age- and cohort-specific mortality rates from non-breast cancer causes by year and level of comorbidity | Yes | Yes; other-cause mortality rates varied by race. Same data source. | Cho,^77^ Gangnon,^46^ Lansdorp-Vogelaar^62^
Quality of life | Utility weights for general health and decrements for screening, diagnostic evaluation, and stage-specific treatment | No | No; utility weights did not vary by race. | de Haes,^50^ Hamner,^48,49^ Stout^51^

Abbreviations: AJCC, American Joint Committee on Cancer; BCSC, Breast Cancer Surveillance Consortium; BI-RADS, Breast Imaging Reporting and Data Systems; CISNET, Cancer Intervention and Surveillance Modeling Network; DM, digital mammography; DBT, digital breast tomosynthesis; ER, estrogen receptor; HER2, human epidermal growth factor receptor 2; NCCN, National Comprehensive Cancer Network; SEER, Surveillance, Epidemiology, and End Results.

### Breast Cancer Screening Component

In all six models, breast cancer is depicted as having a preclinical detectable period or sojourn time, a clinical detection timepoint when symptoms or signs are present (e.g., palpable lump), and a lead time which is the difference of the two (Figure 1). When a screening test is administered during the preclinical detectable period, a true positive test leads to earlier detection and initiation of treatment, and potentially a shift to an earlier stage at diagnosis. Some models require a stage shift for screening to have a survival or mortality benefit, while others allow for improved survival when tumors are detected at smaller sizes within the same stage (Table 1).

Figure 1 Graphical Description of When the Timing of Screening in the Models Can Lead to an Earlier Diagnosis Relative to the Timing of the Onset of Symptoms

Whether a screening test detects breast cancer during the preclinical period depends on the performance characteristics of the test. For this analysis, updated mammography data were provided by the Breast Cancer Surveillance Consortium (BCSC) for sensitivity of DM and DBT (Table 3), the prevalence of breast density by age (Appendix Table 1), and density-specific underlying relative risk of breast cancer (Appendix Table 2). Mammography sensitivity estimates were stratified by age group, screening interval, breast density, and invasive carcinoma versus ductal carcinoma in situ (DCIS) (Table 3). The stage distribution of breast cancer cases was also provided by the BCSC for screen-detected cases (Appendix Figure 1) and interval- and clinically-detected cases (Appendix Figure 2).

Table 3 Performance (Sensitivity, False-Positive Recalls) of Digital Mammography and Digital Breast Tomosynthesis for All and Black Female Persons, Breast Cancer Surveillance Consortium

Density | Age | Interval^a^ | Sensitivity^b^ (%) | False-Positive Recall (%)
Density | Age | Interval^a^ | Sensitivity^b^ (%) | DM | | DBT
Density | Age | Interval^a^ | Sensitivity^b^ (%) | All | Black | All | Black
BI-RADS a | 40-44 | First | 90% | 13% | 10% | 11% | 6%
BI-RADS a | 40-44 | Annual | 86% | 5% | 4% | 4% | 2%
BI-RADS a | 40-44 | Biennial | 90% | 6% | 6% | 5% | 3%
BI-RADS a | 45-49 | First | 93% | 14% | 11% | 12% | 7%
BI-RADS a | 45-49 | Annual | 88% | 4% | 4% | 3% | 2%
BI-RADS a | 45-49 | Biennial | 92% | 6% | 6% | 5% | 3%
BI-RADS a | 50-64 | First | 97% | 16% | 14% | 13% | 8%
BI-RADS a | 50-64 | Annual | 91% | 4% | 4% | 3% | 2%
BI-RADS a | 50-64 | Biennial | 94% | 5% | 5% | 4% | 3%
BI-RADS a | 65-74 | Annual | 93% | 4% | 5% | 3% | 2%
BI-RADS a | 65-74 | Biennial | 95% | 5% | 6% | 3% | 3%
BI-RADS b | 40-44 | First | 93% | 21% | 19% | 20% | 13%
BI-RADS b | 40-44 | Annual | 85% | 9% | 9% | 8% | 6%
BI-RADS b | 40-44 | Biennial | 89% | 11% | 11% | 10% | 8%
BI-RADS b | 45-49 | First | 95% | 22% | 20% | 20% | 14%
BI-RADS b | 45-49 | Annual | 88% | 8% | 9% | 7% | 5%
BI-RADS b | 45-49 | Biennial | 91% | 10% | 11% | 8% | 7%
BI-RADS b | 50-64 | First | 98% | 24% | 24% | 21% | 16%
BI-RADS b | 50-64 | Annual | 91% | 7% | 8% | 5% | 5%
BI-RADS b | 50-64 | Biennial | 93% | 8% | 10% | 7% | 6%
BI-RADS b | 65-74 | Annual | 93% | 6% | 8% | 4% | 5%
BI-RADS b | 65-74 | Biennial | 94% | 7% | 10% | 6% | 6%
BI-RADS c | 40-44 | First | 93% | 24% | 24% | 24% | 18%
BI-RADS c | 40-44 | Annual | 94% | 11% | 15% | 11% | 10%
BI-RADS c | 40-44 | Biennial | 94% | 14% | 17% | 13% | 13%
BI-RADS c | 45-49 | First | 72% | 24% | 25% | 23% | 18%
BI-RADS c | 45-49 | Annual | 82% | 10% | 13% | 9% | 9%
BI-RADS c | 45-49 | Biennial | 96% | 12% | 16% | 11% | 11%
BI-RADS c | 50-64 | First | 76% | 25% | 27% | 23% | 20%
BI-RADS c | 50-64 | Annual | 85% | 8% | 12% | 7% | 8%
BI-RADS c | 50-64 | Biennial | 98% | 10% | 14% | 9% | 10%
BI-RADS c | 65-74 | Annual | 82% | 7% | 11% | 5% | 7%
BI-RADS c | 65-74 | Biennial | 88% | 8% | 13% | 7% | 8%
BI-RADS d | 40-44 | First | 85% | 16% | 16% | 17% | 12%
BI-RADS d | 40-44 | Annual | 90% | 10% | 14% | 11% | 10%
BI-RADS d | 40-44 | Biennial | 86% | 12% | 17% | 13% | 13%
BI-RADS d | 45-49 | First | 90% | 16% | 16% | 17% | 12%
BI-RADS d | 45-49 | Annual | 83% | 9% | 13% | 9% | 9%
BI-RADS d | 45-49 | Biennial | 62% | 11% | 15% | 11% | 12%
BI-RADS d | 50-64 | First | 76% | 16% | 17% | 16% | 13%
BI-RADS d | 50-64 | Annual | 89% | 7% | 11% | 6% | 7%
BI-RADS d | 50-64 | Biennial | 67% | 8% | 13% | 8% | 9%
BI-RADS d | 65-74 | Annual | 80% | 5% | 9% | 5% | 6%
BI-RADS d | 65-74 | Biennial | 95% | 6% | 11% | 6% | 8%

Abbreviations: a=almost entirely fatty; b= scattered areas of fibroglandular density; BI-RADS=Breast Imaging-Reporting and Data System; c= heterogeneously dense; d=extremely dense; DBT=digital breast tomosynthesis; DM=digital mammography.

a Sensitivity and false-positive recall calculations included 12 months of breast cancer followup for both annual and biennial screening intervals.

b Values based on predictions for each screening round using data for the calendar year 2018 from a regression model of 1,765,471 mammograms conducted during 2010–2018, adjusted for age (continuous), age-squared, screening interval, breast density category, year of examination, and all two-way interactions except for density by age and interactions with examination year. Sensitivity of digital mammography was not meaningfully different than of digital breast tomosynthesis. Sensitivity was also similar across race and ethnicity. Values shown for all cancers combined (ductal carcinoma in situ and invasive carcinoma).

As required by the Food and Drug Administration, DBT must be accompanied by traditional DM or synthetic DM, which is a two-dimensional image constructed from DBT data; hereafter, references to DBT will imply concurrent use with DM or synthetic DM. Since evidence suggests that DM and synthetic DM contribute comparable benefits when used with DBT,^34–37^ synthetic DM is rapidly replacing traditional DM in clinical practice to reduce radiation exposure.^38^ For this pragmatic reason, DBT is used in the analysis as the reference modality.

Breast density categories were defined using Breast Imaging Reporting and Data Systems (BI-RADS) lexicon, with dense breasts defined as almost entirely fatty (BI-RADS density “a”), scattered fibroglandular (“b”), heterogeneously dense (“c”), or extremely dense (“d”).^39^ In the models, each person was assigned a breast density category at age 40 (the earliest age at screening in this analysis), which may decrease twice, at ages 50 and 65, to one less-dense category based on prevalence data in the BCSC (Appendix Table 1). BCSC data were also used to estimate the number of false-positive recalls (Table 3) and the number of benign biopsies (Appendix Figure 3). The followup period for all mammography performance measures (sensitivity, false-positive recalls, benign biopsies) for both annual and biennial screening intervals was 12 months.

### Breast Cancer Treatment and Survival

At diagnosis, breast cancer cases were treated according to a stage of disease (AJCC [American Joint Committee on Cancer] anatomic or SEER historical stage) and a subtype based on the estrogen receptor (ER) and human epidermal growth factor receptor 2 (HER2) as observed in the BCSC and SEER (Appendix Table 3). Models assumed that all cases diagnosed with breast cancer immediately received local therapy (mastectomy or breast conserving surgery with radiation). The benefit of treatment was based on the combination of treatment assignment and treatment efficacy. According to each stage at diagnosis and subtype, breast cancer cases were assigned a breast cancer–specific survival time with local therapy.^40,41^ The probability of breast cancer cases receiving specific types of systemic treatment was based on data from the National Comprehensive Cancer Network and, for newer therapies, expert opinion.^42,43^ Treatment efficacy for systemic therapy was based on the most recent published meta-analysis of clinical trials and, for newer therapies, expert opinion.^44,45^

### Non-Breast Cancer Death

Modeled individuals were assigned an age- and race-specific life expectancy to capture death from causes other than breast cancer among female persons based on U.S. actuarial data extrapolated to the 1980 birth cohort (Appendix Figure 4).^46^

### Race-Specific Model Inputs

Some but not all model parameters were updated for separate models of breast cancer outcomes for Black female persons. Model parameters that were assumed to be the same for Black individuals as for female persons overall included mammography sensitivity (stratified by age, breast density, and screening interval), breast cancer survival in the absence of screening and systemic treatment, treatment assignment, and utility values (Table 2). Conversely, race-specific values for Black female persons included the incidence of breast cancer in the absence of screening,^33^ the stage distribution of breast cancer cases at diagnosis (Appendix Figure 1, Appendix Figure 2), the percent of mammograms resulting in a false-positive recall (Table 3) and benign biopsy (Appendix Figure 3), the prevalence of breast density (Appendix Table 1), the distribution of tumor subtype by method of detection (Appendix Table 3), breast cancer treatment effectiveness,^22,47^ and other cause mortality (Appendix Figure 4).^46^

In all analyses, Black individuals received treatment with an efficacy that was lower than for all individuals overall based on an analysis of subtype-specific survival; this decrement in treatment efficacy (28% reduction for treatments for ER-negative tumors and 56% reduction for ER-positive tumors) was based on a published analysis of race-specific breast cancer survival data from >15,000 patients diagnosed during 2000–2007 at eight sites in the National Comprehensive Cancer Network.^47^ For ease of modeling, this decrement in treatment benefit was a simplifying assumption that, together with race-specific screening input parameters, was intended to represent the reduced quality of breast cancer early detection and treatment experienced by Black female patients at many points in care, including access, timeliness, and completeness, that affect breast cancer mortality.

## Outcomes

Each model aggregated simulation results for all individual persons to provide total counts of screening examinations and health outcomes. Outcomes were tallied from age 40 to death and expressed per 1,000 average-risk female persons who were unscreened and free of diagnosed breast cancer at age 40. Outcomes were presented for the overall U.S. female population and for Black female persons. In additional analyses, outcomes were stratified by breast density category (BI-RADS a, b, c, d), or risk factor group (relative risk values 1.5 and 2.0 [e.g., positive family history of breast cancer]), or level of comorbidity (none, low, moderate, severe).

### Benefits

Our primary outcome for screening benefit was estimated percent reduction in breast cancer mortality compared with no screening. (All female patients diagnosed with breast cancer in the models received treatment regardless of method of detection.) Other estimated benefits included breast cancer deaths averted, life-years gained (LYG), and quality-adjusted life-years (QALYs) gained. QALYs were calculated using age-specific utilities for female persons in the general population,^48,49^ with disutilities applied to having a mammogram, and, for patients diagnosed with breast cancer, for breast cancer treatment based on the stage at diagnosis (Appendix Table 4).^50,51^

### Harms

As a routine measure of screening burden, the number of screening tests was considered a harm along with model-estimated false-positive recalls, benign results from biopsies recommended for findings on screening mammography (hereafter referred to as benign biopsies), and the number of overdiagnosed cases of breast cancer. For these results, overdiagnosis was defined as the excess breast cancer cases that were diagnosed in the presence of screening that would not have been diagnosed in the absence of screening. We recognize that the definition of overdiagnosis can vary across studies, including those conducted using CISNET models. The definition of overdiagnosis used in this project was chosen so that calculations were consistent across all six models. The harm of overtreatment after overdiagnosis was captured by a decrement in utility based on a composite value for undergoing local and systemic therapy without a change in life expectancy.

### Trade-Offs

To compare trade-offs of screening harms versus benefits, strategies were plotted on efficiency frontiers. For each figure, the benefits (mortality reduction or LYG) were plotted against the number of mammograms. We considered a strategy more “efficient” than a comparison strategy if it resulted in greater health benefits for a given increase in the number of mammograms. A strategy that entailed more harms but fewer benefits was considered “inferior” to (also referred to as inefficient or dominated by) other strategies. We identified the efficiency frontier as the sequence of strategies that achieved the largest incremental gain in benefits per additional unit of harm (Figure 2). Screening strategies that fell on this frontier were considered the most efficient (i.e., no alternative exists that provides more benefit with fewer harms). Because an inferior strategy providing outcomes that are very similar to an efficient strategy may still be considered by decision makers for other reasons (e.g., uncertainty in model estimates, model parameter sampling variation, or for consistency of starting and stopping ages across screening modalities),^52^ we also identified “near-efficient” strategies using similar methods as the USPSTF decision analysis for colorectal cancer in 2021.^53^ For this analysis, we defined near-efficient a priori as a strategy within 5% of the value for screening biennially during ages 50–74 (the current USPSTF recommendation) with DBT among female persons overall and for Black female persons separately. For plots of the percent reduction in breast cancer mortality, near-efficient strategies included those within 5% of the efficiency frontier on a relative scale, which is equivalent to 1.27 percentage points on an absolute scale for female persons overall and 1.21 percentage points on an absolute scale for Black female persons. For plots of LYG, near-efficient strategies (within 5%) included those within 2.20 days of life gained per person of the efficient frontier for all female persons and 3.15 days of life per Black female person. Strategies that were not efficient or near-efficient were referred to as “inferior.”

Figure 2 Illustration of the Efficiency Frontier, Efficient Screening Strategies, and an Incremental Ratio (b/a)

Adapted From: Knudsen (2021)^53^

Generic dot plot of the relationship between increasing units of benefit from a health service according to units of harm. A line connects the dots with the highest benefit values on the y-axis at each point along the harms on the x-axis. This line shows which strategies for implementing the health service are considered efficient or, conversely, dominated.

#### Incremental Ratios

For each efficient and near-efficient screening strategy, we calculated the incremental number of lifetime mammograms (Δ mammograms) and the incremental LYG (ΔLYG), relative to the next effective or near-effective strategy with fewer mammograms. The ratio for the strategy with the fewest number of mammograms (biennial at ages 50–74) was calculated relative to no screening. We then calculated an “incremental ratio,” defined as the incremental number of mammograms required to achieve one additional LYG (Δ mammograms/ΔLYG). The reciprocal of the slope of the efficient frontier between adjacent strategies is the incremental ratio. This ratio is akin to the incremental cost-effectiveness ratio in a cost-effectiveness analysis. As the efficient frontier gets flatter, the incremental ratio increases, indicating diminishing returns from each additional mammogram performed. Incremental ratios were also calculated using the percent reduction in breast cancer mortality (Δ mammograms/Δ % breast cancer mortality reduction).

To provide additional outcome metrics of screening, we calculated the percentage of breast cancers diagnosed as advanced breast cancer, defined as AJCC version 6 stage IIB or higher (or SEER regional and distant stage). Models also estimated one benefit-to-harm ratio as a measure of the trade-offs of different screening strategies compared with no screening—LYG per 1,000 mammograms—and three ratios of harm-to-benefit: 1) mammograms per breast cancer death averted, 2) false-positive recalls per breast cancer death averted, and 3) mammograms to obtain a 1 percentage point reduction in breast cancer mortality.

## Analysis

For this USPSTF decision analysis, each model depicted a contemporary cohort of U.S. average-risk female persons who received modern breast cancer screening and treatment—that is, the 1980 birth cohort of female persons turning 40 in 2020—who were followed until death.

### Question 1

Compared with no screening, what are the trade-offs of efficient mammography screening strategies for average-risk, asymptomatic female persons when strategies vary by modality, interval, initiation age, and cessation age?

For analyses of the entire U.S. average-risk asymptomatic female population, we compared model results for mammography screening scenarios that varied by modality (DM, DBT), starting age (40, 45, or 50 years), interval (annual, biennial, or a hybrid of annual and biennial), and cessation age (74 or 79). Three types of hybrid screening scenarios were evaluated: 1) annual starting at 40 then biennial starting at 50; 2) annual starting at 45 then biennial starting at 55; and 3) annual starting at 45 then biennial starting at 50. All six models evaluated DBT and five models evaluated DM (Models D, E, GE, M, and W).

### Question 2

Does the answer to question 1 change when breast cancer in Black female persons is modeled? What screening strategies for Black female persons achieve similar trade-offs as observed for female persons overall and reduce mortality disparities?

Based on race-specific inputs, four models for Black female persons (D, GE, M, W) were used to estimate benefits, harms, and the number of mammograms for the same strategies described for Question 1 above. Although individuals of all race and ethnic groups were included in model input data and calibration targets for modeling female persons overall, we did not evaluate screening strategies separately for Hispanic female persons or individuals who were Asian American, American Indian/Alaska Native, Native Hawaiian/Pacific Islander, or multiracial since breast cancer models were unavailable for these populations.

As mentioned above and in accordance with recent statements by the USPSTF, this modeling analysis defines race as a social construct and aimed to provide evidence regarding the trade-offs of mammography screening strategies for female persons who self-identify as Black as an approach to mitigate health effects of racism.^12^ The purpose of this analysis was to 1) identify which screening strategies for Black female persons were efficient, 2) identify which efficient strategies yield benefit-to-harm trade-offs that were similar to (or more favorable than) trade-offs for the strategy recommended for the overall female population, and 3) quantify the breast cancer mortality disparity reduction for pairs of strategies for Black and all female persons.

### Question 3

What are the trade-offs of efficient density-specific DBT screening strategies that vary by starting age, stopping age, and interval once a female person decides on the age to start screening?

We did not examine the value of a “baseline” mammogram at age 35 or 40 to determine breast density. Instead, we evaluated the trade-offs of maintaining a screening strategy, and how this varies by breast density at the first mammogram, once a person has already decided on the age at which to begin screening. Five models (Models D, E, GE, M, and W) repeated 18 DBT strategies described for Question 1 four times based on whether female persons had breast tissue described as BI-RADS density a, b, c, or d at age 40, including strategies that varied by starting age (40, 45, 50), stopping age (74, 79), and interval (annual, biennial). All three hybrid scenarios were also evaluated.

### Question 4

What are the trade-offs of efficient DBT screening strategies that vary by starting age, stopping age, and interval for female persons with modestly elevated risk (e.g., a family history of breast cancer)?

In all six models, a relative risk of breast cancer associated with elevated risk (either 1.5 or 2.0) was applied to each person’s age-specific underlying risk of breast cancer (Appendix Table 2). These relative risk values were selected based on a review of studies estimating the risk of breast cancer associated with a first-degree family history of breast cancer.^54–61^ Trade-offs of screening were estimated assuming 100% of persons in each analysis had the elevated risk of breast cancer, that is, persons with a family history of breast cancer who receive mammography were compared with persons with a family history who do not receive mammography; results are not shown for a population-level analysis where only a portion of persons have a family history. In the models, elevated relative risk of breast cancer increased risk of a breast cancer diagnosis but did not affect the natural history or the distribution of subtypes of the breast tumors. Results are shown for all breast density groups combined.

This analysis was not intended to address screening for persons who are highly likely to have a strong genetic risk of breast cancer; for example, persons with a family member diagnosed before age 40 or more than two diagnosed family members at any age.

### Question 5

Among female persons screened biennially starting at age 50 with DBT, what are the trade-offs of different stop ages within levels of comorbidity?

Two models (Model GE and W) examined the effect of comorbidity on trade-offs of varying ages to stop breast cancer screening by using age- and comorbidity-specific competing mortality.^16,62^ Examples of conditions that placed individuals in severe and moderate comorbidity groups included congestive heart failure and diabetes, respectively (Appendix Table 5). Comorbidity levels and their associated mortality from causes other than breast cancer were based on published data.^63^ We evaluated screening benefits, harms, and numbers of mammograms for female persons screened biennially with DBT from age 50 until age 69, 74, 79, and 84 for each of four comorbidity levels (none, low, moderate, and severe). Within each comorbidity level, biennial DBT screening strategies starting at age 50 with stopping ages 69, 74, 79, and 84 were evaluated. These analyses were limited to persons who survived and were free of breast cancer up until age 65. Within each comorbidity level, biennial screening from ages 50 to 74 was compared with biennial screening from ages 50 to 64. Incremental results for stopping biennial screening at ages 69, 79, and 84 were expressed relative to stopping at age 74.

### Sensitivity Analysis

#### Treatment

In sensitivity analysis, we evaluated the impact on outcomes by varying how treatment is assigned to cases of breast cancer. Primary analyses for the Questions described above assumed that patients received stage- and subtype-specific adjuvant therapy according to empirical data.^41,43^ This analysis is intended to represent treatment use as observed in “real world” data. For comparison with previous modeling in 2009 and 2016 for the USPSTF, we repeated analysis of the screening strategies evaluated for Question 1 (limited to cessation age 74) assuming that all patients diagnosed with breast cancer received the single most effective therapy according to stage and subtype. For example, in the base case, among breast cancer cases ages <50 years diagnosed with stage II node-negative ER-negative, HER2-negative breast cancer, 2.41% received local therapy only; the remainder of cases received surgery with or without radiation along with anthracycline with taxane (91.57%), endocrine therapy (1.2%), or anthracycline with taxane and endocrine therapy (4.82%). (Endocrine therapy included tamoxifen, an aromatase inhibitor, or both sequentially). All patients with this diagnosis in the sensitivity analysis received anthracycline with taxane since it was the most effective option (the hazard ratio of breast cancer death is equal to or lower than other options).

#### Utilities

Although the models calculated QALYs using average disutilities for health states by age, screening, and breast cancer treatment, perceived disutility for these health states varies widely across individual persons. To address this source of variation, we performed sensitivity analyses using the age-specific disutility values for a general population of female persons (all races) derived from the SF-6D^48^ as a complement to the values derived from the EQ5D^49^ in the base case analysis.

### Model Validation

Using dissemination inputs for screening and treatment in all birth cohorts,^20^ the models replicated observed patterns of breast cancer incidence (Figure 3) and mortality (Figure 4) in the United States.

Figure 3 Estimated Age-Adjusted Breast Cancer Incidence per 100,000 Female Persons by Model and From the Surveillance, Epidemiology, and End Results (SEER) Program for 1992–2018, Ages 30–79

A graph showing the number of model diseases Description automatically generated with medium confidence

Figure 4 Estimated Age-Adjusted Breast Cancer Mortality per 100,000 Female Persons by Model and From the Surveillance, Epidemiology, and End Results (SEER) Program for 1992–2018, Ages 30–79

Note: For comparison with model results, breast cancer mortality rates from the National Vital Statistics System through SEER*Stat software are shown limited to deaths in the areas covered by the SEER 13 registries (“SEER”).

Line chart of breast cancer mortality for the United States by year of death. Six closely clustered lines show values for the CISNET models which also closely approximate observed breast cancer mortality from data collected in the SEER registries.

## Expert Review and Public Comment

A draft report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. The draft report was posted for public comment. Revisions were made based on comments received. Revisions included clarifications to phrasing and ordering in the text, figure titles, and table titles, including definitions of key terms and modeling assumptions. Table 2 was expanded to include more detail on model inputs. Changes were also made due to a recommendation to include overdiagnosis along with the other harms of screening (false-positive recall, benign biopsy) consistently in the tables.