# Chapter 1 Introduction

The benefits of screening mammography were first demonstrated over 30 years ago.^1^ As breast cancer screening technology and treatment improve, screening guidelines need to reflect currently available evidence for breast cancer screening performance, treatment effectiveness, and the roles of other factors that impact breast cancer risk and survival. Updated screening guidelines hold promise for improving the balance of harms and benefits of breast cancer screening for more individuals.

Mammography has been the standard of care for breast cancer screening in the United States since the 1980s, and mammography technology has continued to evolve since its early adoption. Digital mammography (DM) largely replaced film-screen mammography in the United States in the early 2000s, and in the past decade mammogram modality has been rapidly transitioning from DM to digital breast tomosynthesis (DBT). As of February 1, 2024, 89% (7,900/8,862) of Mammography Quality Standards Act (MQSA)-certified facilities in the United States were accredited to perform DBT.^2^ Studies of DBT performance in U.S. screening settings have demonstrated improved recall rates (fewer examinations with recommended additional work-up) and cancer detection rates with DBT versus DM,^3,4^ although interval cancer rates are similar.^5,6^ Recently, a large cohort study comparing DBT to DM found a lower risk of advanced cancer with DBT among patients with extremely dense breasts and at high risk of breast cancer.^6^

In 2016, the U.S. Preventive Services Task Force (USPSTF) recommended biennial screening mammography at ages 50 to 74 years with clinical recommendations for discussion between patients and their providers about individual risks and preferences for starting screening prior to age 50 years.^7^ Many person-level factors are known to impact the benefit and harm trade-offs of screening mammography, and these factors arise during conversations between patients and clinicians. Female persons with a family history of breast cancer or other modest breast cancer risk factors likely experience greater screening benefits than patients without these risk factors. Individuals with dense breasts are known to have greater risk for breast cancer overall and are also at risk for false-negative mammograms due to the masking of cancers by dense breast tissue.^8^ At least 38 states now require that mammography facilities include information about breast density in their results letters to patients, and an amendment to MQSA regulations goes into effect September 2024 that specifies a uniform minimum national reporting standard for these letters.^9^

The USPSTF has recently highlighted the need to include “an intentional focus on embedding health equity” into its processes,^10^ where race is considered a social construct, not a biological one.^11,12^ Despite similar rates of self-reported mammography screening as White female persons, cancer registry data show that Black and African American (hereafter referred to as Black) female persons have experienced long-standing disparities in breast cancer mortality, with rates 40% higher for Black as compared with White female persons.^13^ Evidence strongly suggests that racism contributes to differences in risk factor exposures, which impact breast tumor features, for example, obesity and lactation, and to disparities in healthcare access, quality, timeliness, and completeness.^14,15^

Since there are no recent completed U.S. trials of mammography screening and few studies report race-, density-, or risk-specific data, computer models can be utilized to synthesize current observational and trial data and provide evidence for updating screening guidelines. Since 2016, when the USPSTF last commissioned the Cancer Intervention and Surveillance Modeling Network (CISNET) breast cancer modeling teams to evaluate different screening scenarios,^16^ the CISNET models have made significant updates to incorporate recent data on age-, period-, and cohort-specific breast cancer risk, screening technology and performance, and treatment effectiveness. The CISNET breast cancer models now include updated estimates for DM and DBT screening performance.^17^ The models incorporate breast cancer risk factors, including breast density,^18^ and can simulate elevated risk due to factors such as a family history of breast cancer.^19^ The models have also updated their treatment parameters to reflect the extension of endocrine therapy for patients with estrogen receptor (ER)-positive cancers from 5 years to 10 years, and to reflect advances from molecularly-targeted therapies.^20^ Four of the models have been adapted to model questions related to breast cancer screening for Black female persons.^21,22^ CISNET models directly incorporate the differential distributions by race of biological tumor and treatment factors that contribute to race differences in breast cancer mortality and indirectly reflect the effects of racism and other social determinants of health. Our models are therefore well-suited to conduct a decision analysis requested by the USPSTF in conjunction with a systematic review from the Kaiser Permanente Evidence-based Practice Center (EPC) to update its 2016 recommendation statement on breast cancer screening for average-risk female persons overall and groups of female persons based on Black race, breast density, elevated relative risk of breast cancer, and level of comorbidity.