# Appendix B Supplemental Figures

Appendix B Figure 1 AJCC Stage Distribution (%) of Invasive Breast Cancer Cases Diagnosed Through Screening According to Breast Density Category, Screening Interval, and Modality for Female Persons Ages 45–49, Breast Cancer Surveillance Consortium

Abbreviations: a=almost entirely fatty; b= scattered areas of fibroglandular density; c= heterogeneously dense; d=extremely dense; DBT= digital breast tomosynthesis; DM=digital mammography.

Note: Values based on predictions for the calendar year 2018 from a regression model of 18,680 breast cancer cases diagnosed during 2005–2018, adjusted for age, age-squared, screening interval, modality, breast density category, year of diagnosis, and all two-way interactions except for year of diagnosis and screening interval. A single age group is shown as an example of the pattern of the data.

Bar chart of the percent of breast cancer cases diagnosed through screening according to stage at diagnosis, breast density, mammogram modality, and screening interval. The percent of cases diagnosed by screening is greater for digital breast tomosynthesis compared with digital mammography, for earlier stages at diagnosis, and for patients with lower breast density level.

Appendix B Figure 2 AJCC Stage Distribution (%) of All Interval- and Clinically-Detected Invasive Breast Cancer Cases According to Breast Density Category for Female Persons Ages 45–49, Breast Cancer Surveillance Consortium

Abbreviations: a=almost entirely fatty; b= scattered areas of fibroglandular density; c= heterogeneously dense; d=extremely dense.

Note: Values based on predictions for the calendar year 2018 from a regression model of 18,680 breast cancer cases ages 40–89 years diagnosed during 2005–2018, adjusted for age, age-squared, breast density category, and year of diagnosis. A single age group is shown as an example of the pattern of the data.

Bar chart of the stage distribution of breast cancer cases at diagnosis according to breast density category for interval-detected and clinically-detected cases. The percent of cases diagnosed in earlier stages is greater for interval-detected than for clinically-detected cases. Stage distribution was similar across breast density categories for interval-detected cases but, among clinically-detected cases, more cases were detected at later stages among cases with lower breast density.

Appendix B Figure 3 Percent of Mammograms With an Initial Positive Result and a Biopsy Recommendation With No Cancer During 12 Months of Followup (“Benign Biopsy”) According to Age at Diagnosis, Screening Interval, and Mammogram Modality, for All and Black Female Persons, Breast Cancer Surveillance Consortium

Abbreviations: DBT, digital breast tomosynthesis; DM, digital mammography.

Note: Values based on predictions for the calendar year 2018 from a regression model of 18,680 breast cancer cases ages 40–89 diagnosed during 2005–2018, adjusted for age, age-squared, breast density category, and year of diagnosis.

Line chart of the percent of cases with a benign biopsy after a mammogram according to age group, screening interval, and mammography modality for Black female persons and female persons overall. Benign biopsies were more common at the first mammogram than after subsequent mammograms, and more common with digital breast tomosynthesis than for digital mammography.

Appendix Figure 4 Probability of Death From a Cause Other Than Breast Cancer According to Age for All and Black Female Persons Born in 1980

Line graph of the probability of dying from a cause other than breast cancer by age for Black female persons and female persons overall. Risk of dying increases with age. Probability of other-cause mortality is higher for Black than female persons overall between ages 40 and 85, where the curves cross and probabilities for Black female persons are slightly lower through age 100.

Source: Trentham-Dietz (2021)^79^