# Appendix A Supplemental Tables

Appendix A Table 1 Breast Density Distribution by Age, All and Black Female Persons, Breast Cancer Surveillance Consortium

Age (years) | BI-RADS Breast Density Category (row percentages^a^)
Age (years) | a Almost entirely fatty | b Scattered areas of fibroglandular density | c Heterogeneously dense | d Extremely dense
All female persons
All ages | 10.7 | 44.6 | 37.2 | 7.4
40-44 | 5.0 | 29.7 | 49.5 | 15.9
45-49 | 5.8 | 33.1 | 48.0 | 13.1
50-64 | 11.0 | 45.9 | 36.7 | 6.5
65-74 | 14.8 | 52.8 | 29.2 | 3.2
Black female persons
All ages | 10.7 | 52.5 | 33.3 | 3.5
40-44 | 6.4 | 37.1 | 48.1 | 8.4
45-49 | 7.2 | 40.6 | 46.0 | 6.2
50-64 | 11.7 | 54.5 | 30.9 | 2.9
65-74 | 12.5 | 58.8 | 26.9 | 1.8

Abbreviation: BI-RADS=Breast Imaging-Reporting and Data System.

a Prevalence based on 1,765,471 mammograms conducted during 2010–2018. Values shown for all cancers combined (ductal carcinoma in situ and invasive carcinoma).

Appendix A Table 2 Relative Risk of Breast Cancer Associated With Age, Breast Density, and Other Factors Such as a First-Degree Family History of Breast Cancer

Age (yr) and BI-RADS Breast Density | 1.0 (“Average” Risk) | Relative Risk^a^ Associated with Factors Other than Breast Density
Age (yr) and BI-RADS Breast Density | 1.0 (“Average” Risk) | 1.5 | 2.0
40-49
Almost entirely fatty | 0.37 | 0.56 | 0.75
Scattered areas of fibroglandular density | 0.72 | 1.07 | 1.43
Heterogeneously dense | 1.16 | 1.74 | 2.32
Extremely dense | 1.46 | 2.18 | 2.91
50-64
Almost entirely fatty | 0.50 | 0.75 | 1.00
Scattered areas of fibroglandular density | 0.84 | 1.27 | 1.69
Heterogeneously dense | 1.25 | 1.87 | 2.50
Extremely dense | 1.53 | 2.30 | 3.06
65-74
Almost entirely fatty | 0.61 | 0.92 | 1.22
Scattered areas of fibroglandular density | 0.94 | 1.41 | 1.88
Heterogeneously dense | 1.28 | 1.92 | 2.56
Extremely dense | 1.45 | 2.17 | 2.90

Abbreviation: BI-RADS=Breast Imaging-Reporting and Data System.

a Relative risks are standardized to the average risk in the overall population (RR=1) within each age group.

Appendix A Table 3 Distribution (%) of Subtypes of Breast Cancer by Stage and Method of Detection in All and Black Female Persons, Breast Cancer Surveillance Consortium

AJCC v6 Stage^a^ | Subtype | All | | Black
AJCC v6 Stage^a^ | Subtype | Screen and Interval Detected | Clinically Detected | Screen and Interval Detected | Clinically Detected
I | ER+ HER2+ | 7.4 | 8.9 | 7.0 | 8.8
I | ER+ HER2- | 81.1 | 77.1 | 74.5 | 68.0
I | ER− HER2+ | 2.8 | 4.9 | 3.2 | 5.6
I | ER− HER2− | 8.7 | 9.2 | 15.3 | 17.6
IIA | ER+ HER2+ | 10.5 | 10.1 | 11.7 | 10.0
IIA | ER+ HER2− | 70.0 | 66.4 | 54.2 | 43.8
IIA | ER− HER2+ | 4.3 | 5.2 | 4.5 | 6.7
IIA | ER− HER2− | 15.2 | 18.2 | 29.6 | 39.5
IIB | ER+ HER2+ | 9.9 | 11.7 | 9.5 | 9.5
IIB | ER+ HER2− | 70.3 | 66.1 | 54.5 | 56.2
IIB | ER− HER2+ | 5.9 | 7.6 | 9.5 | 8.0
IIB | ER− HER2− | 13.8 | 14.5 | 26.6 | 26.3
III/IV | ER+ HER2+ | 12.0 | 14.0 | 8.5 | 13.5
III/IV | ER+ HER2− | 63.3 | 59.9 | 55.9 | 45.7
III/IV | ER− HER2+ | 8.2 | 10.4 | 7.7 | 11.7
III/IV | ER− HER2− | 16.5 | 15.7 | 27.9 | 29.1

Abbreviations: AJCC v6, American Joint Commission on Cancer Staging System version 6; ER, estrogen receptor; HER2, human epidermal growth factor receptor 2.

a Values are shown in columns by percentages within each stage; based on 18,680 breast cancer cases diagnosed during 2005–2018 among all cancers combined (ductal carcinoma in situ and invasive carcinoma).

Appendix A Table 4 Input Parameter Values for Utilities Associated With Health-Related States

State | Utility | Disutility | Duration | Unit
Age (years)
40-49 | 0.863 | 0.137 | 1 | Year
50-59 | 0.837 | 0.163 | 1 | Year
60-69 | 0.811 | 0.189 | 1 | Year
70-79 | 0.771 | 0.229 | 1 | Year
≥80 | 0.724 | 0.276 | 1 | Year
Screening attendance (routine screening) | 0.994 | 0.006 | 1 | Week
Diagnostic phase (evaluation of positive screen) | 0.895 | 0.105 | 5 | Week
Cancer treatment for local or DCIS breast cancer | 0.9 | 0.1 | 2 | Year
Cancer treatment for regional breast cancer | 0.75 | 0.25 | 2 | Year
Cancer treatment for distant breast cancer | 0.6 | 0.4 | Until death

Abbreviation: DCIS, ductal carcinoma in situ.

Source: Hanmer (2006),^49^ Stout (2006),^51^ and de Haes (1991)^50^

Appendix A Table 5 Comorbidity Levels and Associated Health Conditions

Level | Types of Health Conditions^a^ | Prevalence | Remaining Life Expectancy at Age 66 (Years) | Probability of 10-year Survival at Age 66
None | None | 69% | 17 | 92%
Low | History of myocardial infarction, acute myocardial infarction, ulcer, rheumatologic disease | 2% | 15 | 85%
Moderate | Peripheral vascular disease, cerebrovascular disease, paralysis, diabetes | 12% | 13 | 77%
Severe | AIDS, chronic obstructive pulmonary disease, congestive heart failure, moderate or severe liver disease, chronic renal failure, dementia, cirrhosis, and chronic hepatitis | 17% | 9 | 57%

Source: Cho (2013),^63^ Mandelblatt (2015),^78^ and Trentham-Dietz (2021)^79^

a Health conditions in the table correspond to separate ICD-9 codes with hazard ratio estimates of death grouped into low (hazard ratios, 1.11 to 1.31), moderate (hazard ratios, 1.44 to 1.52), and severe (hazard ratios, 1.76 to 3.66) levels compared to persons with no comorbidity.

Appendix A Table 6 Lifetime Benefits of Mammography Screening With Digital Mammography vs. No Screening for a Cohort of 1,000 40-Year-Old Female Persons According to Model and Screening Strategy

Strategy | Screens, n^a^ | Model | | | | | Median
Strategy | Screens, n^a^ | D | E | GE | M | W | Median
Stopping age 74 | | Reduction in Breast Cancer Mortality per 1,000 Persons Screened vs. No Screening, %^b^
B50-74 | 11,192 | 27.5 | 24.3 | 18.3 | 25.2 | 19.2 | 24.3
B45-74 | 13,283 | 29.3 | 26.4 | 22.8 | 28.0 | 20.4 | 26.4
A45-49, B50-74 | 15,992 | 30.5 | 29.3 | 25.3 | 29.7 | 22.4 | 29.3
B40-74 | 16,092 | 31.6 | 28.4 | 26.9 | 31.7 | 22.3 | 28.4
A45-54, B55-74 | 18,006 | 30.2 | 30.0 | 24.3 | 29.3 | 23.0 | 29.3
A40-49, B50-74 | 20,898 | 32.3 | 31.7 | 28.7 | 33.1 | 24.4 | 31.7
A50-74 | 21,439 | 30.4 | 31.7 | 24.7 | 29.4 | 26.7 | 29.4
A45-74 | 26,272 | 33.4 | 35.4 | 31.6 | 33.7 | 29.8 | 33.4
A40-74 | 31,178 | 35.2 | 37.6 | 35.1 | 37.3 | 31.8 | 35.2
Stopping age 79
B50-79 | 12,456 | 30.2 | 26.9 | 24.3 | 28.5 | 22.2 | 26.9
B45-79 | 15,176 | 33.3 | 30.2 | 31.7 | 32.7 | 24.8 | 31.7
A45-49, B50-79 | 17,242 | 33.1 | 31.8 | 31.3 | 32.8 | 25.4 | 31.8
B40-79 | 17,354 | 34.3 | 31.0 | 32.9 | 34.9 | 25.3 | 32.9
A45-54, B55-79 | 19,876 | 34.2 | 33.9 | 33.2 | 34.1 | 27.5 | 33.9
A40-49, B50-79 | 22,150 | 34.9 | 34.2 | 34.9 | 36.2 | 27.4 | 34.9
A50-79 | 24,563 | 34.3 | 35.8 | 32.5 | 33.7 | 32.1 | 33.7
A45-79 | 29,389 | 37.3 | 39.5 | 39.5 | 38.1 | 35.1 | 38.1
A40-79 | 34,289 | 39.0 | 41.7 | 42.9 | 41.9 | 37.2 | 41.7
Stopping age 74 | | Life-Years Gained per 1,000 Persons Screened vs. No Screening
B50-74 | 11,192 | 165.0 | 114.6 | 111.4 | 116.9 | 109.8 | 114.6
B45-74 | 13,283 | 187.7 | 135.1 | 172.9 | 140.0 | 125.0 | 140.0
A45-49, B50-74 | 15,992 | 194.5 | 151.3 | 189.7 | 146.9 | 140.8 | 151.3
B40-74 | 16,092 | 208.2 | 150.0 | 214.1 | 170.1 | 141.2 | 170.1
A45-54, B55-74 | 18,006 | 195.5 | 159.3 | 187.6 | 148.6 | 149.5 | 159.3
A40-49, B50-74 | 20,898 | 214.7 | 173.8 | 234.6 | 178.9 | 161.9 | 178.9
A50-74 | 21,439 | 181.4 | 153.2 | 152.4 | 134.0 | 157.0 | 153.2
A45-74 | 26,272 | 210.8 | 183.5 | 230.1 | 163.6 | 187.3 | 187.3
A40-74 | 31,178 | 230.9 | 205.5 | 275.5 | 200.7 | 208.7 | 208.7
Stopping age 79
B50-79 | 12,456 | 172.8 | 120.3 | 131.1 | 122.7 | 118.5 | 122.7
B45-79 | 15,176 | 199.8 | 143.5 | 202.5 | 145.6 | 137.8 | 145.6
A45-49, B50-79 | 17,242 | 202.2 | 156.7 | 209.4 | 153.0 | 149.5 | 156.7
B40-79 | 17,354 | 215.9 | 156.0 | 233.9 | 176.8 | 149.8 | 176.8
A45-54, B55-79 | 19,876 | 207.6 | 168.8 | 217.2 | 158.7 | 162.3 | 168.8
A40-49, B50-79 | 22,150 | 222.4 | 180.0 | 257.0 | 187.9 | 170.5 | 187.9
A50-79 | 24,563 | 192.7 | 162.7 | 177.7 | 145.8 | 172.7 | 172.7
A45-79 | 29,389 | 222.1 | 194.1 | 256.1 | 172.0 | 202.9 | 202.9
A40-79 | 34,289 | 242.2 | 215.1 | 300.6 | 211.4 | 224.3 | 224.3
Stopping age 74 | | Breast Cancer Deaths Averted per 1’000 Persons Screened vs. No Screening
B50-74 | 11,192 | 8.6 | 7.2 | 6.9 | 5.9 | 4.8 | 6.9
B45-74 | 13,283 | 9.2 | 7.8 | 8.5 | 6.6 | 5.1 | 7.8
A45-49, B50-74 | 15,992 | 9.6 | 8.6 | 9.5 | 7.0 | 5.7 | 8.6
B40-74 | 16,092 | 9.9 | 8.4 | 10.1 | 7.4 | 5.6 | 8.4
A45-54, B55-74 | 18,006 | 9.4 | 8.8 | 9.1 | 6.9 | 5.8 | 8.8
A40-49, B50-74 | 20,898 | 10.1 | 9.3 | 10.7 | 7.7 | 6.2 | 9.3
A50-74 | 21,439 | 9.5 | 9.3 | 9.2 | 6.9 | 6.8 | 9.2
A45-74 | 26,272 | 10.5 | 10.4 | 11.8 | 7.9 | 7.5 | 10.4
A40-74 | 31,178 | 11.0 | 11.1 | 13.1 | 8.7 | 8.0 | 11.0
Stopping age 79
B50-79 | 12,456 | 9.4 | 7.9 | 9.1 | 6.7 | 5.6 | 7.9
B45-79 | 15,176 | 10.4 | 8.9 | 11.9 | 7.7 | 6.3 | 8.9
A45-49, B50-79 | 17,242 | 10.4 | 9.4 | 11.7 | 7.7 | 6.4 | 9.4
B40-79 | 17,354 | 10.7 | 9.1 | 12.3 | 8.2 | 6.4 | 9.1
A45-54, B55-79 | 19,876 | 10.7 | 10.0 | 12.4 | 8.0 | 6.9 | 10.0
A40-49, B50-79 | 22,150 | 10.9 | 10.1 | 13.1 | 8.5 | 6.9 | 10.1
A50-79 | 24,563 | 10.7 | 10.5 | 12.2 | 7.9 | 8.1 | 10.5
A45-79 | 29,389 | 11.7 | 11.6 | 14.8 | 8.9 | 8.9 | 11.6
A40-79 | 34,289 | 12.2 | 12.3 | 16.1 | 9.8 | 9.4 | 12.2
Stopping age 74 | | QALYs Gained per 1,000 Persons Screened vs. No Screening^c^
B50-74 | 11,192 | 132.4 | 80.7 | 77.4 | 81.2 | 72.3 | 80.7
B45-74 | 13,283 | 149.5 | 94.9 | 124.5 | 97.5 | 82.2 | 97.5
A45-49, B50-74 | 15,992 | 153.1 | 104.7 | 135.8 | 101.0 | 92.4 | 104.7
B40-74 | 16,092 | 163.8 | 103.9 | 154.5 | 118.8 | 91.8 | 118.8
A45-54, B55-74 | 18,006 | 152.8 | 109.8 | 133.1 | 101.3 | 98.3 | 109.8
A40-49, B50-74 | 20,898 | 165.5 | 117.8 | 167.2 | 122.2 | 104.4 | 122.2
A50-74 | 21,439 | 140.3 | 104.9 | 104.2 | 89.0 | 102.9 | 104.2
A45-74 | 26,272 | 160.9 | 125.0 | 162.2 | 108.5 | 122.5 | 125.0
A40-74 | 31,178 | 173.3 | 138.0 | 194.0 | 133.6 | 134.7 | 138.0
Stopping age 79
B50-79 | 12,456 | 138.9 | 84.3 | 91.4 | 84.7 | 77.5 | 84.7
B45-79 | 15,176 | 159.2 | 100.3 | 145.6 | 100.6 | 90.0 | 100.6
A45-49, B50-79 | 17,242 | 159.5 | 107.9 | 149.8 | 104.8 | 97.7 | 107.9
B40-79 | 17,354 | 170.3 | 107.8 | 168.6 | 123.2 | 97.0 | 123.2
A45-54, B55-79 | 19,876 | 162.5 | 115.9 | 154.3 | 107.6 | 106.1 | 115.9
A40-49, B50-79 | 22,150 | 172.0 | 121.8 | 183.4 | 128.3 | 109.6 | 128.3
A50-79 | 24,563 | 148.7 | 110.5 | 121.5 | 96.1 | 112.4 | 112.4
A45-79 | 29,389 | 169.3 | 131.5 | 180.0 | 113.1 | 132.0 | 132.0
A40-79 | 34,289 | 181.7 | 143.6 | 211.2 | 140.0 | 144.2 | 144.2

Abbreviations: A, annual; B, biennial; D, Dana-Farber Cancer Institute; E, Erasmus Medical Center; GE, Georgetown Lombardi Comprehensive Cancer Center-Albert Einstein College of Medicine; M, University of Texas MD Anderson Cancer Center; S, Stanford University; W, University of Wisconsin-Madison and Harvard Pilgrim Health Care Institute.

a Median number of mammograms across models. Strategies are ranked from the least to the most mammograms. Not all possible mammograms in the age interval are obtained because some people die of other causes before screening would occur.

b Without screening, the median probability of dying of breast cancer is 2.73% (range, 2.34%–3.75%). Thus, if a particular screening strategy leads to a 30% reduction in breast cancer mortality, the probability of breast cancer mortality is reduced from 2.73% to 1.91%. This translates into 8.2 deaths averted per 1,000 persons screened.

c Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

Appendix A Table 7 Lifetime Benefits of Mammography Screening With Digital Breast Tomosynthesis vs. No Screening for a Cohort of 1,000 40-Year-Old Female Persons According to Model and Screening Strategy

Strategy | Screens, n^a^ | Model | | | | | | Median
Strategy | Screens, n^a^ | D | E | GE | M | S | W | Median
Stopping age 74 | | Reduction in Breast Cancer Mortality per 1,000 Persons Screened vs. No Screening, %^b^
B50-74 | 11,208 | 29.4 | 25.3 | 18.8 | 26.1 | 25.5 | 20.3 | 25.4
B45-74 | 13,299 | 31.2 | 27.5 | 23.2 | 28.7 | 27.4 | 21.7 | 27.5
A45-49, B50-74 | 16,053 | 32.5 | 30.1 | 25.8 | 30.3 | 28.8 | 23.9 | 29.5
B40-74 | 16,116 | 33.7 | 29.6 | 27.5 | 32.6 | 30.4 | 24.0 | 30.0
A45-54, B55-74 | 18,072 | 32.1 | 30.8 | 24.7 | 30.1 | 29.6 | 24.4 | 29.9
A40-49, B50-74 | 20,979 | 34.4 | 32.5 | 29.4 | 33.8 | 31.9 | 26.1 | 32.2
A50-74 | 21,500 | 32.1 | 32.8 | 24.7 | 29.8 | 31.4 | 27.9 | 30.6
A45-74 | 26,349 | 35.3 | 36.5 | 31.6 | 34.0 | 34.3 | 31.4 | 34.1
A40-74 | 31,273 | 37.2 | 38.9 | 35.0 | 37.6 | 36.8 | 33.6 | 37.0
Stopping age 79
B50-79 | 12,488 | 32.2 | 27.9 | 24.9 | 29.1 | 28.1 | 23.6 | 28.0
B45-79 | 15,218 | 35.5 | 31.3 | 32.3 | 33.5 | 31.8 | 26.5 | 32.1
A45-49, B50-79 | 17,325 | 35.3 | 32.7 | 31.8 | 33.4 | 32.3 | 27.2 | 32.5
B40-79 | 17,397 | 36.5 | 32.2 | 33.5 | 35.9 | 33.1 | 27.2 | 33.3
A45-54, B55-79 | 19,980 | 36.4 | 34.7 | 33.7 | 34.5 | 32.9 | 29.2 | 34.1
A40-49, B50-79 | 22,255 | 37.2 | 35.1 | 35.4 | 36.7 | 34.1 | 29.4 | 35.3
A50-79 | 24,687 | 36.2 | 36.9 | 32.6 | 34.1 | 35.0 | 33.6 | 34.5
A45-79 | 29,517 | 39.4 | 40.8 | 39.5 | 38.4 | 38.7 | 37.1 | 39.1
A40-79 | 34,441 | 41.3 | 43.0 | 42.9 | 42.2 | 40.9 | 39.2 | 41.7
Stopping age 74 | | Life-Years Gained per 1,000 Persons Screened vs. No Screening
B50-74 | 11,208 | 175.8 | 119.2 | 115.1 | 122.4 | 125.4 | 116.1 | 120.8
B45-74 | 13,299 | 200.1 | 140.0 | 176.4 | 142.6 | 137.2 | 133.9 | 141.3
A45-49, B50-74 | 16,053 | 207.2 | 155.1 | 192.6 | 151.8 | 146.3 | 150.9 | 153.5
B40-74 | 16,116 | 221.9 | 155.7 | 218.0 | 174.7 | 152.4 | 152.4 | 165.2
A45-54, B55-74 | 18,072 | 207.9 | 163.2 | 190.5 | 151.2 | 148.2 | 158.9 | 161.1
A40-49, B50-74 | 20,979 | 228.6 | 177.8 | 240.1 | 184.5 | 163.9 | 174.6 | 181.2
A50-74 | 21,500 | 191.7 | 158.3 | 152.8 | 137.1 | 150.9 | 163.4 | 155.6
A45-74 | 26,349 | 222.9 | 189.1 | 230.1 | 165.7 | 171.7 | 197.5 | 193.3
A40-74 | 31,273 | 244.4 | 212.0 | 274.9 | 199.3 | 190.1 | 221.2 | 216.6
Stopping age 79
B50-79 | 12,488 | 184.1 | 124.9 | 135.2 | 133.1 | 119.6 | 125.4 | 129.3
B45-79 | 15,218 | 213.1 | 149.0 | 206.5 | 153.1 | 153.7 | 147.7 | 153.4
A45-49, B50-79 | 17,325 | 215.4 | 160.7 | 212.7 | 155.0 | 152.8 | 160.2 | 160.5
B40-79 | 17,397 | 230.2 | 161.8 | 237.8 | 181.2 | 166.7 | 161.7 | 173.9
A45-54, B55-79 | 19,980 | 220.8 | 172.7 | 220.6 | 161.0 | 161.0 | 172.6 | 172.7
A40-49, B50-79 | 22,255 | 236.9 | 184.2 | 260.1 | 193.2 | 173.4 | 183.9 | 188.7
A50-79 | 24,687 | 203.6 | 167.9 | 178.5 | 150.5 | 148.2 | 180.1 | 173.2
A45-79 | 29,517 | 234.9 | 200.0 | 255.8 | 176.1 | 177.2 | 214.1 | 207.1
A40-79 | 34,441 | 256.3 | 221.6 | 300.7 | 214.2 | 200.4 | 237.8 | 229.7
Stopping age 74 | | Breast Cancer Deaths Averted per 1,000 Persons Screened vs. No Screening
B50-74 | 11,208 | 9.2 | 7.5 | 7.0 | 6.1 | 6.4 | 5.1 | 6.7
B45-74 | 13,299 | 9.8 | 8.1 | 8.7 | 6.7 | 6.9 | 5.5 | 7.5
A45-49, B50-74 | 16,053 | 10.2 | 8.9 | 9.6 | 7.1 | 7.2 | 6.0 | 8.0
B40-74 | 16,116 | 10.6 | 8.7 | 10.3 | 7.6 | 7.6 | 6.1 | 8.2
A45-54, B55-74 | 18,072 | 10.0 | 9.1 | 9.2 | 7.1 | 7.4 | 6.2 | 8.2
A40-49, B50-74 | 20,979 | 10.8 | 9.5 | 11.0 | 7.9 | 8.0 | 6.6 | 8.8
A50-74 | 21,500 | 10.1 | 9.6 | 9.3 | 7.0 | 7.9 | 7.1 | 8.6
A45-74 | 26,349 | 11.0 | 10.7 | 11.8 | 8.0 | 8.6 | 7.9 | 9.7
A40-74 | 31,273 | 11.6 | 11.4 | 13.1 | 8.8 | 9.2 | 8.5 | 10.3
Stopping age 79
B50-79 | 12,488 | 10.1 | 8.2 | 9.3 | 6.8 | 7.0 | 6.0 | 7.6
B45-79 | 15,218 | 11.1 | 9.2 | 12.1 | 7.8 | 8.0 | 6.7 | 8.6
A45-49, B50-79 | 17,325 | 11.1 | 9.6 | 11.9 | 7.8 | 8.1 | 6.9 | 8.9
B40-79 | 17,397 | 11.4 | 9.5 | 12.5 | 8.4 | 8.3 | 6.9 | 8.9
A45-54, B55-79 | 19,980 | 11.4 | 10.2 | 12.6 | 8.1 | 8.2 | 7.4 | 9.2
A40-49, B50-79 | 22,255 | 11.6 | 10.3 | 13.3 | 8.6 | 8.5 | 7.4 | 9.5
A50-79 | 24,687 | 11.3 | 10.9 | 12.2 | 8.0 | 8.8 | 8.5 | 9.8
A45-79 | 29,517 | 12.3 | 12.0 | 14.8 | 9.0 | 9.7 | 9.4 | 10.9
A40-79 | 34,441 | 12.9 | 12.7 | 16.1 | 9.9 | 10.2 | 9.9 | 11.5
Stopping age 74 | | QALYs Gained per 1,000 Persons Screened vs. No Screening^c^
B50-74 | 11,208 | 143.0 | 85.3 | 81.7 | 86.9 | 92.0 | 77.9 | 86.1
B45-74 | 13,299 | 161.3 | 99.8 | 128.7 | 101.1 | 99.6 | 89.9 | 100.4
A45-49, B50-74 | 16,053 | 165.5 | 109.2 | 139.8 | 106.4 | 105.8 | 101.3 | 107.8
B40-74 | 16,116 | 177.0 | 109.5 | 159.1 | 124.0 | 109.5 | 101.4 | 116.8
A45-54, B55-74 | 18,072 | 165.1 | 114.6 | 137.4 | 105.2 | 106.6 | 106.9 | 110.7
A40-49, B50-74 | 20,979 | 179.2 | 122.8 | 173.6 | 128.6 | 115.9 | 115.5 | 125.7
A50-74 | 21,500 | 151.4 | 110.8 | 107.0 | 93.7 | 108.5 | 109.6 | 109.0
A45-74 | 26,349 | 173.8 | 131.5 | 164.8 | 112.8 | 121.5 | 132.5 | 132.0
A40-74 | 31,273 | 187.5 | 145.5 | 196.5 | 135.6 | 132.3 | 146.8 | 146.1
Stopping age 79
B50-79 | 12,488 | 150.1 | 89.0 | 96.2 | 94.4 | 87.7 | 83.7 | 91.7
B45-79 | 15,218 | 172.1 | 105.8 | 150.5 | 108.0 | 112.4 | 98.5 | 110.2
A45-49, B50-79 | 17,325 | 172.5 | 112.8 | 154.3 | 108.1 | 110.3 | 107.1 | 111.5
B40-79 | 17,397 | 184.2 | 113.6 | 173.4 | 128.2 | 120.2 | 107.2 | 124.2
A45-54, B55-79 | 19,980 | 175.9 | 120.8 | 159.2 | 111.6 | 115.9 | 115.4 | 118.4
A40-49, B50-79 | 22,255 | 186.4 | 127.0 | 188.1 | 134.4 | 122.8 | 121.4 | 130.7
A50-79 | 24,687 | 160.8 | 116.8 | 125.0 | 102.5 | 105.7 | 120.1 | 118.4
A45-79 | 29,517 | 183.2 | 138.6 | 182.9 | 119.5 | 124.9 | 143.0 | 140.8
A40-79 | 34,441 | 196.9 | 151.4 | 214.6 | 145.5 | 139.5 | 157.2 | 154.3

Abbreviations: A, annual; B, biennial; D, Dana-Farber Cancer Institute; E, Erasmus Medical Center; GE, Georgetown Lombardi Comprehensive Cancer Center-Albert Einstein College of Medicine; M, University of Texas MD Anderson Cancer Center; S, Stanford University; W, University of Wisconsin-Madison and Harvard Pilgrim Health Care Institute.

a Median number of mammograms across models. Strategies are ranked from the least to the most mammograms by stopping age. Not all possible mammograms in the age interval are obtained because some people die of other causes before screening would occur.

b Without screening, the median probability of dying of breast cancer is 2.73% (range, 2.34%–3.75%). Thus, if a particular screening strategy leads to a 30% reduction in breast cancer mortality, the probability of breast cancer mortality is reduced from 2.73% to 1.91%. This translates into 8.2 deaths averted per 1,000 persons screened.

c Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

Appendix A Table 8 Incremental Changes in Benefits and Harms for a Cohort of 1,000 Screened 40-Year-Old Female Persons: Comparison Strategies Limited to Strategies Efficient or Near-Efficient for Both Percent Breast Cancer Mortality Reduction and Life-Years Gained vs. No Screening in Most Models

Initial Strategy | Comparison Strategy^a^ | Added Screens^b^ | Change in Value by Model | | | | | | Median
Initial Strategy | Comparison Strategy^a^ | Added Screens^b^ | D | E | GE | M | S^c^ | W | Median
Breast Cancer Deaths Averted
DM B50-74 | DBT B50-74 | 0 | 0.6 | 0.3 | 0.2 | 0.2 | | 0.3 | 0.3
DM B50-74 | DBT B45-79 | 4,026 | 2.5 | 2.1 | 5.2 | 1.9 | | 1.9 | 2.1
DM B50-74 | DBT B40-79 | 6,205 | 2.8 | 2.3 | 5.7 | 2.5 | | 2.0 | 2.5
DM B50-74 | DBT A40-49, B50-79 | 11,063 | 3.0 | 3.2 | 6.4 | 2.7 | | 2.6 | 3.0
DM B50-74 | DBT A40-79 | 23,249 | 4.3 | 5.5 | 9.2 | 4.0 | | 5.1 | 5.1
DBT B50-74 | DBT B45-79 | 4,010 | 1.9 | 1.8 | 5.0 | 1.7 | 1.6 | 1.6 | 1.7
DBT B50-74 | DBT B40-79 | 6,189 | 2.3 | 2.0 | 5.5 | 2.3 | 1.9 | 1.7 | 2.1
DBT B50-74 | DBT A40-49, B50-79 | 11,047 | 2.5 | 2.9 | 6.2 | 2.5 | 2.1 | 2.3 | 2.5
DBT B50-74 | DBT A40-79 | 23,233 | 3.7 | 5.2 | 9.0 | 3.8 | 3.9 | 4.8 | 4.3
Life-Years Gained
DM B50-74 | DBT B50-74 | 0 | 10.8 | 4.6 | 3.7 | 5.5 | | 6.3 | 5.5
DM B50-74 | DBT B45-79 | 4,026 | 48.0 | 34.4 | 95.1 | 36.2 | | 37.9 | 37.9
DM B50-74 | DBT B40-79 | 6,205 | 65.2 | 47.2 | 126.4 | 64.4 | | 51.9 | 64.4
DM B50-74 | DBT A40-49, B50-79 | 11,063 | 71.9 | 69.6 | 148.7 | 76.3 | | 74.1 | 74.1
DM B50-74 | DBT A40-79 | 23,249 | 91.3 | 107.0 | 189.3 | 97.3 | | 128.0 | 107.0
DBT B50-74 | DBT B45-79 | 4,010 | 37.2 | 29.8 | 91.4 | 30.7 | 28.3 | 31.6 | 31.1
DBT B50-74 | DBT B40-79 | 6,189 | 54.4 | 42.6 | 122.7 | 58.8 | 41.2 | 45.7 | 50.0
DBT B50-74 | DBT A40-49, B50-79 | 11,047 | 61.1 | 65.0 | 145.0 | 70.8 | 48.0 | 67.8 | 66.4
DBT B50-74 | DBT A40-79 | 23,233 | 80.4 | 102.4 | 185.6 | 91.8 | 75.0 | 121.7 | 97.1
False-positive Recalls
DM B50-74 | DBT B50-74 | 0 | −150 | −149 | −149 | −148 | | −148 | −149
DM B50-74 | DBT B45-79 | 4,026 | 156 | 153 | 156 | 146 | | 150 | 153
DM B50-74 | DBT B40-79 | 6,205 | 421 | 416 | 421 | 407 | | 412 | 416
DM B50-74 | DBT A40-49, B50-79 | 11,063 | 741 | 727 | 738 | 716 | | 725 | 727
DM B50-74 | DBT A40-79 | 23,249 | 1,211 | 1,194 | 1,210 | 1,177 | | 1,172 | 1,194
DBT B50-74 | DBT B45-79 | 4,010 | 305 | 302 | 305 | 294 | 306 | 298 | 304
DBT B50-74 | DBT B40-79 | 6,189 | 571 | 566 | 569 | 556 | 571 | 560 | 568
DBT B50-74 | DBT A40-49, B50-79 | 11,047 | 890 | 877 | 887 | 864 | 889 | 873 | 882
DBT B50-74 | DBT A40-79 | 23,233 | 1,361 | 1,343 | 1,359 | 1,325 | 1,364 | 1,320 | 1,351
Benign Biopsies
DM B50-74 | DBT B50-74 | 0 | −12 | −12 | −12 | −12 | | −12 | −12
DM B50-74 | DBT B45-79 | 4,026 | 28 | 28 | 28 | 26 | | 28 | 28
DM B50-74 | DBT B40-79 | 6,205 | 62 | 61 | 62 | 59 | | 61 | 61
DM B50-74 | DBT A40-49, B50-79 | 11,063 | 99 | 98 | 99 | 94 | | 97 | 98
DM B50-74 | DBT A40-79 | 23,249 | 157 | 155 | 157 | 151 | | 152 | 155
DBT B50-74 | DBT B45-79 | 4,010 | 41 | 40 | 41 | 38 | 41 | 40 | 41
DBT B50-74 | DBT B40-79 | 6,189 | 74 | 74 | 74 | 71 | 74 | 73 | 74
DBT B50-74 | DBT A40-49, B50-79 | 11,047 | 112 | 110 | 111 | 106 | 112 | 109 | 111
DBT B50-74 | DBT A40-79 | 23,233 | 170 | 167 | 169 | 163 | 170 | 164 | 168

Abbreviations: A, annual; B, biennial; D, Dana-Farber Cancer Institute; E, Erasmus Medical Center; GE, Georgetown Lombardi Comprehensive Cancer Center-Albert Einstein College of Medicine; M, University of Texas MD Anderson Cancer Center; S, Stanford University; W, University of Wisconsin-Madison and Harvard Pilgrim Health Care Institute.

a DBT strategies were efficient or near-efficient in 5 or more out of 6 models for either incremental ratio shown in Table 10. Zero DM strategies were efficient or near-efficient in 4 or more out of 5 models for either incremental ratio.

b Median across six models.

c Model S did not evaluate strategies for digital mammography.

Appendix A Table 9 Benefits of Screening With Digital Mammography vs. No Screening for a Cohort of 1,000 40-Year-Old Black Female Persons by Model and Screening Strategy

Strategy | Screens, n^a^ | Model | | | | Median
Strategy | Screens, n^a^ | D | GE | M | W | Median
Stopping Age 74 | | Reduction in Breast Cancer Mortality per 1,000 Black Persons Screened vs. No Screening, %^b^
B50-74 | 10,905 | 24.9 | 25.2 | 20.5 | 18.5 | 22.7
B45-74 | 13,009 | 26.5 | 28.0 | 23.6 | 19.1 | 25.0
A45-49, B50-74 | 15,743 | 27.7 | 30.2 | 24.7 | 20.8 | 26.2
B40-74 | 15,801 | 28.6 | 31.0 | 27.2 | 20.8 | 27.9
A45-54, B55-74 | 17,772 | 27.5 | 29.3 | 24.4 | 21.1 | 26.0
A40-49, B50-74 | 20,677 | 29.4 | 32.5 | 28.1 | 22.3 | 28.7
A50-74 | 20,935 | 28.4 | 31.8 | 24.2 | 26.8 | 27.6
A45-74 | 25,760 | 31.2 | 36.8 | 28.3 | 28.9 | 30.1
A40-74 | 30,694 | 32.8 | 39.1 | 31.9 | 30.4 | 32.4
Stopping age 79
B50-79 | 12,072 | 27.8 | 30.0 | 23.5 | 22.4 | 25.6
B45-79 | 14,755 | 30.7 | 35.2 | 27.7 | 24.4 | 29.2
A45-49, B50-79 | 16,907 | 30.5 | 35.0 | 27.4 | 24.6 | 28.9
B40-79 | 16,966 | 31.5 | 35.8 | 30.1 | 24.6 | 30.8
A45-54, B55-79 | 19,518 | 31.8 | 36.5 | 28.7 | 26.4 | 30.2
A40-49, B50-79 | 21,846 | 32.3 | 37.5 | 30.9 | 26.1 | 31.6
A50-79 | 23,830 | 32.3 | 38.3 | 28.3 | 33.7 | 33.0
A45-79 | 28,644 | 35.1 | 43.3 | 32.3 | 35.8 | 35.4
A40-79 | 33,578 | 36.7 | 45.5 | 35.9 | 37.2 | 37.0
Stopping age 74 | | Life-Years Gained per 1,000 Black Persons Screened vs. No Screening
B50-74 | 10,905 | 185.3 | 211.9 | 121.7 | 141.7 | 163.5
B45-74 | 13,009 | 210.3 | 262.2 | 153.0 | 156.1 | 183.2
A45-49, B50-74 | 15,743 | 219.6 | 281.7 | 153.9 | 173.5 | 196.5
B40-74 | 15,801 | 232.8 | 297.5 | 195.1 | 174.0 | 214.0
A45-54, B55-74 | 17,772 | 222.0 | 278.7 | 159.9 | 183.4 | 202.7
A40-49, B50-74 | 20,677 | 242.8 | 318.4 | 203.1 | 195.8 | 223.0
A50-74 | 20,935 | 210.7 | 266.5 | 145.6 | 211.5 | 211.1
A45-74 | 25,760 | 244.8 | 336.0 | 186.4 | 242.3 | 243.6
A40-74 | 30,694 | 268.0 | 373.2 | 227.8 | 264.8 | 266.4
Stopping age 79
B50-79 | 12,072 | 196.9 | 233.2 | 131.3 | 156.7 | 176.8
B45-79 | 14,755 | 227.2 | 294.4 | 164.3 | 176.8 | 202.0
A45-49, B50-79 | 16,907 | 230.5 | 303.1 | 166.9 | 188.5 | 209.5
B40-79 | 16,966 | 244.4 | 318.5 | 206.3 | 189.0 | 225.4
A45-54, B55-79 | 19,518 | 238.9 | 311.1 | 172.7 | 204.0 | 221.5
A40-49, B50-79 | 21,846 | 254.4 | 343.5 | 210.7 | 210.6 | 232.6
A50-79 | 23,830 | 226.0 | 295.0 | 160.0 | 238.7 | 232.3
A45-79 | 28,644 | 260.1 | 364.4 | 189.3 | 269.4 | 264.8
A40-79 | 33,578 | 283.3 | 401.3 | 239.5 | 291.8 | 287.5
Stopping age 74 | | Breast Cancer Deaths Averted per 1,000 Black Persons Screened vs. No Screening
B50-74 | 10,905 | 9.9 | 12.2 | 6.5 | 7.2 | 8.5
B45-74 | 13,009 | 10.5 | 13.5 | 7.5 | 7.4 | 9.0
A45-49, B50-74 | 15,743 | 11.0 | 14.6 | 7.9 | 8.1 | 9.5
B40-74 | 15,801 | 11.3 | 14.9 | 8.7 | 8.1 | 10.0
A45-54, B55-74 | 17,772 | 10.9 | 14.1 | 7.8 | 8.2 | 9.6
A40-49, B50-74 | 20,677 | 11.6 | 15.7 | 9.0 | 8.7 | 10.3
A50-74 | 20,935 | 11.2 | 15.4 | 7.7 | 10.4 | 10.8
A45-74 | 25,760 | 12.3 | 17.8 | 9.0 | 11.3 | 11.8
A40-74 | 30,694 | 13.0 | 18.9 | 10.2 | 11.8 | 12.4
Stopping age 79
B50-79 | 12,072 | 11.0 | 14.5 | 7.5 | 8.7 | 9.9
B45-79 | 14,755 | 12.1 | 17.0 | 8.9 | 9.5 | 10.8
A45-49, B50-79 | 16,907 | 12.1 | 16.9 | 8.8 | 9.6 | 10.8
B40-79 | 16,966 | 12.4 | 17.3 | 9.6 | 9.6 | 11.0
A45-54, B55-79 | 19,518 | 12.6 | 17.6 | 9.2 | 10.3 | 11.4
A40-49, B50-79 | 21,846 | 12.8 | 18.1 | 9.9 | 10.2 | 11.5
A50-79 | 23,830 | 12.8 | 18.5 | 9.0 | 13.1 | 12.9
A45-79 | 28,644 | 13.9 | 20.9 | 10.3 | 14.0 | 13.9
A40-79 | 33,578 | 14.5 | 22.0 | 11.5 | 14.5 | 14.5
Stopping age 74 | | QALYs Gained per 1,000 Black Persons Screened vs. No Screening^c^
B50-74 | 10,905 | 138.8 | 153.6 | 82.6 | 94.1 | 116.5
B45-74 | 13,009 | 157.0 | 191.4 | 105.1 | 103.2 | 131.1
A45-49, B50-74 | 15,743 | 162.1 | 204.5 | 103.5 | 114.1 | 138.1
B40-74 | 15,801 | 172.3 | 216.3 | 135.5 | 113.6 | 153.9
A45-54, B55-74 | 17,772 | 162.9 | 200.9 | 106.8 | 120.7 | 141.8
A40-49, B50-74 | 20,677 | 176.0 | 228.7 | 137.6 | 126.3 | 156.8
A50-74 | 20,935 | 152.2 | 189.9 | 94.2 | 140.4 | 146.3
A45-74 | 25,760 | 175.5 | 240.5 | 121.8 | 159.6 | 167.5
A40-74 | 30,694 | 195.7 | 265.1 | 149.9 | 171.9 | 183.8
Stopping age 79
B50-79 | 12,072 | 147.1 | 168.5 | 88.9 | 103.7 | 125.4
B45-79 | 14,755 | 169.0 | 214.0 | 112.1 | 116.2 | 142.6
A45-49, B50-79 | 16,907 | 170.0 | 219.5 | 112.3 | 123.6 | 146.8
B40-79 | 16,966 | 180.6 | 231.0 | 142.9 | 123.1 | 161.7
A45-54, B55-79 | 19,518 | 174.8 | 223.7 | 114.9 | 133.7 | 154.2
A40-49, B50-79 | 21,846 | 184.3 | 246.7 | 142.2 | 135.7 | 163.2
A50-79 | 23,830 | 162.2 | 209.0 | 102.9 | 157.6 | 159.9
A45-79 | 28,644 | 185.5 | 259.6 | 121.7 | 176.8 | 181.1
A40-79 | 33,578 | 199.4 | 284.0 | 156.5 | 189.0 | 194.2

Abbreviations: A, annual; B, biennial; D, Dana-Farber Cancer Institute; E, Erasmus Medical Center; GE, Georgetown Lombardi Comprehensive Cancer Center-Albert Einstein College of Medicine; M, University of Texas MD Anderson Cancer Center; S, Stanford University; W, University of Wisconsin-Madison and Harvard Pilgrim Health Care Institute.

a Median number of mammograms across models. Strategies are ranked from the least to the most mammograms. Not all possible mammograms in the age interval are obtained because some people die of other causes before screening would occur.

b Without screening, the median probability of dying of breast cancer is 3.93% (range, 3.20%–4.82%). Thus, if a particular screening strategy leads to a 25.8% reduction in breast cancer mortality, the probability of breast cancer mortality is reduced from 3.93% to 2.91%. This translates into 10.1 deaths averted per 1,000 Black female persons screened.

c Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

Appendix A Table 10 Benefits of Screening With Digital Breast Tomosynthesis vs. No Screening for a Cohort of 1,000 40-Year-Old Black Female Persons by Model and Screening Strategy

Strategy | Screens, n^a^ | Model | | | | Median
Strategy | Screens, n^a^ | D | GE | M | W | Median
Stopping Age 74 | | Reduction in Breast Cancer Mortality per 1,000 Black Persons Screened vs. No Screening, %^b^
B50-74 | 10,905 | 27.1 | 26.1 | 22.1 | 19.8 | 24.1
B45-74 | 13,009 | 28.8 | 28.9 | 24.9 | 20.5 | 26.8
A45-49, B50-74 | 15,743 | 30.2 | 31.1 | 26.1 | 22.3 | 28.1
B40-74 | 15,801 | 31.1 | 31.9 | 28.7 | 22.4 | 29.9
A45-54, B55-74 | 17,771 | 29.9 | 30.1 | 25.9 | 22.6 | 27.9
A40-49, B50-74 | 20,676 | 31.9 | 33.6 | 29.9 | 24.0 | 30.9
A50-74 | 20,934 | 30.5 | 32.4 | 25.5 | 28.2 | 29.3
A45-74 | 25,759 | 33.5 | 37.3 | 30.0 | 30.6 | 32.1
A40-74 | 30,693 | 35.3 | 39.6 | 33.5 | 32.2 | 34.4
Stopping age 79
B50-79 | 12,073 | 30.2 | 31.0 | 24.9 | 24.1 | 27.6
B45-79 | 14,755 | 33.3 | 36.3 | 29.2 | 26.4 | 31.2
A45-49, B50-79 | 16,907 | 33.1 | 35.9 | 29.1 | 26.5 | 31.1
B40-79 | 16,965 | 34.2 | 36.8 | 31.8 | 26.6 | 33.0
A45-54, B55-79 | 19,517 | 34.4 | 37.5 | 30.3 | 28.5 | 32.4
A40-49, B50-79 | 21,846 | 35.1 | 38.4 | 32.8 | 28.2 | 33.9
A50-79 | 23,827 | 34.7 | 39.0 | 29.7 | 35.6 | 35.1
A45-79 | 28,646 | 37.7 | 43.9 | 34.0 | 38.1 | 37.9
A40-79 | 33,577 | 39.5 | 46.2 | 37.9 | 39.6 | 39.6
Stopping age 74 | | Life-Years Gained per 1,000 Black Persons Screened vs. No Screening
B50-74 | 10,905 | 201.8 | 219.8 | 127.8 | 151.5 | 176.7
B45-74 | 13,009 | 229.2 | 270.4 | 157.3 | 168.7 | 199.0
A45-49, B50-74 | 15,743 | 238.9 | 288.8 | 167.3 | 187.0 | 212.9
B40-74 | 15,801 | 253.9 | 305.7 | 203.8 | 189.0 | 228.9
A45-54, B55-74 | 17,771 | 241.0 | 285.8 | 165.4 | 197.3 | 219.1
A40-49, B50-74 | 20,676 | 264.2 | 329.5 | 214.6 | 213.1 | 239.4
A50-74 | 20,934 | 226.6 | 271.3 | 154.2 | 222.9 | 224.7
A45-74 | 25,759 | 263.6 | 340.3 | 196.2 | 257.9 | 260.8
A40-74 | 30,693 | 288.8 | 377.7 | 243.7 | 283.6 | 286.2
Stopping age 79
B50-79 | 12,073 | 214.3 | 241.7 | 142.0 | 168.1 | 191.2
B45-79 | 14,755 | 247.4 | 303.6 | 172.7 | 191.5 | 219.4
A45-49, B50-79 | 16,907 | 250.7 | 310.7 | 177.0 | 203.5 | 227.1
B40-79 | 16,965 | 266.3 | 328.1 | 210.7 | 205.4 | 238.5
A45-54, B55-79 | 19,517 | 259.2 | 318.7 | 180.7 | 220.0 | 239.6
A40-49, B50-79 | 21,846 | 276.6 | 351.4 | 225.4 | 229.5 | 253.1
A50-79 | 23,827 | 242.9 | 300.2 | 164.5 | 252.3 | 247.6
A45-79 | 28,646 | 279.9 | 369.0 | 209.5 | 287.2 | 283.6
A40-79 | 33,577 | 305.2 | 406.8 | 253.9 | 312.9 | 309.0
Stopping age 74 | | Breast Cancer Deaths Averted per 1,000 Black Persons Screened vs. No Screening
B50-74 | 10,905 | 10.7 | 12.6 | 7.1 | 7.7 | 9.2
B45-74 | 13,009 | 11.4 | 13.9 | 8.0 | 8.0 | 9.7
A45-49, B50-74 | 15,743 | 11.9 | 15.0 | 8.4 | 8.7 | 10.3
B40-74 | 15,801 | 12.3 | 15.4 | 9.2 | 8.7 | 10.7
A45-54, B55-74 | 17,771 | 11.8 | 14.5 | 8.3 | 8.8 | 10.3
A40-49, B50-74 | 20,676 | 12.6 | 16.2 | 9.6 | 9.4 | 11.1
A50-74 | 20,934 | 12.1 | 15.6 | 8.2 | 11.0 | 11.5
A45-74 | 25,759 | 13.3 | 18.0 | 9.6 | 11.9 | 12.6
A40-74 | 30,693 | 14.0 | 19.1 | 10.7 | 12.6 | 13.3
Stopping age 79
B50-79 | 12,073 | 12.0 | 15.0 | 8.0 | 9.4 | 10.7
B45-79 | 14,755 | 13.2 | 17.5 | 9.3 | 10.3 | 11.7
A45-49, B50-79 | 16,907 | 13.1 | 17.3 | 9.3 | 10.3 | 11.7
B40-79 | 16,965 | 13.5 | 17.8 | 10.2 | 10.4 | 12.0
A45-54, B55-79 | 19,517 | 13.6 | 18.1 | 9.7 | 11.1 | 12.4
A40-49, B50-79 | 21,846 | 13.9 | 18.5 | 10.5 | 11.0 | 12.4
A50-79 | 23,827 | 13.7 | 18.8 | 9.5 | 13.9 | 13.8
A45-79 | 28,646 | 14.9 | 21.2 | 10.9 | 14.8 | 14.9
A40-79 | 33,577 | 15.6 | 22.3 | 12.1 | 15.4 | 15.5
Stopping age 74 | | QALYs Gained per 1,000 Black Persons Screened vs. No Screening^c^
B50-74 | 10,905 | 156.2 | 163.8 | 91.3 | 105.1 | 130.6
B45-74 | 13,009 | 177.1 | 202.5 | 113.2 | 116.9 | 147.0
A45-49, B50-74 | 15,743 | 183.3 | 215.6 | 119.2 | 129.3 | 156.3
B40-74 | 15,801 | 195.0 | 228.4 | 148.0 | 130.1 | 171.5
A45-54, B55-74 | 17,771 | 184.2 | 212.5 | 117.2 | 136.7 | 160.5
A40-49, B50-74 | 20,676 | 200.4 | 244.6 | 153.5 | 146.0 | 177.0
A50-74 | 20,934 | 171.6 | 200.1 | 107.3 | 155.0 | 163.3
A45-74 | 25,759 | 198.6 | 251.8 | 137.3 | 179.0 | 188.8
A40-74 | 30,693 | 215.8 | 278.2 | 171.8 | 195.3 | 205.6
Stopping age 79
B50-79 | 12,073 | 165.6 | 179.6 | 101.4 | 116.1 | 140.9
B45-79 | 14,755 | 190.7 | 226.6 | 123.7 | 132.0 | 161.3
A45-49, B50-79 | 16,907 | 192.2 | 231.4 | 126.0 | 140.3 | 166.3
B40-79 | 16,965 | 204.5 | 244.6 | 152.6 | 141.0 | 178.5
A45-54, B55-79 | 19,517 | 197.8 | 236.3 | 127.7 | 151.8 | 174.8
A40-49, B50-79 | 21,846 | 209.9 | 260.4 | 161.3 | 157.0 | 185.6
A50-79 | 23,827 | 183.4 | 220.5 | 113.7 | 174.6 | 179.0
A45-79 | 28,646 | 210.4 | 272.1 | 146.0 | 198.5 | 204.5
A40-79 | 33,577 | 227.5 | 298.8 | 178.1 | 214.9 | 221.2

Abbreviations: A, annual; B, biennial; D, Dana-Farber Cancer Institute; E, Erasmus Medical Center; GE, Georgetown Lombardi Comprehensive Cancer Center-Albert Einstein College of Medicine; M, University of Texas MD Anderson Cancer Center; S, Stanford University; W, University of Wisconsin-Madison and Harvard Pilgrim Health Care Institute.

a Median number of mammograms across models. Strategies are ranked from the least to the most mammograms. Not all possible mammograms in the age interval are obtained because some people die of other causes before screening would occur.

b Without screening, the median probability of dying of breast cancer is 3.93% (range, 3.20%–4.82%). Thus, if a particular screening strategy leads to a 25.8% reduction in breast cancer mortality, the probability of breast cancer mortality is reduced from 3.93% to 2.91%. This translates into 10.1 deaths averted per 1,000 Black female persons screened.

c Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

Appendix A Table 11 Incremental Changes in Benefits and Harms for a Cohort of 1,000 Screened 40-Year-Old Black Female Persons: Comparison Strategies Limited to Strategies Efficient or Near-Efficient for Both Percent Breast Cancer Mortality Reduction and Life-Years Gained vs. No Screening in Most Models of Breast Cancer in Black Female Persons

Initial Strategy | Comparison Strategy^a^ | Added Screens^b^ | Change in Value by Model | | | | Median
Initial Strategy | Comparison Strategy^a^ | Added Screens^b^ | D | GE | M | W | Median
Breast Cancer Deaths Averted
DM B50-74 | DBT B45-79 | 3,850 | 3.3 | 5.3 | 2.8 | 3.1 | 3.2
DM B50-74 | DBT B40-79 | 6,060 | 3.7 | 5.6 | 3.6 | 3.1 | 3.7
DM B50-74 | DBT A40-79 | 22,672 | 5.8 | 10.1 | 5.6 | 8.2 | 7.0
DBT B50-74 | DBT B45-79 | 3,850 | 2.5 | 4.9 | 2.3 | 2.6 | 2.5
DBT B50-74 | DBT B40-79 | 6,060 | 2.8 | 5.2 | 3.1 | 2.6 | 3.0
DBT B50-74 | DBT A40-79 | 22,672 | 4.9 | 9.7 | 5.1 | 7.7 | 6.4
Life-Years Gained
DM B50-74 | DBT B45-79 | 3,850 | 62.1 | 91.7 | 50.9 | 49.8 | 56.5
DM B50-74 | DBT B40-79 | 6,060 | 81.0 | 116.3 | 89.0 | 63.7 | 85.0
DM B50-74 | DBT A40-79 | 22,672 | 119.9 | 194.9 | 132.1 | 171.2 | 151.7
DBT B50-74 | DBT B45-79 | 3,850 | 45.5 | 83.8 | 44.8 | 40.0 | 45.2
DBT B50-74 | DBT B40-79 | 6,060 | 64.5 | 108.4 | 82.9 | 53.9 | 73.7
DBT B50-74 | DBT A40-79 | 22,672 | 103.3 | 187.0 | 126.1 | 161.4 | 143.7
False-positive Recalls
DM B50-74 | DBT B45-79 | 3,850 | −156 | −155 | −158 | −158 | −157
DM B50-74 | DBT B40-79 | 6,060 | 63 | 63 | 63 | 58 | 63
DM B50-74 | DBT A40-79 | 22,672 | 812 | 814 | 808 | 791 | 810
DBT B50-74 | DBT B45-79 | 3,850 | 293 | 294 | 291 | 290 | 292
DBT B50-74 | DBT B40-79 | 6,060 | 513 | 513 | 512 | 506 | 512
DBT B50-74 | DBT A40-79 | 22,672 | 1,262 | 1,263 | 1,257 | 1,238 | 1,259
Benign Biopsies
DM B50-74 | DBT B45-79 | 3,850 | 20 | 20 | 20 | 19 | 19.80
DM B50-74 | DBT B40-79 | 6,060 | 57 | 57 | 57 | 56 | 57.04
DM B50-74 | DBT A40-79 | 22,672 | 135 | 135 | 134 | 131 | 134.37
DBT B50-74 | DBT B45-79 | 3,850 | 50 | 50 | 49 | 49 | 49.38
DBT B50-74 | DBT B40-79 | 6,060 | 87 | 87 | 87 | 86 | 86.62
DBT B50-74 | DBT A40-79 | 22,672 | 164 | 165 | 164 | 161 | 163.95

Abbreviations: A, annual; B, biennial; D, Dana-Farber Cancer Institute; GE, Georgetown Lombardi Comprehensive Cancer Center-Albert Einstein College of Medicine; M, University of Texas MD Anderson Cancer Center; W, University of Wisconsin-Madison and Harvard Pilgrim Health Care Institute.

a Comparison strategies were efficient or near-efficient in 3 or more out of 4 models for both incremental ratios shown in Table 17. Zero DM strategies were efficient or near-efficient in 3 or more out of 4 models for either incremental ratio.

b Median across models.

Appendix A Table 12 Median Values (Range Across Four Models) for Harm-to-Benefit Ratios With Digital Breast Tomosynthesis Compared With No Screening for a Cohort of 1,000 40-Year-Old Female Persons (All Races) and 1,000 40-Year-Old Black Female Persons

Strategy Interval, Start and Stop Age | False-positive Recalls per Breast Cancer Death Averted | | Mammograms per Breast Cancer Death Averted | | Mammograms to Obtain 1 Percentage Point Reduction in Breast Cancer Mortality
Strategy Interval, Start and Stop Age | All | Black | All | Black | All | Black
Biennial
B50-74 | 132.8 (95.6-166.5) | 90.3 (64.7-115.0) | 1,709 (1,228-2,137) | 1,209 (869-1,539) | 483 (384-598) | 456 (403-546)
B45-74 | 141.5 (111.3-193.2) | 106.0 (71.7-124.9) | 1,750 (1,371-2,376) | 1,381 (937-1,630) | 517 (429-600) | 487 (452-631)
B40-74 | 156.2 (131.1-223.5) | 119.2 (81.6-142.5) | 1,837 (1,536-2,613) | 1,501 (1,031-1,798) | 541 (481-660) | 529 (497-701)
Hybrid
A45-49, B50-74 | 150.7 (122.8-202.0) | 113.6 (76.6-136.5) | 1,960 (1,588-2,610) | 1,560 (1,054-1,879) | 576 (497-659) | 562 (509-700)
A45-54, B55-74 | 163.9 (132.0-209.8) | 120.5 (84.1-146.1) | 2,257 (1,812-2,877) | 1,756 (1,227-2,134) | 662 (567-736) | 640 (592-781)
A40-49, B50-74 | 184.5 (154.3-252.3) | 141.1 (95.0-162.8) | 2,301 (1,917-3,127) | 1,900 (1,282-2,195) | 668 (614-790) | 670 (618-855)
Annual
A50-74 | 157.6 (127.8-181.3) | 104.6 (77.5-148.0) | 2,654 (2,153-3,062) | 1,812 (1,344-2,562) | 734 (674-874) | 711 (649-820)
A45-74 | 176.6 (139.6-203.9) | 122.0 (85.8-159.7) | 2,822 (2,237-3,288) | 2,040 (1,436-2,676) | 795 (751-837) | 801 (693-856)
A40-74 | 207.9 (160.5-242.2) | 145.2 (101.2-179.5) | 3,117 (2,398-3,603) | 2,310 (1,613-2,853) | 872 (826-910) | 892 (778-942)
Biennial
B50-79 | 118.5 (93.7-153.7) | 83.9 (59.3-111.3) | 1,585 (1,249-2,045) | 1,143 (810-1,513) | 465 (391-517) | 442 (391-497)
B45-79 | 127.2 (97.6-172.0) | 95.4 (63.4-118.4) | 1,653 (1,266-2,218) | 1,271 (847-1,580) | 463 (431-561) | 474 (409-554)
B40-79 | 148.0 (115.2-205.7) | 112.4 (74.7-130.4) | 1,795 (1,394-2,477) | 1,439 (959-1,666) | 502 (479-626) | 515 (463-632)
Hybrid
A45-49, B50-79 | 141.6 (110.1-186.8) | 105.0 (70.4-130.3) | 1,889 (1,464-2,474) | 1,457 (979-1,810) | 532 (494-625) | 545 (472-632)
A45-54, B55-79 | 148.8 (112.4-187.9) | 108.2 (73.6-136.5) | 2,111 (1,593-2,653) | 1,590 (1,084-2,008) | 586 (552-670) | 605 (523-680)
A40-49, B50-79 | 176.4 (132.9-232.6) | 130.6 (86.8-152.9) | 2,249 (1,687-2,944) | 1,775 (1,182-2,074) | 617 (602-744) | 644 (570-768)
Annual
A50-79 | 142.9 (115.6-174.1) | 97.4 (72.1-142.6) | 2,506 (2,033-3,075) | 1,715 (1,272-2,511) | 716 (686-761) | 674 (614-803)
A45-79 | 164.9 (120.5-194.3) | 112.6 (79.7-154.2) | 2,738 (2,007-3,262) | 1,915 (1,358-2,627) | 759 (751-774) | 752 (655-840)
A40-79 | 196.4 (138.9-221.8) | 132.7 (93.2-170.6) | 3,034 (2,155-3,468) | 2,149 (1,513-2,761) | 826 (807-855) | 844 (730-883)

Abbreviations: A, annual; B, biennial.

All values presented for four models (D, GE, M, W). Grey shading highlights strategies where median values for Black female persons are greater than values for female persons overall.

Appendix A Table 13 Sensitivity Analysis of Benefits of Screening Strategies Compared With No Screening for a Cohort of 1,000 40-Year-Old Female Persons With Either Population Dissemination Patterns of Treatment Utilization or With All Breast Cancer Cases Receiving the Most Effective Treatment Regimen

Strategy Interval, Start and Stop Age^a^ | Reduction in Breast Cancer Mortality, % | | | Breast Cancer Deaths Averted
Strategy Interval, Start and Stop Age^a^ | Treatment Dissemination | Most Effective Treatment | Difference | Treatment Dissemination | Most Effective Treatment | Difference
Biennial
B50-74 | 25.3 (18.8-29.4) | 30.4 (24.7-33.7) | +4.4 (2.4-13.5) | 7.0 (5.1-9.2) | 6.8 (3.9-9.3) | 0 (−1.3-2.2)
B45-74 | 27.5 (21.7-31.2) | 33.3 (26.7-36.0) | +4.8 (2.6-11.8) | 8.1 (5.5-9.8) | 7.3 (4.2-10.0) | 0 (−1.3-1.4)
B40-74 | 29.6 (24.0-33.7) | 37.5 (30.1-38.9) | +5.1 (3.0-10.2) | 8.7 (6.1-10.6) | 7.9 (4.7-10.8) | 0 (−1.4-0.5)
Hybrid
A45-54, B55-74 | 30.1 (24.4-32.1) | 34.8 (30.4-37) | +4.9 (2.9-11.7) | 9.1 (6.2-10.0) | 8.2 (4.8-10.4) | 0 (−1.4-1.2)
A40-49, B50-74 | 32.5 (26.1-34.4) | 38.9 (33-39.6) | +5.2 (3.2-9.7) | 9.5 (6.6-11.0) | 8.7 (5.2-11.2) | 0 (−1.4-0.2)
Annual
A50-74 | 29.8 (24.7-32.8) | 35.7 (32.6-37.4) | +4.6 (2.9-12.6) | 9.3 (7.0-10.1) | 8.7 (5.1-10.7) | −0.1 (−1.9-1.5)
A45-74 | 34.0 (31.4-36.5) | 40.0 (37.6-42.0) | +5.0 (3.4-10.3) | 10.7 (7.9-11.8) | 9.7 (5.9-12.0) | −0.1 (−2.0-0.2)
A40-74 | 37.2 (33.6-38.9) | 42.6 (40.8-44.0) | +5.3 (3.9-9.0) | 11.4 (8.5-13.1) | 10.4 (6.4-12.6) | −0.5 (−2.1-0)
| Life-Years Gained | | | QALYs Gained^b^
| Treatment Dissemination | Most Effective Treatment | Difference | Treatment Dissemination | Most Effective Treatment | Difference
Biennial
B50-74 | 119.2 (115.1-175.8) | 131.8 (100.2-175.3) | −0.6 (−15.9-47.3) | 85.3 (77.9-143.0) | 94.2 (66.2-144.7) | +1.7 (−11.7-38.3)
B45-74 | 142.6 (133.9-200.1) | 152.7 (115.9-199.9) | −0.2 (−18.0-14.2) | 101.1 (89.9-161.3) | 108.8 (76.5-163.4) | +2.1 (−13.4-12.0)
B40-74 | 174.7 (152.4-221.9) | 179.7 (134.6-221.7) | −9.3 (−17.8-5.0) | 124.0 (101.4-17.07) | 128.0 (88.2-179.2) | −6.6 (−13.2-4.0)
Hybrid
A45-54, B55-74 | 163.2 (151.2-207.9) | 157.9 (138.2-207.2) | −0.6 (−20.7-9.8) | 114.6 (105.2-165.1) | 110.4 (91.4-166.8) | +1.7 (−15.4-8.6)
A40-49, B50-74 | 184.5 (174.6-240.1) | 191.2 (153.9-228.0) | −12.3 (−20.7-6.7) | 128.6 (115.5-179.2) | 133.7 (100.1-181.1) | −9.0 (−15.4-5.2)
Annual
A50-74 | 158.3 (137.1-191.7) | 147.9 (135.4-190.0) | −1.7 (−27.9-34.7) | 109.6 (93.7-151.4) | 102.2 (88.9-152.3) | +0.9 (−20.7-28.6)
A45-74 | 197.5 (165.7-230.1) | 175.0 (166.4-225.9) | −4.2 (−31.1-8.6) | 132.5 (112.8-173.8) | 121.3 (109.4-174.7) | −2.1 (−23.1-6.6)
A40-74 | 221.2 (199.3-274.9) | 205.3 (188.9-245.7) | −14.8 (−32.3-6.0) | 146.8 (135.6-196.5) | 140.2 (122.7-188.6) | −10.8 (−24.1-4.6)

a All strategies use digital breast tomosynthesis. Median and range of values across five models (D, GE, E, M, and W) are shown.

b Adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

Appendix A Table 14 Comparison of Lifetime QALYs Gained From the Base Case (Using EQ-5D for Age-Specific Utilities) to a Sensitivity Analysis (Using SF-6D) According to Screening Strategy for Cohorts of 1,000 40-Year-Old Female Persons Overall and 1,000 40-Year-Old Black Female Persons

Strategy Interval, Start and Stop Age^a^ | QALYs for All Female Persons | | | QALYs for Black Female Persons
Strategy Interval, Start and Stop Age^a^ | Base Case (EQ-5D)^b^ | Sensitivity Analysis (SF-6D) | Difference | Base Case (EQ-5D)^c^ | Sensitivity Analysis (SF-6D) | Difference
Biennial
B50-74^d,e^ | 86.1 (77.9-143.0) | 82.4 (74.8-136.6) | 3.7 (2.4-6.4) | 130.6 (91.3-163.8) | 125.0 (87.4-157.0) | 5.5 (3.9-7.0)
B45-74^d,e^ | 100.4 (89.9-161.3) | 96.0 (86.2-153.9) | 4.4 (3.7-7.4) | 147.0 (113.2-202.5) | 140.4 (108-193.4) | 6.8 (4.9-9.1)
B40-74^d^ | 116.8 (101.4-177) | 111.4 (97.1-168.7) | 5.4 (4.2-8.4) | 171.5 (130.1-228.4) | 163.1 (124.5-217.7) | 8.4 (5.5-10.7)
Hybrid
A45-49, B50-74 | 107.8 (101.3-165.5) | 103.1 (97.0-157.9) | 4.7 (4.2-7.6) | 156.3 (119.2-215.6) | 149.3 (113.8-205.8) | 7.0 (5.5-9.8)
A45-54, B55-74 | 110.7 (105.2-165.1) | 106.0 (100.5-157.6) | 4.8 (4.5-7.5) | 160.5 (117.2-212.5) | 153.3 (111.8-202.9) | 7.2 (5.4-9.6)
A40-49, B50-74 | 125.7 (115.5-179.2) | 119.9 (110.6-170.9) | 5.8 (4.9-8.4) | 177.0 (146.0-244.6) | 168.3 (139.7-233.0) | 8.6 (6.3-11.6)
Annual
A50-74 | 109.0 (93.7-151.4) | 104.6 (89.7-144.8) | 4.4 (3.4-6.6) | 163.3 (107.3-200.1) | 156.4 (102.8-191.8) | 6.9 (4.6-8.2)
A45-74 | 132.0 (112.8-173.8) | 126.5 (107.9-166.0) | 5.5 (5.0-7.8) | 188.8 (137.3-251.8) | 180.5 (131.1-240.6) | 8.3 (6.2-11.2)
A40-74 | 146.1 (132.3-196.5) | 139.9 (126.8-187.9) | 6.3 (5.5-8.6) | 205.6 (171.8-278.2) | 196.3 (163.3-265.3) | 9.3 (8.3-12.9)
| QALYs for All Female Persons | | | QALYs for Black Female Persons
| Base Case (EQ-5D)^b^ | Sensitivity Analysis (SF-6D) | Difference | Base Case (EQ-5D)^c^ | Sensitivity Analysis (SF-6D) | Difference
Biennial
B50-79 | 91.7 (83.7-150.1) | 87.8 (80.4-143.5) | 3.7 (2.9-6.6) | 140.9 (101.4-179.6) | 134.9 (97.0-172.3) | 6.0 (4.4-7.3)
B45-79^d,e^ | 110.2 (98.5-172.1) | 105.3 (94.6-164.3) | 4.9 (4-7.8.0) | 161.3 (123.7-226.6) | 154.3 (118.1-216.6) | 7.2 (5.4-10.0)
B40-79^d,e^ | 124.2 (107.2-184.2) | 118.5 (102.8-175.6) | 5.7 (4.4-8.6) | 178.5 (141.0-244.6) | 169.8 (135.1-233.3) | 8.7 (5.9-11.3)
Hybrid
A45-49, B50-79 | 111.5 (107.1-172.5) | 106.8 (102.7-164.7) | 4.8 (4.4-7.8) | 166.3 (126.0-231.4) | 158.9 (120.3-221.1) | 7.3 (5.7-10.3)
A45-54, B55-79 | 118.4 (111.6-175.9) | 113.3 (106.7-167.9) | 5.1 (4.8-7.9) | 174.8 (127.7-236.3) | 167.1 (121.9-225.9) | 7.7 (5.8-10.4)
A40-49, B50-79^d,e^ | 130.7 (121.4-188.1) | 124.8 (116.3-179.8) | 5.9 (5.1-8.6) | 185.6 (157.0-260.4) | 176.6 (150.3-248.3) | 9.0 (6.7-12.1)
Annual
A50-79 | 118.4 (102.5-160.8) | 113.7 (98.1-153.8) | 4.5 (4.0-6.9) | 179.0 (113.7-220.5) | 171.5 (108.9-211.5) | 7.4 (4.8-8.9)
A45-79 | 140.8 (119.5-183.2) | 135.0 (114.2-175.6) | 5.8 (5.0-8.1) | 204.5 (146.0-272.1) | 195.6 (139.5-260.2) | 8.8 (6.5-11.9)
A40-79^d,e^ | 154.3 (139.5-214.6) | 147.8 (133.7-205.4) | 6.6 (5.8-9.2) | 221.2 (178.1-298.8) | 211.4 (169.5-285.2) | 9.8 (8.6-13.6)

Abbreviations: A, annual; B, biennial; QALYs, quality-adjusted life-years.

a All strategies use digital breast tomosynthesis. QALYs adjusted for general health, mammography screening, breast cancer diagnosis, and breast cancer treatment.

b Same as shown in Table 5. Results shown for six models (D, GE, E, M, S, and W).

c Same as shown in Table 11. Results shown for four models (D, GE, M, and W).

d Efficient or near-efficient based on an incremental ratio defined as the change in the number of mammograms/change in QALYs gained for female persons overall. Ratios for each strategy were calculated relative to the next efficient or near-efficient strategy with fewer mammograms, not necessarily shown in the order listed in the table (varied across models). DBT strategies are indicated that were efficient or near-efficient in 5 or more out of 6 models. Zero DM strategies were efficient or near-efficient in 4 or more out of 5 models. Strategies were considered near-efficient if they were within 1.57 quality-adjusted days per person of the efficiency frontier for female persons overall.

e Efficient or near-efficient based on an incremental ratio defined as the change in the number of mammograms/change in QALYs gained for Black female persons. Ratios for each strategy were calculated relative to the next efficient or near-efficient strategy with fewer mammograms, not necessarily shown in the order listed in the table (varied across models). DBT strategies are indicated that were efficient or near-efficient in 3 or more out of 4 models. Zero DM strategies were efficient or near-efficient in at least 3 models. Strategies were considered near-efficient if they were within 2.33 quality-adjusted days per person of the efficiency frontier for Black female persons.