# References

1 Siu AL. Screening for Breast Cancer: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2016;164(4):279–296.26757170
2 The Breast : Comprehensive Management of Benign and Malignant Disorders, 3rd Edition. Vol 3. St. Louis: WB Saunders; 2004.
3 Dillon D, Guidi A, Schnitt S. Ch 25: Pathology of Invasive Breast Cancer. In: Harris J, Lippman M, Morrow M, Osborne C, eds. Diseases of the Breast. 5th ed. Philadelphia: Lippincott-Williams & Wilkins; 2014.
4 Corben A, Brogi E. Ch 21: Ductal Carcinoma In Situ and Other Intraductal Lesions: Pathology, Immunochemistry, and Molecular Alterations. In: Harris J, Lippman M, Morrow M, Osborne C, eds. Diseases of the Breast. 5th ed. Philadelphia: Lippincott-Williams & Wilkins; 2014.
5 Burstein HJ, Polyak K, Wong JS, Lester SC, Kaelin CM. Ductal carcinoma in situ of the breast. N Engl J Med. 2004;350(14):1430–1441.15070793
6 King T, Reis-Filho J. Ch 22: Lobular Carcinoma In Situ: Biology and Management. In: Harris J, Lippman M, Morrow M, Osborne C, eds. Diseases of the Breast. 5th ed. Philadelphia: Lippincott-Williams & Wilkins; 2014.
7 Houghton J, George WD, Cuzick J, Duggan C, Fentiman IS, Spittle M. Radiotherapy and tamoxifen in women with completely excised ductal carcinoma in situ of the breast in the UK, Australia, and New Zealand: randomised controlled trial. Lancet. 2003;362(9378):95–102.12867108
8 Schwartz G. Biology and Management of Lobular Carcinoma In Situ of the Breast. In: Bland K, Copeland E, eds. The Breast : Comprehensive Management of Benign and Malignant Disorders, 3rd Edition. 3rd ed. St Louis: Saunders; 2004.
9 U.S. Cancer Statistics Working Group. U.S. Cancer Statistics Visualizations Tool, based on 2020 submission data (1999-2018). U.S. Department of Health and Human Services, Cancers for Disease Control and Prevention and National Cancer Institute. https://gis.cdc.gov/Cancer/USCS/#/AtAGlance/ Updated June 2021. Accessed May 22, 2022.
10 SEER Explorer. Breast Cancer: SEER 5-year Age-Adjusted Incidence Rates, 2015-2019. National Institutes of Health and National Cancer Institute. https://seer.cancer.gov/explorer/application.html. Published 2022. Accessed February 16, 2023.
11 National Cancer Institute (NCI) Surveillance Epidemiology and End Results (SEER) Program. Cancer Stat Facts: Female Breast Cancer. National Institutes of Health and National Cancer Institute. https://seer.cancer.gov/statfacts/html/breast.html. Published 2020. Accessed March 3, 2023.
12 American Cancer Society. Cancer Facts & Figures 2019. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/annual-cancer-facts-and-figures/2019/cancer-facts-and-figures-2019.pdf. Published 2019. Accessed March 10, 2023.
13 U.S. Cancer Statistics Working Group. U.S. Cancer Statistics Data Visualizations Tool, based on 2019 submission data (1999-2017). Centers for Disease Control and Prevention and National Cancer Institute. www.cdc.gov/cancer/dataviz. Published 2020. Updated June, 2020. Accessed September 24, 2020.
14 Giaquinto AN, Sung H, Miller KD, . Breast Cancer Statistics, 2022. CA Cancer J Clin. 2022;72(6):524–541.36190501
15 Cronin KA, Scott S, Firth AU, . Annual report to the nation on the status of cancer, part 1: National cancer statistics. Cancer. 2022;128(24):4251–4284.36301149
16 Surveillance Epidemiology and End Results (SEER) Program. SEER*Stat Database: Incidence - SEER Research Limited-Field Data with Delay-Adjustment, 22 Registries, Malignant Only, Nov 2021 Sub (2000-2019) - Linked To County Attributes - Time Dependent (1990-2019) Income/Rurality, 1969-2020 Counties. National Cancer Institute, DCCPS, Surveillance Research Program;Released April 2022, based on the November 2021 submission.
17 Melkonian SC, Jim MA, Haverkamp D, . Disparities in Cancer Incidence and Trends among American Indians and Alaska Natives in the United States, 2010-2015. Cancer Epidemiol Biomarkers Prev. 2019;28(10):1604–1611.31575554
18 Iqbal J, Ginsburg O, Rochon PA, Sun P, Narod SA. Differences in breast cancer stage at diagnosis and cancer-specific survival by race and ethnicity in the United States. JAMA. 2015;313(2):165–173.25585328
19 DeSantis CE, Ma J, Gaudet MM, . Breast cancer statistics, 2019. CA Cancer J Clin. 2019;69(6):438–451.31577379
20 Jatoi I, Sung H, Jemal A. The Emergence of the Racial Disparity in U.S. Breast-Cancer Mortality. N Engl J Med. 2022;386(25):2349–2352.35713541
21 American Association for Cancer Research. AACR Cancer Disparities Progress Report 2020. http://www.CancerDisparitiesProgressReport.org. Published 2020. Accessed September 23, 2020.
22 National Center for Health Statistics. Table 033: Use of mammography among women aged 40 and over, by selected characteristics: United States, selected years 1987–2015. Centers for Disease Control and Prevention. Health, United States, 2018 – Data Finder Web site. https://www.cdc.gov/nchs/hus/contents2018.htm#Table_033. Published 2019. Accessed Oct 27, 2020.
23 SEER Explorer. Breast Cancer: U.S Mortality Rates by Age at Death, 2016-2020. National Institutes of Health and National Cancer Institute. https://seer.cancer.gov/explorer/application.html. Published 2022. Accessed February 16, 2023.
24 SEER Explorer. Breast Cancer: SEER 5-Year Relative Survival Rates, 2012-2018. National Institutes of Health and National Cancer Institute. https://seer.cancer.gov/explorer/application.html. Published 2022. Accessed February 16, 2023.
25 Rodgers KM, Udesky JO, Rudel RA, Brody JG. Environmental chemicals and breast cancer: An updated review of epidemiological literature informed by biological mechanisms. Environ Health.160:152–182.
26 National Cancer Institute. Breast Cancer and the Environment: Controversial and Emerging Exposures Workshop Summary. National Institutes of Health. https://www.cancer.gov/research/areas/causes/breast-cancer-environment. Published 2021. Accessed June 2, 2022.
27 Kresovich JK, Xu Z, O’Brien KM, Weinberg CR, Sandler DP, Taylor JA. Methylation-based biological age and breast cancer risk. Journal of the National Cancer Institute. 2019;111(10):1051–1058.30794318
28 O’Brien KM, Sandler DP, Taylor JA, Weinberg CR. Serum vitamin D and risk of breast cancer within five years. Environ Health Perspect. 2017;125(7):077004.28728134
29 Park YM, O’Brien KM, Zhao S, Weinberg CR, Baird DD, Sandler DP. Gestational diabetes mellitus may be associated with increased risk of breast cancer. Br J Cancer. 2017;116(7):960–963.28208154
30 White AJ, Weinberg CR, Park YM, . Sleep characteristics, light at night and breast cancer risk in a prospective cohort. Int J Cancer. 2017;141(11):2204–2214.28791684
31 Lawson JS, Günzburg WH, Whitaker NJ. Viruses and human breast cancer. Future Microbiol. 2006;1(1):33–51.17661684
32 American Cancer Society. Breast Cancer Facts & Figures 2019-2020. American Cancer Society, Inc. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/breast-cancer-facts-and-figures/breast-cancer-facts-and-figures-2019-2020.pdf. Published 2019. Accessed March 8, 2023.
33 National Comprehensive Cancer Network. NCCN Guidelines: Breast Cancer Screening and Diagnosis. https://www.nccn.org/guidelines/nccn-guidelines/guidelines-detail?category=2&id=1421. Published 2022. Accessed March 10, 2023.
34 Allison KH, Hammond MEH, Dowsett M, . Estrogen and progesterone receptor testing in breast cancer: ASCO/CAP Guideline update. J Clin Oncol. 2020;38(12):1346–1366.31928404
35 Zhu X, Chen L, Huang B, . The prognostic and predictive potential of Ki-67 in triple-negative breast cancer. Sci Rep. 2020;10(1):225.31937819
36 Plevritis SK, Munoz D, Kurian AW, . Association of Screening and Treatment With Breast Cancer Mortality by Molecular Subtype in US Women, 2000-2012. JAMA. 2018;319(2):154–164.29318276
37 Surveillance Epidemiology and End Results Program. Cancer Stat Facts: Female Breast Cancer Subtypes. National Institutes of Health and National Cancer Institute. https://seer.cancer.gov/statfacts/html/breast.html. Published 2020. Accessed March 3, 2023.
38 Howlader N, Cronin KA, Kurian AW, Andridge R. Differences in Breast Cancer Survival by Molecular Subtypes in the United States. Cancer Epidemiol Biomarkers Prev. 2018;27(6):619–626.29593010
39 Evans A, Pinder S, Wilson R, . Ductal carcinoma in situ of the breast: correlation between mammographic and pathologic findings. AJR Am J Roentgenol. 1994;162(6):1307–1311.8191988
40 Neal CH, Joe AI, Patterson SK, Pujara AC, Helvie MA. Digital Mammography Has Persistently Increased High-Grade and Overall DCIS Detection Without Altering Upgrade Rate. AJR Am J Roentgenol. 2021;216(4):912–918.33594910
41 Erbas B, Provenzano E, Armes J, Gertig D. The natural history of ductal carcinoma in situ of the breast: a review. Breast Cancer Res Treat. 2006;97(2):135–144.16319971
42 Chootipongchaivat S, van Ravesteyn NT, Li X, . Modeling the natural history of ductal carcinoma in situ based on population data. Breast Cancer Res. 2020;22(1):53.32460821
43 Gorringe KL, Fox SB. Ductal carcinoma in situ biology, biomarkers, and diagnosis. Front Oncol. 2017;7:248.29109942
44 Giannakeas V, Sopik V, Narod SA. Association of a Diagnosis of Ductal Carcinoma In Situ With Death From Breast Cancer. JAMA Netw Open. 2020;3(9):e2017124.32936299
45 Hwang ES, Miglioretti DL, Ballard-Barbash R, Weaver DL, Kerlikowske K. Association between breast density and subsequent breast cancer following treatment for ductal carcinoma in situ. Cancer Epidemiol Biomarkers Prev. 2007;16(12):2587–2593.18086762
46 Allegra CJ, Aberle DR, Ganschow P, . NIH state-of-the-science conference statement: diagnosis and management of ductal carcinoma in situ (DCIS). NIH Consens State Sci Statements. 2009;26(2):1–27.
47 Visser LL, Groen EJ, van Leeuwen FE, Lips EH, Schmidt MK, Wesseling J. Predictors of an invasive breast cancer recurrence after DCIS: a systematic review and meta-analyses. Cancer Epidemiol Biomarkers Prev. 2019;28(5):835–845.31023696
48 Nelson HD, Pappas M, Cantor A, Haney E, Holmes R. Risk Assessment, Genetic Counseling, and Genetic Testing for BRCA-Related Cancer in Women: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2019;322(7):666–685.31429902
49 Owens DK, Davidson KW, Krist AH, . Risk Assessment, Genetic Counseling, and Genetic Testing for BRCA-Related Cancer: US Preventive Services Task Force Recommendation Statement. JAMA. 2019;322(7):652–665.31429903
50 Nelson HD, Zakher B, Cantor A, . Risk factors for breast cancer for women aged 40 to 49 years: a systematic review and meta-analysis. Ann Intern Med. 2012;156(9):635–648.22547473
51 Familial breast cancer: collaborative reanalysis of individual data from 52 epidemiological studies including 58,209 women with breast cancer and 101,986 women without the disease. Lancet. 2001;358(9291):1389–1399.11705483
52 Braithwaite D, Miglioretti DL, Zhu W, . Family History and Breast Cancer Risk Among Older Women in the Breast Cancer Surveillance Consortium Cohort. JAMA internal medicine. 2018;178(4):494–501.29435563
53 McCormack VA, dos Santos Silva I. Breast density and parenchymal patterns as markers of breast cancer risk: a meta-analysis. Cancer Epidemiol Biomarkers Prev. 2006;15(6):1159–1169.16775176
54 National Cancer Institute. Breast Cancer Prevention (PDQ®)–Health Professional Version 06/10/2022. National Cancer Institute. https://www.cancer.gov/types/breast/hp/breast-screening-pdq#section/all. Published 2018. Accessed August 27, 2022.
55 D’Orsi C, Sickles E, Mendelson E, Morris E. ACR BI-RADS® Atlas, Breast Imaging Reporting and Data System. Reston, VA: American College of Radiology; 2013.
56 Melnikow J, Fenton J, DL M, Whitlock E, Weyrich M. Screening for Breast Cancer with Digital Breast Tomosynthesis In: Rockville, MD: Agency for Healthcare Research and Quality; 2016.
57 Sprague BL, Gangnon RE, Burt V, . Prevalence of mammographically dense breasts in the United States. Journal of the National Cancer Institute. 2014;106(10).
58 Advani SM, Zhu W, Demb J, . Association of breast density with breast cancer risk among women aged 65 years or older by age group and body mass index. JAMA Netw Open. 2021;4(8):e2122810–e2122810.34436608
59 Bissell MCS, Kerlikowske K, Sprague BL, . Breast cancer population attributable risk proportions associated with body mass index and breast density by race/ethnicity and menopausal status. Cancer Epidemiol Biomarkers Prev. 2020;29(10):2048–2056.32727722
60 Mokhtary A, Karakatsanis A, Valachis A. Mammographic density changes over time and breast cancer risk: a systematic review and meta-analysis. Cancers (Basel). 2021;13(19):4805.34638289
61 Burton A, Maskarinec G, Perez-Gomez B, . Mammographic density and ageing: A collaborative pooled analysis of cross-sectional data from 22 countries worldwide. PLoS Med. 2017;14(6):e1002335.28666001
62 National Cancer Institute. Dense Breasts: Answers to Commonly Asked Questions. National Institutes of Health. https://www.cancer.gov/types/breast/breast-changes/dense-breasts. Published 2020. Accessed September 25, 2020.
63 Kerlikowske K, Sprague BL, Tosteson ANA, . Strategies to Identify Women at High Risk of Advanced Breast Cancer During Routine Screening for Discussion of Supplemental Imaging. JAMA internal medicine. 2019;[Epub ahead of print].
64 Sprague BL, Kerlikowske K, Bowles EJA, . Trends in Clinical Breast Density Assessment From the Breast Cancer Surveillance Consortium. Journal of the National Cancer Institute. 2019.
65 Azam S, Sjölander A, Eriksson M, Gabrielson M, Czene K, Hall P. Determinants of Mammographic Density Change. JNCI Cancer Spectr. 2019;3(1):pkz004–pkz004.31360892
66 Gail MH, Brinton LA, Byar DP, . Projecting individualized probabilities of developing breast cancer for white females who are being examined annually. Journal of the National Cancer Institute. 1989;81(24):1879–1886.2593165
67 Claus EB, Risch N, Thompson WD. The calculation of breast cancer risk for women with a first degree family history of ovarian cancer. Breast Cancer Res Treat. 1993;28(2):115–120.8173064
68 Tice JA, Cummings SR, Smith-Bindman R, Ichikawa L, Barlow WE, Kerlikowske K. Using clinical factors and mammographic breast density to estimate breast cancer risk: development and validation of a new predictive model. Ann Intern Med. 2008;148(5):337–347.18316752
69 Lee A, Mavaddat N, Wilcox AN, . BOADICEA: a comprehensive breast cancer risk prediction modelincorporating genetic and nongenetic risk factors. Genet Med. 2019;21(8):1708–1718.30643217
70 Euhus DM, Smith KC, Robinson L, . Pretest prediction of BRCA1 or BRCA2 mutation by risk counselors and the computer model BRCAPRO. Journal of the National Cancer Institute. 2002;94(11):844–851.12048272
71 Maas P, Barrdahl M, Joshi AD, . Breast Cancer Risk From Modifiable and Nonmodifiable Risk Factors Among White Women in the United States. JAMA Oncol. 2016;2(10):1295–1302.27228256
72 Nelson HD, Fu R, Zakher B, Pappas M, McDonagh M. Medication Use for the Risk Reduction of Primary Breast Cancer in Women: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2019;322(9):868–886.31479143
73 Louro J, Posso M, Hilton Boon M, . A systematic review and quality assessment of individualised breast cancer risk prediction models. Br J Cancer. 2019;121(1):76–85.31114019
74 Yanes T, Young M-A, Meiser B, James PA. Clinical applications of polygenic breast cancer risk: a critical review and perspectives of an emerging field. Breast Cancer Res. 2020;22(1):21.32066492
75 Nelson HD, Tyne K, Naik A, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. In: Screening for Breast Cancer: Systematic Evidence Review Update for the US Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2009.
76 Nelson HD, Fu R, Cantor A, Pappas M, Daeges M, Humphrey L. Effectiveness of Breast Cancer Screening: Systematic Review and Meta-analysis to Update the 2009 U.S. Preventive Services Task Force Recommendation. Ann Intern Med. 2016;164(4):244–255.26756588
77 Duffy SW, Vulkan D, Cuckle H, . Effect of mammographic screening from age 40 years on breast cancer mortality (UK Age trial): final results of a randomised, controlled trial. Lancel Oncol. 2020;21(9):1165–1172.
78 Duffy S, Vulkan D, Cuckle H, . Annual mammographic screening to reduce breast cancer mortality in women from age 40 years: long-term follow-up of the UK Age RCT. Health Technol Assess. 2020;24(55):1–24.
79 Johnson K, Lang K, Ikeda DM, Akesson A, Andersson I, Zackrisson S. Interval Breast Cancer Rates and Tumor Characteristics in the Prospective Population-based Malmo Breast Tomosynthesis Screening Trial. Radiology. 2021;299(3):559–567.33825509
80 Johnson K, Zackrisson S, Rosso A, . Tumor Characteristics and Molecular Subtypes in Breast Cancer Screening with Digital Breast Tomosynthesis: the Malmö Breast Tomosynthesis Screening Trial. Radiology. 2019;293(2):273–281.31478799
81 Canelo-Aybar C, Posso M, Montero N, . Benefits and harms of annual, biennial, or triennial breast cancer mammography screening for women at average risk of breast cancer: a systematic review for the European Commission Initiative on Breast Cancer (ECIBC). Br J Cancer. 2022;126(4):673–688.34837076
82 Ciatto S, Houssami N, Bernardi D, . Integration of 3D digital mammography with tomosynthesis for population breast-cancer screening (STORM): a prospective comparison study. Lancel Oncol. 2013;14(7):583–589.
83 Skaane P, Bandos AI, Eben EB, . Two-View Digital Breast Tomosynthesis Screening with Synthetically Reconstructed Projection Images: Comparison with Digital Breast Tomosynthesis with Full-Field Digital Mammographic Images. Radiology. 2014;271(3):655–663.24484063
84 Durand MA. Synthesized Mammography: Clinical Evidence, Appearance, and Implementation. Diagnostics (Basel). 2018;8(2):04.
85 Abdullah P, Alabousi M, Ramadan S, . Synthetic 2D Mammography Versus Standard 2D Digital Mammography: A Diagnostic Test Accuracy Systematic Review and Meta-Analysis. AJR Am J Roentgenol. 2021;217(2):314–325.32966115
86 Alabousi M, Wadera A, Kashif Al-Ghita M, . Performance of Digital Breast Tomosynthesis, Synthetic Mammography, and Digital Mammography in Breast Cancer Screening: A Systematic Review and Meta-Analysis. J Natl Cancer Cent. 2021;113(6):680–690.
87 Welch HG, Prorok PC, O’Malley AJ, Kramer BS. Breast-Cancer Tumor Size, Overdiagnosis, and Mammography Screening Effectiveness. N Engl J Med. 2016;375(15):1438–1447.27732805
88 Davies L, Petitti DB, Woo M, Lin JS. Defining, Estimating, and Communicating Overdiagnosis in Cancer Screening. Ann Intern Med. 2018;169(11):824.
89 Miglioretti DL, Lange J, van den Broek JJ, . Radiation-Induced Breast Cancer Incidence and Mortality From Digital Mammography Screening: A Modeling Study. Ann Intern Med. 2016;164(4):205–214.26756460
90 Ma AK, Darambara DG, Stewart A, Gunn S, Bullard E. Mean glandular dose estimation using MCNPX for a digital breast tomosynthesis system with tungsten/aluminum and tungsten/aluminum+silver x-ray anode-filter combinations. Med Phys. 2008;35(12):5278–5289.19175087
91 Pattacini P, Nitrosi A, Giorgi Rossi P, . Digital Mammography versus Digital Mammography Plus Tomosynthesis for Breast Cancer Screening: The Reggio Emilia Tomosynthesis Randomized Trial. Radiology. 2018;288(2):375–385.29869961
92 Niklason LT, Christian BT, Niklason LE, . Digital tomosynthesis in breast imaging. Radiology. 1997;205(2):399–406.9356620
93 Niklason LT, Kopans DB, Hamberg LM. Digital breast imaging: tomosynthesis and digital subtraction mammography. Breast Dis. 1998;10(3–4):151–164.15687571
94 Caumo F, Romanucci G, Hunter K, . Comparison of breast cancers detected in the Verona screening program following transition to digital breast tomosynthesis screening with cancers detected at digital mammography screening. Breast Cancer Res Treat. 2018;20:20.
95 Melnikow J, Fenton JJ, Whitlock EP, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. In: Supplemental Screening for Breast Cancer in Women With Dense Breasts: A Systematic Review for the U.S. Preventive Service Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); January 2016.
96 Yankaskas BC, Klabunde CN, Ancelle-Park R, . International comparison of performance measures for screening mammography: can it be done? J Med Screen. 2004;11(4):187–193.15624239
97 Thurfjell EL, Lernevall KA, Taube AA. Benefit of independent double reading in a population-based mammography screening program. Radiology. 1994;191(1):241–244.8134580
98 Azavedo E, Zackrisson S, Mejàre I, Heibert Arnlind M. Is single reading with computer-aided detection (CAD) as good as double reading in mammography screening? A systematic review. BMC Med Imaging. 2012;12:22.22827803
99 Taylor P, Potts HW. Computer aids and human second reading as interventions in screening mammography: two systematic reviews to compare effects on cancer detection and recall rate. Eur J Cancer. 2008;44(6):798–807.18353630
100 Bennett RL, Blanks RG, Moss SM. Does the accuracy of single reading with CAD (computer-aided detection) compare with that of double reading?: A review of the literature. Clin Radiol. 2006;61(12):1023–1028.17097423
101 Richman IB, Hoag JR, Xu X, . Adoption of Digital Breast Tomosynthesis in Clinical Practice. JAMA internal medicine. 2019;179(9):1292–1295.31233086
102 Mammography Quality Standards Act and Program (MQSA). MQSA National Statistics. https://www.fda.gov/radiation-emitting-products/mqsa-insights/mqsa-national-statistics. Published December 2020. Accessed December 10, 2020.
103 Waks AG, Winer EP. Breast cancer treatment: a review. JAMA. 2019;321(3):288–300.30667505
104 Czajka M, Pfeifer C. Breast Cancer Surgery. In: StatPearls. Treasure Island (FL): StatPearls Publishing: https://www.ncbi.nlm.nih.gov/books/NBK553076/.
105 American Cancer Society. Breast Biopsy. https://www.cancer.org/cancer/breast-cancer/screening-tests-and-early-detection/breast-biopsy.html. Published 2019. Accessed October 27, 2020.
106 Amin MB, Edge SB, Greene F, JD. B. AJCC cancer staging manual, 8th Edition. . 2017.
107 Giuliano AE, Connolly JL, Edge SB, . Breast Cancer-Major changes in the American Joint Committee on Cancer eighth edition cancer staging manual. CA Cancer J Clin. 2017;67(4):290–303.28294295
108 Crane-Okada R, Wascher RA, Elashoff D, Giuliano AE. Long-term morbidity of sentinel node biopsy versus complete axillary dissection for unilateral breast cancer. Ann Surg Oncol. 2008;15(7):1996–2005.18415650
109 Chen JC, Li Y, Fisher JL, Bhattacharyya O, Tsung A, Obeng-Gyasi S. Neighborhood socioeconomic status and low-value breast cancer care. J Surg Oncol. 2022;126(3):433–442.35452136
110 Nayyar A, Strassle PD, Schlottmann F, . Disparities in the Use of Sentinel Lymph Node Dissection for Early Stage Breast Cancer. J Surg Res. 2020;254:31–40.32408028
111 Nelson HD, Cantor A, Humphrey L, . Screening for Breast Cancer: A Systematic Review to Update the 2009 U.S. Preventive Services Task Force Recommendation. 01 2016.
112 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2023.
113 Wang S, Sultana F, Kavanagh A, . Benefits and harms of breast cancer screening: Cohort study of breast cancer mortality and overdiagnosis. Cancer Med. 2023;12(17):18120–18132.37548277
114 Richman IB, Long JB, Soulos PR, Wang SY, Gross CP. Estimating Breast Cancer Overdiagnosis After Screening Mammography Among Older Women in the United States. Ann Intern Med. 2023;176(9):1172–1180.37549389
115 Caughey AB, Krist AH, Wolff TA, . USPSTF Approach to Addressing Sex and Gender When Making Recommendations for Clinical Preventive Services. JAMA. 2021;326(19):1953–1961.34694343
116 United Nations Development Programme. 2020 Statistical Update: Human Development Indices and Indicators. New York 2020.
117 Hellquist BN, Duffy SW, Abdsaleh S, . Effectiveness of population-based service screening with mammography for women ages 40 to 49 years: evaluation of the Swedish Mammography Screening in Young Women (SCRY) cohort. Cancer. 2011;117(4):714–722.20882563
118 Mao Z, Nystrom L, Jonsson H. Effectiveness of Population-Based Service Screening with Mammography for Women Aged 70-74 Years in Sweden. Cancer Epidemiol Biomarkers Prev. 2020;29(11):2149–2156.32856607
119 Seely JM, Peddle SE, Yang H, . Breast Density and Risk of Interval Cancers: The Effect of Annual Versus Biennial Screening Mammography Policies in Canada. Can Assoc Radiol J. 2021:8465371211027958.
120 Castellano CR, Aguilar Angulo PM, Hernandez LC, . Breast cancer mortality after eight years of an improved screening program using digital breast tomosynthesis. J Med Screen. 2021:9691413211002556.
121 Canelo-Aybar C, Carrera L, Beltran J, . Digital breast tomosynthesis compared to diagnostic mammographic projections (including magnification) among women recalled at screening mammography: a systematic review for the European Commission Initiative on Breast Cancer (ECIBC). Cancer Med. 2021;10(7):2191–2204.33675147
122 Ryser MD, Lange J, Inoue LYT, . Estimation of Breast Cancer Overdiagnosis in a U.S. Breast Screening Cohort. Ann Intern Med. 2022;175(4):471–478.35226520
123 Dunn BK, Woloshin S, Xie H, Kramer BS. Cancer overdiagnosis: A challenge in the era of screening. J Natl Cancer Cent. 2022;2(4):235–242.36568283
124 van Ravesteyn NT, van den Broek JJ, Li X, . Modeling Ductal Carcinoma In Situ (DCIS): An Overview of CISNET Model Approaches. Med Decis Making. 2018;38(1_suppl):126S–139S.29554463
125 Guyatt G, Oxman AD, Akl EA, . GRADE guidelines: 1. Introduction-GRADE evidence profiles and summary of findings tables. J Clin Epidemiol. 2011;64(4):383–394.21195583
126 The frequency of breast cancer screening: results from the UKCCCR Randomised Trial. United Kingdom Co-ordinating Committee on Cancer Research. Eur J Cancer. 2002;38(11):1458–1464.12110490
127 Aase HS, Danielsen AS, Hoff SR, . Mammographic features and screening outcome in a randomized controlled trial comparing digital breast tomosynthesis and digital mammography. Eur J Radiol. 2021;141:109753.34053786
128 Aase HS, Holen AS, Pedersen K, . A randomized controlled trial of digital breast tomosynthesis versus digital mammography in population-based screening in Bergen: interim analysis of performance indicators from the To-Be trial. Eur Radiol. 2019;29(3):1175–1186.30159620
129 Armaroli P, Frigerio A, Correale L, . A randomised controlled trial of Digital Breast Tomosynthesis versus Digital Mammography as primary screening tests: screening results over subsequent episodes of the Proteus Donna study. Int J Cancer. 2022;151(10):1778–1790.35689673
130 Bakker MF, de Lange SV, Pijnappel RM, . Supplemental MRI Screening for Women with Extremely Dense Breast Tissue. N Engl J Med. 2019;381(22):2091–2102.31774954
131 Braithwaite D, Zhu W, Hubbard RA, . Screening outcomes in older US women undergoing multiple mammograms in community practice: does interval, age, or comorbidity score affect tumor characteristics or false positive rates? Journal of the National Cancer Institute. 2013;105(5):334–341.23385442
132 Conant EF, Beaber EF, Sprague BL, . Breast cancer screening using tomosynthesis in combination with digital mammography compared to digital mammography alone: a cohort study within the PROSPR consortium. Breast Cancer Res Treat. 2016;156(1):109–116.26931450
133 de Lange SV, Bakker MF, Monninkhof EM, . Reasons for (non)participation in supplemental population-based MRI breast screening for women with extremely dense breasts. Clin Radiol. 2018;73(8):759.e751–759.e759.
134 Dittus K, Geller B, Weaver DL, . Impact of mammography screening interval on breast cancer diagnosis by menopausal status and BMI. J Gen Intern Med. 2013;28(11):1454–1462.23760741
135 Ganguli I, Keating NL, Thakore N, Lii J, Raza S, Pace LE. Downstream Mammary and Extramammary Cascade Services and Spending Following Screening Breast Magnetic Resonance Imaging vs Mammography Among Commercially Insured Women. JAMA Netw Open. 2022;5(4):e227234.35416989
136 Garcia-Albeniz X, Hernan MA, Logan RW, Price M, Armstrong K, Hsu J. Continuation of Annual Screening Mammography and Breast Cancer Mortality in Women Older Than 70 Years. Ann Intern Med. 2020;172(6):381–389.32092767
137 Goel A, Littenberg B, Burack RC. The association between the pre-diagnosis mammography screening interval and advanced breast cancer. Breast Cancer Res Treat. 2007;102(3):339–345.16927175
138 Harada-Shoji N, Suzuki A, Ishida T, . Evaluation of Adjunctive Ultrasonography for Breast Cancer Detection Among Women Aged 40-49 Years With Varying Breast Density Undergoing Screening Mammography: A Secondary Analysis of a Randomized Clinical Trial. JAMA Netw Open. 2021;4(8):e2121505.34406400
139 Heindel W, Weigel S, Gerß J, . Digital breast tomosynthesis plus synthesised mammography versus digital screening mammography for the detection of invasive breast cancer (TOSYMA): a multicentre, open-label, randomised, controlled, superiority trial. Lancet Oncol. 2022;23(5):601–611.35427470
140 Ho TH, Bissell MCS, Kerlikowske K, . Cumulative Probability of False-Positive Results After 10 Years of Screening With Digital Breast Tomosynthesis vs Digital Mammography. JAMA Netw Open. 2022;5(3):e222440.35333365
141 Hofvind S, Holen AS, Aase HS, . Two-view digital breast tomosynthesis versus digital mammography in a population-based breast cancer screening programme (To-Be): a randomised, controlled trial. Lancel Oncol. 2019;20(6):795–805.
142 Hofvind S, Hovda T, Holen AS, . Digital Breast Tomosynthesis and Synthetic 2D Mammography versus Digital Mammography: Evaluation in a Population-based Screening Program. Radiology. 2018;287(3):787–794.29494322
143 Hofvind S, Moshina N, Holen AS, . Interval and Subsequent Round Breast Cancer in a Randomized Controlled Trial Comparing Digital Breast Tomosynthesis and Digital Mammography Screening. Radiology. 2021;300(1):66–76.33973840
144 Hovda T, Holen AS, Lang K, . Interval and Consecutive Round Breast Cancer after Digital Breast Tomosynthesis and Synthetic 2D Mammography versus Standard 2D Digital Mammography in BreastScreen Norway. Radiology. 2020;294(2):256–264.31821118
145 Hubbard RA, Kerlikowske K, Flowers CI, Yankaskas BC, Zhu W, Miglioretti DL. Cumulative probability of false-positive recall or biopsy recommendation after 10 years of screening mammography: a cohort study. Ann Intern Med. 2011;155(8):481–492.22007042
146 Ishida T, Suzuki A, Kawai M, . A randomized controlled trial to verify the efficacy of the use of ultrasonography in breast cancer screening aged 40-49 (J-START): 76 196 women registered. Jpn J Clin Oncol. 2014;44(2):134–140.24407835
147 Kerlikowske K, Su Y-R, Sprague BL, . Association of Screening With Digital Breast Tomosynthesis vs Digital Mammography With Risk of Interval Invasive and Advanced Breast Cancer. JAMA. 2022;327(22):2220–2230.35699706
148 Kerlikowske K, Zhu W, Hubbard RA, . Outcomes of screening mammography by frequency, breast density, and postmenopausal hormone therapy. JAMA internal medicine. 2013;173(9):807–816.23552817
149 Klemi PJ, Toikkanen S, Räsänen O, Parvinen I, Joensuu H. Mammography screening interval and the frequency of interval cancers in a population-based screening. Br J Cancer. 1997;75(5):762–766.9043038
150 Lang K, Andersson I, Rosso A, Tingberg A, Timberg P, Zackrisson S. Performance of one-view breast tomosynthesis as a stand-alone breast cancer screening modality: results from the Malmo Breast Tomosynthesis Screening Trial, a population-based study. Eur Radiol. 2016;26(1):184–190.25929946
151 Lang K, Nergarden M, Andersson I, Rosso A, Zackrisson S. False positives in breast cancer screening with one-view breast tomosynthesis: An analysis of findings leading to recall, work-up and biopsy rates in the Malmo Breast Tomosynthesis Screening Trial. Eur Radiol. 2016;26(11):3899–3907.26943342
152 Lee JM, Arao RF, Sprague BL, . Performance of Screening Ultrasonography as an Adjunct to Screening Mammography in Women Across the Spectrum of Breast Cancer Risk. JAMA internal medicine. 2019;179(5):658–667.30882843
153 McGuinness JE, Ueng W, Trivedi MS, . Factors Associated with False Positive Results on Screening Mammography in a Population of Predominantly Hispanic Women. Cancer Epidemiol Biomarkers Prev. 2018;27(4):446–453.29382701
154 Miglioretti DL, Zhu W, Kerlikowske K, . Breast Tumor Prognostic Characteristics and Biennial vs Annual Mammography, Age, and Menopausal Status. JAMA Oncol. 2015;1(8):1069–1077.26501844
155 Moger TA, Swanson JO, Holen AS, Hanestad B, Hofvind S. Cost differences between digital tomosynthesis and standard digital mammography in a breast cancer screening programme: results from the To-Be trial in Norway. Eur J Health Econ. 2019;20(8):1261–1269.31399773
156 Moshina N, Aase HS, Danielsen AS, . Comparing Screening Outcomes for Digital Breast Tomosynthesis and Digital Mammography by Automated Breast Density in a Randomized Controlled Trial: Results from the To-Be Trial. Radiology. 2020;297(3):522–531.32930649
157 Nelson HD, O’Meara ES, Kerlikowske K, Balch S, Miglioretti D. Factors Associated With Rates of False-Positive and False-Negative Results From Digital Mammography Screening: An Analysis of Registry Data. Ann Intern Med. 2016;164(4):226–235.26756902
158 Ohuchi N, Suzuki A, Sobue T, . Sensitivity and specificity of mammography and adjunctive ultrasonography to screen for breast cancer in the Japan Strategic Anti-cancer Randomized Trial (J-START): a randomised controlled trial. Lancet. 2016;387(10016):341–348.26547101
159 Parvinen I, Chiu S, Pylkkänen L, . Effects of annual vs triennial mammography interval on breast cancer incidence and mortality in ages 40-49 in Finland. Br J Cancer. 2011;105(9):1388–1391.21934688
160 Pattacini P, Nitrosi A, Giorgi Rossi P, . A Randomized Trial Comparing Breast Cancer Incidence and Interval Cancers after Tomosynthesis Plus Mammography versus Mammography Alone. Radiology. 2022:211132.
161 Pattacini P, Nitrosi A, Giorgi Rossi P, . Digital Mammography versus Digital Mammography Plus Tomosynthesis for Breast Cancer Screening: The Reggio Emilia Tomosynthesis Randomized Trial. Radiology. 2018;288(2):375–385.29869961
162 Richman IB, Long JB, Hoag JR, . Comparative Effectiveness of Digital Breast Tomosynthesis for Breast Cancer Screening among Women 40-64 Years Old. J Natl Cancer Cent. 2021;03:03.
163 Rosso A, Lang K, Petersson IF, Zackrisson S. Factors affecting recall rate and false positive fraction in breast cancer screening with breast tomosynthesis - A statistical approach. Breast. 2015;24(5):680–686.26365133
164 Veenhuizen SGA, de Lange SV, Bakker MF, . Supplemental Breast MRI for Women with Extremely Dense Breasts: Results of the Second Screening Round of the DENSE Trial. Radiology. 2021;299(2):278–286.33724062
165 Waade G, Holen Å, Sebuødegård S, . Breast compression parameters among women screened with standard digital mammography and digital breast tomosynthesis in a randomized controlled trial. Acta Radiol. 2020;61(3):321–330.31342757
166 White E, Miglioretti DL, Yankaskas BC, . Biennial versus annual mammography and the risk of late-stage breast cancer. Journal of the National Cancer Institute. 2004;96(24):1832–1839.15601639
167 Zackrisson S, Lang K, Rosso A, . One-view breast tomosynthesis versus two-view mammography in the Malmo Breast Tomosynthesis Screening Trial (MBTST): a prospective, population-based, diagnostic accuracy study. Lancel Oncol. 2018;19(11):1493–1503.
168 Sprague B, Coley RY, Lowry K, . Digital breast tomosynthesis versus digital mammography screening performance on successive screening rounds from the Breast Cancer Surveillance Consortium. Radiology 2023;307(5):e223142.37249433
169 Hernán MA, Robins JM. Using Big Data to Emulate a Target Trial When a Randomized Trial Is Not Available. Am J Epidemiol. 2016;183(8):758–764.26994063
170 Acerbi I, Fiscalini A, Che M, . Personalized breast cancer screening in a population-based study: women informed to screen depending on measures of risk (WISDOM). Cancer Res. 2021;81(4 suppl).
171 Doubovetzky J, Bour C. Use of screening research to boost overdiagnosis: the mypebs trial. BMJ Evid Based Med. 2019;24:A43-.
172 García-Albéniz X, Hsu J, Bretthauer M, Hernán MA. Effectiveness of Screening Colonoscopy to Prevent Colorectal Cancer Among Medicare Beneficiaries Aged 70 to 79 Years: A Prospective Observational Study. Ann Intern Med. 2017;166(1):18–26.27669524
173 Cook AJ, Elmore JG, Miglioretti DL, . Decreased accuracy in interpretation of community-based screening mammography for women with multiple clinical risk factors. J Clin Epidemiol. 2010;63(4):441–451.19744825
174 Nelson HD. Mammography Screening and Overdiagnosis. JAMA Oncol. 2016;2(2):261–262.26501939
175 Heywang-Köbrunner S-H, Jänsch A, Hacker A, Weinand S, Vogelmann T. Tomosynthesis with synthesised two-dimensional mammography yields higher cancer detection compared to digital mammography alone, also in dense breasts and in younger women: A systematic review and meta-analysis. Eur J Radiol. 2022;152.
176 Libesman S, Zackrisson S, Hofvind S, . An individual participant data meta-analysis of breast cancer detection and recall rates for digital breast tomosynthesis versus digital mammography population screening. Clin Breast Cancer. 2022;22(5):e647–e654.35246389
177 Giampietro RR, Cabral MVG, Lima SAM, Weber SAT, Dos Santos Nunes-Nogueira V. Accuracy and Effectiveness of Mammography versus Mammography and Tomosynthesis for Population-Based Breast Cancer Screening: A Systematic Review and Meta-Analysis. Sci Rep. 2020;10(1):7991.32409756
178 Lowry KP, Coley RY, Miglioretti DL, . Screening Performance of Digital Breast Tomosynthesis vs Digital Mammography in Community Practice by Patient Age, Screening Round, and Breast Density. JAMA Netw Open. 2020;3(7):e2011792–e2011792.32721031
179 Mizzi D, Allely C, Zarb F, . Examining the effectiveness of supplementary imaging modalities for breast cancer screening in women with dense breasts: A systematic review and meta-analysis. Eur J Radiol. 2022;154:110416.35803102
180 Yuan WH, Hsu HC, Chen YY, Wu CH. Supplemental breast cancer-screening ultrasonography in women with dense breasts: a systematic review and meta-analysis. Br J Cancer. 2020;123(4):673–688.32528118
181 Yang L, Wang S, Zhang L, . Performance of ultrasonography screening for breast cancer: a systematic review and meta-analysis. BMC Cancer. 2020;20(1):499.32487106
182 Jemal A, Ward EM, Johnson CJ, . Annual Report to the Nation on the Status of Cancer, 1975-2014, Featuring Survival. Journal of the National Cancer Institute. 2017;109(9).
183 Lewis-Thames MW, Langston ME, Khan S, . Racial and Ethnic Differences in Rural-Urban Trends in 5-Year Survival of Patients With Lung, Prostate, Breast, and Colorectal Cancers: 1975-2011 Surveillance, Epidemiology, and End Results (SEER). JAMA Netw Open. 2022;5(5):e2212246–e2212246.35587350
184 Alvidrez J, Castille D, Laude-Sharp M, Rosario A, Tabor D. The National Institute on Minority Health and Health Disparities Research Framework. Am J Public Health. 2019;109(S1):S16–s20.30699025
185 Nong P, Raj M, Creary M, Kardia SLR, Platt JE. Patient-Reported Experiences of Discrimination in the US Health Care System. JAMA Netw Open. 2020;3(12):e2029650.33320264
186 Nelson HD, Cantor A, Wagner J, . Effectiveness of Patient Navigation to Increase Cancer Screening in Populations Adversely Affected by Health Disparities: a Meta-analysis. J Gen Intern Med. 2020;35(10):3026–3035.32700218
187 Williams DR, Priest N, Anderson NB. Understanding associations among race, socioeconomic status, and health: Patterns and prospects. Health Psychol. 2016;35(4):407–411.27018733
188 Bailey ZD, Krieger N, Agénor M, Graves J, Linos N, Bassett MT. Structural racism and health inequities in the USA: evidence and interventions. Lancet. 2017;389(10077):1453–1463.28402827
189 Zavala VA, Bracci PM, Carethers JM, . Cancer health disparities in racial/ethnic minorities in the United States. Br J Cancer. 2020;124(2):315–332.32901135
190 Bemanian A, Beyer KM. Measures Matter: The Local Exposure/Isolation (LEx/Is) Metrics and Relationships between Local-Level Segregation and Breast Cancer Survival. Cancer Epidemiol Biomarkers Prev. 2017;26(4):516–524.28325737
191 Collin LJ, Gaglioti AH, Beyer KM, . Neighborhood-Level Redlining and Lending Bias Are Associated with Breast Cancer Mortality in a Large and Diverse Metropolitan Area. Cancer Epidemiol Biomarkers Prev. 2021;30(1):53–60.33008873
192 Goel N, Westrick AC, Bailey ZD, . Structural Racism and Breast Cancer-specific Survival: Impact of Economic and Racial Residential Segregation. Ann Surg. 2022;275(4):776–783.35081560
193 Siegel SD, Brooks MM, Lynch SM, Sims-Mourtada J, Schug ZT, Curriero FC. Racial disparities in triple negative breast cancer: toward a causal architecture approach. Breast Cancer Res. 2022;24(1):37.35650633
194 Kerlikowske K, Chen S, Golmakani MK, . Cumulative advanced breast cancer risk prediction model developed in a screening mammography population. Journal of the National Cancer Institute. 2022;114(5):676–685.35026019
195 Niraula S, Biswanger N, Hu P, Lambert P, Decker K. Incidence, Characteristics, and Outcomes of Interval Breast Cancers Compared With Screening-Detected Breast Cancers. JAMA Netw Open. 2020;3(9):e2018179.32975573
196 Davis Lynn BC, Chernyavskiy P, Gierach GL, Rosenberg PS. Decreasing Incidence of Estrogen Receptor-Negative Breast Cancer in the United States: Trends by Race and Region. Journal of the National Cancer Institute. 2022;114(2):263–270.34508608
197 Nelson HD, Cantor A, Wagner J, . Achieving Health Equity in Preventive Services: A Systematic Review for a National Institutes of Health Pathways to Prevention Workshop. Ann Intern Med. 2020;172(4):258–271.31931527
198 Centers for Disease Control and Prevention. BRFSS Web Enabled Analysis Tool. https://nccd.cdc.gov/weat/#/analysis. Accessed August 29, 2022.
199 Gorina Y, Elgaddal N. Patterns of Mammography, Pap Smear, and Colorectal Cancer Screening Services Among Women Aged 45 and Over. Natl Health Stat Report. 2021(157):1–18.
200 Lee CI, Lehman CD. Digital breast tomosynthesis and the challenges of implementing an emerging breast cancer screening technology into clinical practice. J Am Coll Radiol. 2013;10(12):913–917.24295940
201 Lee CI, Zhu W, Onega T, . Comparative Access to and Use of Digital Breast Tomosynthesis Screening by Women’s Race/Ethnicity and Socioeconomic Status. JAMA Netw Open. 2021;4(2):e2037546.33606032
202 Clark CR, Tosteson TD, Tosteson ANA, . Diffusion of digital breast tomosynthesis among women in primary care: associations with insurance type. Cancer Med. 2017;6(5):1102–1107.28378409
203 Schifferdecker KE, Tosteson ANA, Kaplan C, . Knowledge and Perception of Breast Density, Screening Mammography, and Supplemental Screening: in Search of “Informed”. J Gen Intern Med. 2020;35(6):1654–1660.31792869
204 Warnecke RB, Campbell RT, Vijayasiri G, Barrett RE, Rauscher GH. Multilevel Examination of Health Disparity: The Role of Policy Implementation in Neighborhood Context, in Patient Resources, and in Healthcare Facilities on Later Stage of Breast Cancer Diagnosis. Cancer Epidemiol Biomarkers Prev. 2019;28(1):59–66.30352817
205 Onega T, Hubbard R, Hill D, . Geographic access to breast imaging for US women. J Am Coll Radiol. 2014;11(9):874–882.24889479
206 Fayanju OM, Ren Y, Stashko I, . Patient-reported causes of distress predict disparities in time to evaluation and time to treatment after breast cancer diagnosis. Cancer. 2021;127(5):757–768.33175437
207 Selove R, Kilbourne B, Fadden MK, . Time from Screening Mammography to Biopsy and from Biopsy to Breast Cancer Treatment among Black and White, Women Medicare Beneficiaries Not Participating in a Health Maintenance Organization. Womens Health Issues. 2016;26(6):642–647.27773529
208 Nguyen KH, Pasick RJ, Stewart SL, Kerlikowske K, Karliner LS. Disparities in abnormal mammogram follow-up time for Asian women compared with non-Hispanic white women and between Asian ethnic groups. Cancer. 2017;123(18):3468–3475.28603859
209 Warner ET, Tamimi RM, Hughes ME, . Time to diagnosis and breast cancer stage by race/ethnicity. Breast Cancer Res Treat. 2012;136(3):813–821.23099438
210 Kovar A, Bronsert M, Jaiswal K, . The Waiting Game: How Long Are Breast Cancer Patients Waiting for Definitive Diagnosis? Ann Surg Oncol. 2020;27(10):3641–3649.32314153
211 Elmore JG, Nakano CY, Linden HM, Reisch LM, Ayanian JZ, Larson EB. Racial inequities in the timing of breast cancer detection, diagnosis, and initiation of treatment. Med Care. 2005;43(2):141–148.15655427
212 Emerson MA, Golightly YM, Aiello AE, . Breast cancer treatment delays by socioeconomic and health care access latent classes in Black and White women. Cancer. 2020;126(22):4957–4966.32954493
213 Lawson MB, Bissell MCS, Miglioretti DL, . Multilevel Factors Associated With Time to Biopsy After Abnormal Screening Mammography Results by Race and Ethnicity. JAMA Oncol. 2022;8(8):1115–1126.35737381
214 Yussof I, Mohd Tahir NA, Hatah E, Mohamed Shah N. Factors influencing five-year adherence to adjuvant endocrine therapy in breast cancer patients: A systematic review. Breast. 2022;62:22–35.35121501
215 Hu X, Walker MS, Stepanski E, . Racial Differences in Patient-Reported Symptoms and Adherence to Adjuvant Endocrine Therapy Among Women With Early-Stage, Hormone Receptor-Positive Breast Cancer. JAMA Netw Open. 2022;5(8):e2225485.35947386
216 Hu X, Chehal PK, Kaplan C, . Characterization of Clinical Symptoms by Race Among Women With Early-Stage, Hormone Receptor-Positive Breast Cancer Before Starting Chemotherapy. JAMA Netw Open. 2021;4(6):e2112076.34061200
217 Nystrom L, Bjurstam N, Jonsson H, Zackrisson S, Frisell J. Reduced breast cancer mortality after 20+ years of follow-up in the Swedish randomized controlled mammography trials in Malmo, Stockholm, and Goteborg. J Med Screen. 2017;24(1):34–42.27306511
218 Tice JA, Miglioretti DL, Li CS, Vachon CM, Gard CC, Kerlikowske K. Breast Density and Benign Breast Disease: Risk Assessment to Identify Women at High Risk of Breast Cancer. J Clin Oncol. 2015;33(28):3137–3143.26282663
219 Adams-Campbell LL, Makambi KH, Palmer JR, Rosenberg L. Diagnostic accuracy of the Gail model in the Black Women’s Health Study. Breast J. 2007;13(4):332–336.17593036
220 Gail MH, Anderson WF, Garcia-Closas M, Sherman ME. Absolute risk models for subtypes of breast cancer. Journal of the National Cancer Institute. 2007;99(22):1657–1659.18000214
221 Matsuno RK, Costantino JP, Ziegler RG, . Projecting individualized absolute invasive breast cancer risk in Asian and Pacific Islander American women. Journal of the National Cancer Institute. 2011;103(12):951–961.21562243
222 Amir E, Evans DG, Shenton A, . Evaluation of breast cancer risk assessment packages in the family history evaluation and screening programme. J Med Genet. 2003;40(11):807–814.14627668
223 Chlebowski RT, Anderson GL, Lane DS, . Predicting risk of breast cancer in postmenopausal women by hormone receptor status. Journal of the National Cancer Institute. 2007;99(22):1695–1705.18000216
224 Barlow WE, White E, Ballard-Barbash R, . Prospective breast cancer risk prediction model for women undergoing screening mammography. Journal of the National Cancer Institute. 2006;98(17):1204–1214.16954473
225 Vacek PM, Skelly JM, Geller BM. Breast cancer risk assessment in women aged 70 and older. Breast Cancer Res Treat. 2011;130(1):291–299.21604157
226 Brentnall AR, Harkness EF, Astley SM, . Mammographic density adds accuracy to both the Tyrer-Cuzick and Gail breast cancer risk models in a prospective UK screening cohort. Breast Cancer Res. 2015;17(1):147.26627479
227 Tice JA, Bissell MCS, Miglioretti DL, . Validation of the breast cancer surveillance consortium model of breast cancer risk. Breast Cancer Res Treat. 2019;175(2):519–523.30796654
228 Nickson C, Procopio P, Velentzis LS, . Prospective validation of the NCI Breast Cancer Risk Assessment Tool (Gail Model) on 40,000 Australian women. Breast Cancer Res. 2018;20(1):155.30572910
229 MacInnis RJ, Knight JA, Chung WK, . Comparing 5-Year and Lifetime Risks of Breast Cancer using the Prospective Family Study Cohort. J Natl Cancer Cent. 2021;113(6):785–791.
230 Louro J, Roman M, Posso M, . Developing and validating an individualized breast cancer risk prediction model for women attending breast cancer screening. PLoS ONE. 2021;16(3):e0248930.33755692
231 McCarthy AM, Guan Z, Welch M, . Performance of Breast Cancer Risk-Assessment Models in a Large Mammography Cohort. J Natl Cancer Cent. 2020;112(5):489–497.
232 Abdolell M, Payne JI, Caines J, . Assessing breast cancer risk within the general screening population: developing a breast cancer risk model to identify higher risk women at mammographic screening. Eur Radiol. 2020;30(10):5417–5426.32358648
233 Eriksson M, Czene K, Strand F, . Identification of Women at High Risk of Breast Cancer Who Need Supplemental Screening. Radiology. 2020;297(2):327–333.32897160
234 Kakileti ST, Madhu HJ, Manjunath G, Wee L, Dekker A, Sampangi S. Personalized risk prediction for breast cancer pre-screening using artificial intelligence and thermal radiomics. Artif Intell Med. 2020;105:101854.32505418
235 Ming C, Viassolo V, Probst-Hensch N, Chappuis P, Dinov I, Katapodi M. Machine learning techniques for personalized breast cancer risk prediction: comparison with the BCRAT and BOADICEA models [Journal: Article]. Breast Cancer Res. 2019;21(1). doi:10.1186/s13058-019-1158-4.
236 Yala A, Mikhael PG, Strand F, . Toward robust mammography-based models for breast cancer risk. Sci Transl Med. 2021;13(578):27.
237 van Veen EM, Brentnall AR, Byers H, . Use of Single-Nucleotide Polymorphisms and Mammographic Density Plus Classic Risk Factors for Breast Cancer Risk Prediction. JAMA Oncol. 2018;4(4):476–482.29346471
238 Lall K, Lepamets M, Palover M, . Polygenic prediction of breast cancer: comparison of genetic predictors and implications for risk stratification. BMC Cancer. 2019;19(1):557.31182048
239 Mathioudakis AG, Salakari M, Pylkkanen L, . Systematic review on women’s values and preferences concerning breast cancer screening and diagnostic services. Psychooncology. 2019;28(5):939–947.30812068
240 Mottram R, Knerr WL, Gallacher D, . Factors associated with attendance at screening for breast cancer: a systematic review and meta-analysis. BMJ Open. 2021;11(11):e046660.
241 Brewer NT, Salz T, Lillie SE. Systematic review: the long-term effects of false-positive mammograms. Ann Intern Med. 2007;146(7):502–510.17404352
242 Dabbous FM, Dolecek TA, Berbaum ML, . Impact of a False-Positive Screening Mammogram on Subsequent Screening Behavior and Stage at Breast Cancer Diagnosis. Cancer Epidemiol Biomarkers Prev. 2017;26(3):397–403.28183826
243 Shi W, Nagler RH, Fowler EF, Gollust SE. Predictors of Women’s Awareness of the Benefits and Harms of Mammography Screening and Associations with Confusion, Ambivalence, and Information Seeking. Health Commun. 2021;36(3):303–314.31690128
244 Hoover DS, Pappadis MR, Housten AJ, . Preferences for Communicating about Breast Cancer Screening Among Racially/Ethnically Diverse Older Women. Health Commun. 2019;34(7):702–706.29373069
245 Ro V, Jones T, Silverman T, . Patient, primary care provider, and stakeholder perspectives on mammography screening frequency: lessons learned from a qualitative study. BMC Cancer. 2022;22(1):819.35897000
246 Thomson MD, Siminoff LA. Perspectives on mammography after receipt of secondary screening owing to a false positive. Womens Health Issues. 2015;25(2):128–133.25648490
247 Brandzel S, Chang E, Tuzzio L, . Latina and Black/African American women’s perspectives on cancer screening and cancer screening reminders. J Racial Ethn Health Disparities. 2016.
248 Esmaeili M, Ayyoubzadeh SM, Javanmard Z, S RNK. A systematic review of decision aids for mammography screening: Focus on outcomes and characteristics. Int J Med Inf. 2021;149:104406.
249 Taghian A, Merajver SD. Overview of the treatment of newly diagnosed, invasive, non-metastatic breast cancer. In: Post TW, ed. UpToDate; 2022.
250 Sharma P. Overview of the approach to metastatic breast cancer. In: Post TW, ed. UpToDate; 2022.
251 Sabel MS. Breast-conserving therapy. In: Post TW, ed. UpToDate; 2022.
252 Kwong A, Sabel MS. Mastectomy. In: Post TW, ed. UpToDate; 2022.
253 Taghian A. Adjuvant radiation therapy for women with newly diagnosed, non-metastatic breast cancer. In: Post TW, ed. UpToDate; 2022.
254 Shapiro CL. Acute side effects of adjuvant chemotherapy for early-stage breast cancer. In: Post TW, ed. UpToDate; 2022.
255 Rivera DR, Ganz PA, Weyrich MS, Bandos H, Melnikow J. Chemotherapy-Associated Peripheral Neuropathy in Patients With Early-Stage Breast Cancer: A Systematic Review. Journal of the National Cancer Institute. 2018;110(2).
256 Elghazawy H, Venkatesulu BP, Verma V, . The role of cardio-protective agents in cardio-preservation in breast cancer patients receiving Anthracyclines ± Trastuzumab: a Meta-analysis of clinical studies. Crit Rev Oncol Hematol. 2020;153:103006.32777728
257 Upshaw JN, Finkelman B, Hubbard RA, . Comprehensive Assessment of Changes in Left Ventricular Diastolic Function With Contemporary Breast Cancer Therapy. JACC Cardiovasc Imaging. 2020;13(1 Pt 2):198–210.31542526
258 Chen DH, Tyebally S, Malloupas M, . Cardiovascular Disease Amongst Women Treated for Breast Cancer: Traditional Cytotoxic Chemotherapy, Targeted Therapy, and Radiation Therapy. Curr Cardiol Rep. 2021;23(3):16.33501515
259 Stan D, Loprinzi CL, Ruddy KJ. Breast cancer survivorship issues. Hematol Oncol Clin North Am. 2013;27(4):805–827, ix.23915746
260 Come SE. Overview of long-term complications of therapy in breast cancer survivors and patterns of relapse. In: Post TW, ed. UpToDate; 2022.
261 Mannu GS, Wang Z, Broggio J, . Invasive breast cancer and breast cancer mortality after ductal carcinoma in situ in women attending for breast screening in England, 1988-2014: population based observational cohort study. BMJ. 2020;369:m1570.32461218
262 Narod SA, Iqbal J, Giannakeas V, Sopik V, Sun P. Breast cancer mortality after a diagnosis of ductal carcinoma in situ. JAMA Oncol. 2015;1(7):888–896.26291673
263 Zhang B, Coopey SB, Gadd MA, Hughes KS, Chang DC, Oseni TO. Trends in unilateral and contralateral prophylactic mastectomy use in ductal carcinoma in situ of the breast: patterns and predictors. Ann Surg Oncol. 2019;26(12):3863–3873.31325048
264 Bouskill K, Hempel S, Richardson A, . Evidence map of ductal carcinoma in situ management options. Menopause. 2019;26(11):1250–1258.31567868
265 Hwang ES, Hyslop T, Lynch T, . The COMET (Comparison of Operative versus Monitoring and Endocrine Therapy) trial: a phase III randomised controlled clinical trial for low-risk ductal carcinoma in situ (DCIS). BMJ Open. 2019;9(3):e026797.
266 Francis A, Fallowfield L, Rea D. The LORIS Trial: Addressing overtreatment of ductal carcinoma in situ. Clin Oncol (R Coll Radiol). 2015;27(1):6–8.25445552
267 Solin L. Feasibility of a prospective, randomised, open-label, international multicentre, phase III, non-inferiority trial to assess the safety of active surveillance for low risk ductal carcinoma in situ - The LORD study [Journal: Short Survey]. Breast diseases. 2016;27(1):47–48. doi:10.1016/j.breastdis.2016.01.009.
268 Kerlikowske K, Bissell MCS, Sprague BL, . Advanced Breast Cancer Definitions by Staging System Examined in the Breast Cancer Surveillance Consortium. J Natl Cancer Cent. 2021;113(7):909–916.
269 Davies NM, Holmes MV, Davey Smith G. Reading Mendelian randomisation studies: a guide, glossary, and checklist for clinicians. BMJ. 2018;362:k601.30002074
270 ECOG-ACRIN Cancer Research Group. EA1151 / TMIST: Digital Tomosynthesis Mammography and Digital Mammography in Screening Patients for Breast Cancer. https://ecog-acrin.org/clinical-trials/ea1151-tmist-breast-cancer-screening-mammography/. Accessed March 8, 2023.
271 SEER Explorer. Breast Cancer: Recent Trends in SEER Age-Adjusted Incidence Rates, 2000-2019. National Institutes of Health and National Cancer Institute. https://seer.cancer.gov/explorer/application.html. Published 2022. Accessed February 16, 2023.
272 Oeffinger KC, Fontham ET, Etzioni R, . Breast Cancer Screening for Women at Average Risk: 2015 Guideline Update From the American Cancer Society. JAMA. 2015;314(15):1599–1614.26501536
273 American Academy of Family Physicians. Clinical Preventive Service Recommendation Web site. https://www.aafp.org/family-physician/patient-care/clinical-recommendations/all-clinical-recommendations/breast-cancer.html. Published 2020. Accessed Accessed August 26, 2020.
274 Anonymous. Practice Bulletin Number 179: Breast Cancer Risk Assessment and Screening in Average-Risk Women. Obstet Gynecol. 2017;130(1):e1–e16.28644335
275 Qaseem A, Lin JS, Mustafa RA, . Screening for Breast Cancer in Average-Risk Women: A Guidance Statement From the American College of Physicians. Ann Intern Med. 2019;170(8):547–560.30959525
276 Monticciolo DL, Malak SF, Friedewald SM, . Breast Cancer Screening Recommendations Inclusive of All Women at Average Risk: Update from the ACR and Society of Breast Imaging. J Am Coll Radiol. 2021;18(9):1280–1288.34154984
277 Women’s Preventive Services Initiative (WPSI). Breast Cancer Screening for Average-Risk Women. https://www.womenspreventivehealth.org/recommendations/breast-cancer-screening-for-average-risk-women/. Published 2020. Accessed Accessed December 4, 2020.
278 NHS Breast Cancer Screening Programme. Breast screening: programme overview. https://www.gov.uk/guidance/breast-screening-programme-overview. Published 2015. Accessed September 3, 2020.
279 European Commission Initiative on Breast Cancer (ECIBC). European guidelines on breast cancer screening and diagnosis. https://healthcare-quality.jrc.ec.europa.eu/ecibc/european-breast-cancer-guidelines. Published 2022. Accessed August 18, 2022.
280 Klarenbach S, Sims-Jones N, Lewin G, . Recommendations on screening for breast cancer in women aged 40-74 years who are not at increased risk for breast cancer. CMAJ. 2018;190(49):E1441–E1451.30530611
281 Cancer Australia. Early detection of breast cancer. https://www.canceraustralia.gov.au/publications-and-resources/position-statements/early-detection-breast-cancer. Published 2015. Accessed August 31, 2020.
282 Habbema JD, van Oortmarssen GJ, van Putten DJ, Lubbe JT, van der Maas PJ. Age-specific reduction in breast cancer mortality by screening: an analysis of the results of the Health Insurance Plan of Greater New York study. Journal of the National Cancer Institute. 1986;77(2):317–320.3461193
283 Miller A, Wall C, Baines C, Sun P, To T, Narod S. Twenty five year follow-up for breast cancer incidence and mortality of the Canadian National Breast Screening Study: randomised screening trial [Journal: Article]. BMJ 2014;348. doi:10.1136/bmj.g366.
284 Moss SM, Cuckle H, Evans A, Johns L, Waller M, Bobrow L. Effect of mammographic screening from age 40 years on breast cancer mortality at 10 years’ follow-up: a randomised controlled trial. Lancet. 2006;368(9552):2053–2060.17161727
285 Bjurstam N, Björneld L, Warwick J, . The Gothenburg Breast Screening Trial. Cancer. 2003;97(10):2387–2396.12733136
286 Nyström L, Andersson I, Bjurstam N, Frisell J, Nordenskjöld B, Rutqvist LE. Long-term effects of mammography screening: updated overview of the Swedish randomised trials. Lancet. 2002;359(9310):909–919.11918907
287 Tabar L, Fagerberg G, Chen HH, . Efficacy of breast cancer screening by age. New results from the Swedish Two-County Trial. Cancer. 1995;75(10):2507–2517.7736395
288 Nelson HD, Pappas M, Cantor A, Griffin J, Daeges M, Humphrey L. Harms of Breast Cancer Screening: Systematic Review to Update the 2009 U.S. Preventive Services Task Force Recommendation. Ann Intern Med. 2016;164(4):256–267.26756737
289 Yaffe MJ, Mainprize JG. Risk of radiation-induced breast cancer from mammographic screening. Radiology. 2011;258(1):98–105.21081671
290 Sterne JA, Hernán MA, Reeves BC, . ROBINS-I: a tool for assessing risk of bias in non-randomised studies of interventions. BMJ. 2016;355:i4919.27733354
291 Dale A, Slade E, Heneghan C. Adjunctive ultrasonography for breast cancer screening. The Lancet. 2016;387(10036):2379–2380.