# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tracy Wolff and Howard Tracer at the Agency for Healthcare Research and Quality; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Patricia Ganz, MD, Gerald Gartlehner, MD, Nehmat Houssami, MBBS, MPH, MEd, PhD, Karla Kerlikowske, MD, and Lisa Newman, MD, MPH, FACS, FASCO, who provided expert review of the draft report; Erin Abramsohn, DrPH, on behalf of the Centers for Disease Control and Prevention, Sarah Temkim, MD, with the Office of Research on Women’s Health, Anna Maria Nápoles, PhD, MPH, and Arielle Gillman, PhD, MPH, on behalf of the National Institute on Minority Health and Health Disparities for providing federal partner review of the draft report; and Heidi Nelson, MD, MPH, for mentoring and expert input. Thanks to Eric (Rocky) Feuer from the National Cancer Institute and Steve Scoppa for technical assistance obtaining detailed SEER breast cancer surveillance data. We also thank Leslie Perdue, MPH, Jill Pope, Melinda Davies, MA, and Tracy Beil, MS, for technical and editorial assistance.