# Chapter 2 Methods

## Scope and Purpose

This updated review will focus new KQs for the USPSTF on the comparative effectiveness and harms of different screening strategies. These include strategies based on individual characteristics and risk markers of the screening population; mammography screening modalities (i.e., DBT versus DM); and screening delivery approaches (e.g., intervals, use of supplemental screening). This review does not include evidence on differences in the use of technologies intended to improve the reading of mammography (e.g., computer assisted, artificial intelligence) nor evidence on interventions aimed at increasing screening uptake or adherence. The evidence synthesis follows USPSTF procedures and methods for systematic reviews.^112^

## Key Questions and Analytic Framework

The review addresses three KQs, illustrated in an analytic framework (Figure 2), with predefined inclusion and exclusion criteria describing the target population, study design, intervention, and outcomes (Appendix B Table 1).

Figure 2 Analytic Framework

Key Questions

1. What is the comparative effectiveness of different mammography-based breast cancer screening strategies (e.g., by modality, interval, initiation age, use of supplemental imaging, or personalization based on risk factors) on breast cancer morbidity and breast cancer–specific or all-cause mortality?
  a. Does comparative effectiveness differ by population characteristics and risk markers (e.g., age, breast density, race and ethnicity, family history)?
2. What is the comparative effectiveness of different mammography-based breast cancer screening strategies (e.g., by modality, interval, initiation age, use of supplemental imaging, or personalization based on risk factors) on the incidence and progression to advanced breast cancer?
  a. Does comparative effectiveness differ by population characteristics and risk markers (e.g., age, breast density, race and ethnicity, family history)?
3. What are the comparative harms of different breast mammography-based cancer screening strategies (e.g., by modality, interval, initiation age, use of supplemental imaging, or personalization based on risk factors)?
  a. Do the comparative harms vary by population characteristics and risk markers (e.g., age, breast density, race and ethnicity, family history)?

Figure 2 is an analytic framework that depicts the three Key Questions. In general, the figure illustrates how breast cancer screening can reduce the incidence of advanced breast cancer, breast cancer morbidity and mortality, and all-cause mortality.

1. What is the comparative effectiveness of different mammography-based breast cancer screening strategies (e.g., by modality, interval, initiation age, use of supplemental imaging, or personalization based on risk factors) on breast cancer morbidity and breast cancer–specific or all-cause mortality?
  a. Does comparative effectiveness differ by population characteristics and risk markers (e.g., age, breast density, race and ethnicity, family history)?
2. What is the comparative effectiveness of different mammography-based breast cancer screening strategies (e.g., by modality, interval, initiation age, use of supplemental imaging, or personalization based on risk factors) on the incidence and progression to advanced breast cancer?
  a. Does comparative effectiveness differ by population characteristics and risk markers (e.g., age, breast density, race and ethnicity, family history)?
3. What are the comparative harms of different breast mammography-based cancer screening strategies (e.g., by modality, interval, initiation age, use of supplemental imaging, or personalization based on risk factors)?
  a. Do the comparative harms vary by population characteristics and risk markers (e.g., age, breast density, race and ethnicity, family history)?

## Data Sources and Searches

Studies included in the 2016 USPSTF reviews^76,95^ were evaluated for inclusion against the updated eligibility criteria for the current review. In addition, database searches of MEDLINE, Cochrane Central Register of Controlled Clinical Trials, and the Cochrane Database of Systematic Reviews were conducted by a research librarian for relevant studies published between January 2014 and August 22, 2022. A second research librarian peer-reviewed the search strategy (Appendix B). Additionally, investigators examined the reference lists of other previously published reviews, meta-analyses, and primary studies and new publications identified from table-of-contents alerts and searched ClinicalTrials.gov (https://ClinicalTrials.gov/) for ongoing trials. We supplemented these searches with suggestions from experts and articles identified through news and table-of-contents alerts. Ongoing surveillance to identify newly published studies was conducted through March 2024 to identify major studies published in the interim. Two new nonrandomized studies^113,114^ were identified and are not further discussed since they would not substantively change the interpretation of the review findings or conclusions. We managed all literature search results in EndNote® X9 (Thomson Reuters, New York, NY).

## Study Selection

Two reviewers independently evaluated all titles and abstracts using prespecified inclusion and exclusion criteria developed for this review (Appendix B Table 1). The full texts of potentially relevant studies were then further evaluated by two reviewers to determine final inclusion. Disagreements regarding inclusion at both the abstract and full text review level were resolved via discussion or with the input of a third reviewer as needed. A list of studies excluded during full text review are included in Appendix D, along with reasons for exclusion. DistillerSR (Evidence Partners, Ottawa, Canada) was used to conduct abstract and full-text review.

### Population

Routine breast cancer screening applies to adults with female sex-specific breast tissue without current symptoms of breast cancer, previous breast cancer, or high-risk breast lesions (DCIS, LCIS, atypical ductal hyperplasia, atypical lobular hyperplasia). Additional exclusions include adults with clinically significant genetic markers or syndromes associated with a high risk of breast cancer (e.g., BRCA1 or BRCA2 pathogenic variants, Li-Fraumeni syndrome) and those who received previous large doses of chest radiation before age 30 years because these represent high-risk conditions that may require different screening regimens. Screening in high-risk populations is outside the scope of the review.

We excluded studies conducted with populations receiving breast imaging performed for diagnostic or surveillance purposes, and studies that included a mix of screening and diagnostic populations where results were not stratified by indication. Studies of screening following gender-affirming medical treatment with exogenous estrogen, if such studies had been identified, would be excluded since care would be specific to individual clinical histories and involve specialty consultation beyond primary care. Throughout the report we incorporate gender inclusive language (people, individuals, persons with breasts) when referring to the screening population to recognize that not all people at risk of breast cancer and eligible for screening are women.^115^ We use the term women primarily when referring to studies using this language to reflect the evidence base yet acknowledge that previous studies did not collect nuanced data on gender and most likely conflated biological sex characteristics with gender. While the search and eligibility criteria for this review used an inclusive definition of women, all studies referred to their populations as women and this term was used in the report to reflect the evidence base. The review was limited to studies conducted in countries with “very high” Human Development Index scores (as of 2020) as published by the United Nations Development Programme.^116^

### Intervention and Comparison

We included studies that evaluated the following breast imaging screening modalities: DM, DBT, ultrasound, and MRI. All eligible studies included a comparator group that received screening with DM only in one of the study arms to assess the comparative effectiveness of screening relative to this established evidence-based practice. Studies were included that examined the effects of varying the primary mammography screening modality (e.g., DBT versus DM) or using supplemental/adjunctive imaging in addition to DM (e.g., DM plus ultrasound). In addition, we included studies that compared different screening strategies, including different screening intervals, ages to begin or end screening, and personalization of the screening program based on risk factors, markers, or risk assessment tools. We excluded studies of breast self-examination, clinical breast examination, and film mammography.

### Outcomes

Outcomes included for KQ1 were mortality (breast cancer and all-cause), breast cancer morbidity (e.g., treatment-related morbidity, physical/functional impairment), and quality of life or subjective well-being.

For KQ2, outcomes included advanced cancer detection and the stage distribution of screen-detected invasive breast cancers from at least two rounds of screening and followup. For the outcome of “advanced cancer,” data were abstracted as reported by the study authors. The majority of studies reporting “late-stage cancer” or “advanced cancer” define this as any cancer diagnosed at stage II or later, and in a few cases as stage IIB or later to exclude localized stage II cancers from the definition of advanced cancer. Some studies provided detailed data on the stage, node, and size of detected cancers. When possible, we prioritized reporting outcomes related to invasive cancers. We have noted cases where DCIS was reported combined with invasive cancer cases.

For KQ3, eligible harms outcomes included false-positive and false-negative findings at screening and biopsy, screening recall rate (need for further evaluation following screening), psychological harms (e.g., anxiety, depression, decrease in quality of life) associated with screening or followup, and overdiagnosis and overtreatment (as defined by the study), and rates of interval cancers (occurring between screening rounds) were included for KQ3. Rates of interval cancers reported in screening studies reflect a combination of clinically presenting cancers that were missed during previous screening examinations and incident cancers emerging between screening rounds or during a period of followup (ideally at least 12 months after screening).

### Study Design

To minimize bias, only individual-participant data meta-analyses, RCTs, controlled clinical trials, and cohort studies analyzing the outcomes of different screening strategies between comparison groups over a concurrent time period were included. Studies of test accuracy, including where participants served as their own controls to evaluate test performance (e.g., accuracy) were excluded, as were modeling studies. Nonrandomized studies were excluded if the comparison groups were highly selected based on factors that could influence breast cancer risk or health outcomes (e.g., family history or health status, breast density, access to health care, care seeking behaviors). Finally, we excluded studies that compared breast cancer mortality and detection outcomes at the population level if the study examined differences in screening outcomes by different regional policies affecting implementation since risks of bias in such ecological studies are untenably high.^117–120^

Studies of test performance studies and studies reporting cancer detection at a single round of screening were excluded because they are not able to provide adequate evidence that a breast screening program would necessarily improve health outcomes. The natural history of breast cancer is such that a screening test could be better at detecting cancers unlikely to impact health outcomes (overdiagnosis) or detect them at an earlier time without changing the outcome (lead time bias). Cancer sojourn time describes a related concept whereby slower growing cancers are stable and detectable for a longer period before advancing to metastatic disease and can therefore comprise a larger proportion of screen-detected cancers. While overdiagnosis is known to occur, its quantification in breast cancer screening programs is challenging, and studies have reported a wide range of estimates (11% to 22% based on individual data, higher estimates using aggregated data).^121–123^ All of these factors contribute to the understanding that a small increase in screening sensitivity might lead to detection of cases at an earlier point in time or with different characteristics without necessarily changing the risk of morbidity or mortality from breast cancer.^87^ Conversely, fast growing cancers with high metastatic potential may have similarly poor outcomes, even with small improvements in overall screening test sensitivity. Due to these factors, it is important to evaluate the effects of screening programs over several rounds of screening rather than at a single point in time, and to examine health outcomes to determine whether those screened benefited from the practice and the treatments received as a result.^123^

Studies were included for KQ2 only if they reported at least two rounds of screening and followup. Data from a second round of screening offer insight on the cumulative effects of screening and whether cancers detected at an earlier round were consequential or could have been detected and treated at a later point in time without adverse health consequences.^87^ This is important for the reasons described above. In the absence of health outcome results, a more effective screening program would be expected to reduce detection of advanced cancers that had progressed by a second round of screening relative to a comparison screening program.

Commonly reported outcomes on potential harms of screening (KQ3), including recall (i.e., return for additional imaging), false-positive recall, biopsy, and false-positive biopsy rates were obtained from the same studies included for effectiveness (KQ1/KQ2) or from studies providing data across multiple screening rounds. Studies with multiple screening rounds are essential for assessing harms where cumulative effects are important to consider. For example, a screening program with high recall at one round may show lower recall in subsequent rounds and the balance over time would be a more accurate measure of the outcome. Differences in screen detection of DCIS lesions can be viewed as a measure of potential overdiagnosis. The incidence of DCIS lesions has increased substantially with the advent of mammography screening programs, but their natural history and contribution to health risks remain unclear,^124^ as discussed above. Screen-detected DCIS may contribute to overdetection and overtreatment since patients may choose to undergo treatment (lumpectomy, mastectomy, radiation, hormone therapy).

For rates of interval cancer (including false negatives), results of studies with only a single round of screening were included because this finding has health implications at each round. Followup data to assess interval cancers can be obtained from a variety of sources, including prospectively collected data, cancer registries, administrative data, and medical records. For other uncommonly reported outcomes (e.g., quality of life; psychological health; radiation), we also included studies reporting findings based on a single round of screening, large population-based case-control studies, and followup surveys of patient experiences from participants in large trials or cohort studies.

Where multiple publications on similar analyses from the same registry or observational cohort studies were available, such as analyses using BCSC data, the most recently analyzed data available were selected for inclusion in the review.

## Quality Assessment and Data Abstraction

Two reviewers independently rated all eligible studies for potential risks of bias. Each study was given a rating of “good,” “fair,” or “poor” based on consensus from two reviewers. Discordant quality ratings were resolved through discussion and input from a third reviewer as needed. For randomized trials, USPSTF-specific criteria for assessing risk of bias were applied. For nonrandomized studies, we answered signaling questions from the Risk of Bias in Non-randomized Studies of Interventions (ROBIN-I) tool. Appendix B Table 2 lists the domains and criteria applied for each study design.

Good-quality studies met nearly all design-specific quality criteria indicative of good internal validity. These studies used valid randomization (for trials) or conducted appropriate statistical adjustments to create comparable study arms that were maintained throughout the study with minimal loss to followup. Given the nature of the screening intervention, lack of allocation concealment was not considered an important risk of bias domain. Studies rated fair quality did not have serious threats to their internal validity related to design, execution, or reporting, but were found to be at risk of bias for some criteria. Studies were rated poor quality if they had serious important limitations or a critical flaw that would likely affect the validity of study findings; these were excluded from this review. For nonrandomized studies, a rating of poor quality often resulted from an assessment of there being a very high risk of bias due to: confounding based on imbalances in baseline characteristics (without proper statistical adjustment); a lack of reporting of population characteristics by study arm; concerns about the classification of the intervention (e.g., self-reported screening interval, determination of diagnostic versus screening mammography); differences in followup procedures based on intervention arm; high or differential rates of attrition between groups; or evidence of possible selective reporting.

One reviewer extracted key elements of included studies into standardized evidence tables in DistillerSR (Evidence Partners, Ottawa, Canada). A second reviewer checked the data for accuracy. Evidence tables were tailored to each KQ, study design, and screening intervention. Tables generally included details on the study design and quality, setting and population (e.g., country, inclusion criteria, age, race and ethnicity, breast density, family history), screening features and protocol (e.g., modality, screening interval, reading procedure), and outcomes included for each KQ.

## Data Synthesis and Analysis

We created summary tables for all KQs to describe the study design, population, intervention characteristics, and outcomes in each included study. Individual study results were described for each KQ, and further grouped by comparison (i.e., modality, screening interval, age to start or stop screening) and outcome. When available, relative risks reported by study authors were provided in the tables, but we calculated and reported crude effect estimates and confidence intervals when studies provided only p-values, raw percentages, or other estimates of effects (e.g., odds ratios). To additionally facilitate comparisons among the studies, we converted effects to a common scale, as events per 100,000 individuals screened for mortality outcomes and per 1,000 individuals screened or examinations conducted for all others. We used summary tables and descriptive forest plots of the results to examine data for consistency, precision, and differences in effect sizes related to study and population characteristics.

Studies were considered for meta-analysis if they were sufficiently similar in terms of their study designs, populations, and reported outcomes. When very few studies were available (e.g., <5), we presented pooled effects only if the results were relatively consistent (overlapping confidence intervals) and exhibited modest clinical diversity and statistical heterogeneity (<50%). We used a random effects model with restricted maximum likelihood estimation. A fixed effects model was also computed for sensitivity analyses exploring the potential influence of the statistical model used on results. We also recognize that estimates of statistical heterogeneity are limited when very few studies are available for pooling and therefore considered heterogeneity based on the estimated effects and study features (e.g., design, population, comparison, and intervention protocols). For comparisons with few studies with clinically diversity or statistically heterogenous results, we did not generate pooled estimates using quantitative synthesis. We instead provided a narrative synthesis describing the findings separately for each KQ. Our synthesis sought to identify the range of effects as well as sources of heterogeneity and possible explanations for similarities and differences in the findings across different studies based on their identified sources of potential bias, study settings, populations, and screening intervention protocols.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ using the Evidence-based Practice Center (EPC) approach, which is based on an adaptation of the system developed by the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) Working Group.^125^ Four of five GRADE domains for assessing the strength of evidence are addressed in the EPC adaptation: consistency, precision, reporting bias, and study quality. The fifth domain, directness, is not addressed in the EPC approach since it is built into the structure of the analytic framework that underlies the KQs (i.e., link between the interventions and a health outcome).

Consistency (similarity of effect direction and size) was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision (degree of certainty around an estimate) was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there was insufficient evidence for a particular outcome) to address the potential for bias related to publication, selective outcome reporting, or selective analysis reporting. Study quality summarizes the degree to which the results are likely to have adequately low risk of bias (internal validity) based on individual study quality ratings. Additionally, the limitations domain highlights important constraints in answering the overall KQ.

Overall strength of evidence assessments were defined as “High,” “Moderate,” “Low,” or “Insufficient.” A rating of “High” indicates high confidence that the included evidence reflects the true effect, and that further research is very unlikely to change our confidence in the estimate of effects. A “Moderate” strength of evidence ratings indicates moderate confidence that the evidence reflects the true effect and recognizes that further research may change confidence in the estimate of effect or may change the estimate itself. A “Low” strength of evidence rating indicates low confidence that the evidence reflects the true effect, and that further research is likely to change the rating and the estimate itself. A grade of “Insufficient” is used to indicate that evidence is either unavailable or does not permit estimation of an effect. The strength of evidence judgments were independently completed by at least two reviewers, with discrepancies resolved through consensus discussion involving more reviewers.

## Contextual Questions

In addition to the systematically reviewed questions (KQs), we also addressed contextual questions (CQs) to aid with the broader interpretation of the evidence. Evidence for CQs was identified based on literature retrieved for the systematic search for KQs as well as targeted searches and scanning bibliographies of relevant articles. CQs are not systematically reviewed. We used a “best evidence” approach to identify the most recent, applicable, and robust evidence. Evidence related to the CQs is included throughout the Background and in dedicated sections of the Discussion to provide important context on breast cancer screening.

CQ1 How do racism, social inequalities, unequal access to high-quality health care, and other factors contribute to disparities in breast cancer incidence and outcomes? For example, what may account for higher breast cancer mortality among Black women in the United States?
CQ 2 How do new findings, analyses, or longer-term followup from foundational effectiveness trials of mammography screening influence conclusions about the benefits and harms of screening mammography?
CQ3 What risk assessment tools are available for use in average-risk screening populations and how well do they perform, particularly to support decisions about screening in younger women or women from racial and ethnic groups that are historically under-represented in research studies?
CQ4 How do the personal preferences of specific populations (including those that are under-represented in research) shape the ways in which they evaluate the potential harms and benefits of screening for breast cancer and decisions about whether to undergo screening?
CQ5 What are the harms of treatment associated with the detection of invasive breast cancer and DCIS?

## Expert Review and Public Comment

The draft Research Plan was posted for public comment on the USPSTF website from January 21, 2021, to February 18, 2021. Based on comments related to the scientific and conceptual scope of the review, the USPSTF revised the scope to require that effectiveness studies have data from at least two rounds of screening and include nonrandomized studies for the assessment of effectiveness. The USPSTF also clarified the proposed approach for including interval cancers and for defining advanced breast cancer. In addition, a proposed CQ on breast density assessment was replaced with a question on treatment harms. A final Research Plan was posted on the USPSTF website on May 6, 2021.

A draft version of this report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were addressed in revisions of this report when appropriate. Additionally, a draft of the report was posted for public comment on the USPSTF website from May 9, 2023, through June 6, 2023. The draft received many comments from individuals representing lay and professional perspectives, advocacy organizations, businesses, and scientific experts, leading to several editorial changes to more clearly explain the review scope and methods, add information about ongoing trials, and incorporate additional references related to the review context and framing. Relevant studies cited in the public comments were evaluated for potential inclusion in the review and none meeting the review criteria were identified.

Our review sought direct evidence from comparative studies to ascertain the comparative effectiveness of different screening programs. Future studies may determine whether supplemental screening is effective for women with modestly increased risk of breast cancer. Trials underway, such as TMIST and WISDOM, will hopefully bolster the evidence available for evaluating supplemental breast cancer screening programs.

## USPSTF Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and KQs and to resolve issues around scope for the final evidence synthesis. AHRQ staff provided oversight for the project, coordinated the systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.