# Chapter 1 Introduction

## Purpose

This comparative effectiveness evidence review and synthesis will be used by the U.S. Preventive Services Task Force (USPSTF) to inform its update to the 2016 recommendations on breast cancer screening.^1^

## Condition Background

### Condition Definition

Breast cancer is a proliferation of malignant cells that usually originates in the terminal ductal-lobular unit in breast tissue.^2^ Invasive breast cancer extends through the basement membrane of the breast and into the adjacent stroma, allowing for potential metastatic spread. The most common sites of metastases are adjacent lymph nodes, lung, liver, and bone. The most common invasive breast cancer is invasive (infiltrating) ductal carcinoma, histologically categorized as “no special type.” A smaller percentage (5%–15%) are invasive (infiltrating) lobular carcinoma. The remainder of invasive cancers are less common subtypes with specific histologic features (20%–30%) including tubular, papillary, apocrine, medullary, metaplastic, and mucinous.^3^

Noninvasive (in-situ) lesions are contained in the ductal-lobular unit and do not extend into the basement membrane or surrounding tissue. When confined to the duct, these lesions can be classified as usual ductal hyperplasia (UDH), flat epithelial atypia (FEA), atypical ductal hyperplasia (ADH), or ductal carcinoma in situ (DCIS).^4^ DCIS is heterogenous and has varying clinical behavior and pathologic characteristics; some forms are viewed as precursor lesions for invasive ductal carcinoma and it is sometimes referred to as noninvasive or stage 0 cancer.^5^ DCIS accounts for approximately 20 to 25 percent of all breast neoplasms, and incidence has increased with the widespread use of mammographic screening.^4^ Lesions confined to the lobule are less common and include lobular intraepithelial neoplasia (LIN), lesions composed of benign, non-infiltrating lobular proliferations of the mammary epithelium; atypical lobular hyperplasia (ALH); and lobular carcinoma in situ (LCIS).^6,7^ LIN is an established risk marker for invasive ductal or lobular breast cancer because it is associated with bilateral invasive cancer.^6,8^

### Prevalence and Burden

Overall, among U.S. women, breast cancer is the second most common cancer (excluding non-melanoma skin cancer) and the second most common cause of cancer death after lung cancer.^9^ In 2019, an estimated 3,771,795 women were living with invasive breast cancer in the United States.^10^ With respect to yearly incidence, in 2022 an estimated 287,850 women in the United States were diagnosed with invasive breast cancer (representing 15% of all new cancer cases) and 43,250 were estimated to have died of breast cancer (representing 7% of all cancer deaths).^11^ Although it is the second leading cause of cancer mortality for women overall,^12^ it is the leading cause of mortality from cancer for Hispanic women.^13^ Based on the most recent lifetime risk estimates for the general population, approximately 12.9 percent of women will develop breast cancer during their lives, and 2.6 percent will die of the disease.^14^

An increasing trend in invasive cancer incidence has been observed with the widespread adoption of breast cancer screening programs. Overall, since 2004 there has been a 0.5 average annual percent rise in invasive cancer diagnoses.^15^ A steeper increase in incidence has been observed for individuals ages 40 to 49 years from 2015 to 2019 (2.0 average annual percent change; rates were 162 per 100,000 in 2015 compared with 172 per 100,000 in 2019). The rising incidence is mainly attributed to increases in the diagnosis of localized cancers.^16^ Mortality from breast cancer has continued to decline, albeit less steeply in recent years; by approximately 1.3 percent each year on average from 2010–2019.^15^

Breast cancer incidence varies by age and race (Table 1, Figure 1). Incidence rates for invasive cancer are highest for women ages 65 to 74 (447.7 per 100,000) and decline with further increasing age.^10^ Overall, average rates of invasive breast cancer from 2015–2019 were highest among non-Hispanic White women (137.6 per 100,000 women) and second highest for non-Hispanic Black women (129.6 per 100,000).^10^ Hispanic women of any race experienced the lowest incidence (99.9 per 100,000). Rates are slightly higher for non-Hispanic Asian/Pacific Islander women (106.9 per 100,000) and non-Hispanic American Indian/Alaska Native (AI/AN) women (111.3 per 100,000 women),^10^ although incidence rates for the AI/AN population vary widely by region.^17^

Figure 1 Breast Cancer Incidence Rates by Age at Diagnosis, 2015 to 2019, by Race and Ethnicity

Figure 1 shows breast cancer incidence at age of diagnosis and by race and ethnicity, from 2015 to 2019.

Source: SEER Explorer^10^

Table 1 Breast Cancer Incidence and Mortality, by Age and Race/Ethnicity

| Incidence of New Cases^*^; (per 100,000 women, per year) | Mortality Rate^†^; (per 100,000 women, per year)
Age (years)
30-34 | 30.9 | 2.9
35-39 | 64.9 | 6.6
40-44 | 132.9 | 11.5
45-49 | 199.9 | 18.0
50-54 | 238.1 | 27.1
55-59 | 273.0 | 36.0
60-64 | 343.9 | 45.3
65-69 | 428.9 | 56.8
70-74 | 477.7 | 71.4
75-79 | 460.2 | 90.0
80-84 | 416.5 | 115.0
[underlined: ≥]85 | 325.0 | 174.3
Race and Ethnicity
Non-Hispanic White | 137.6 | 19.7
Non-Hispanic Black | 129.6 | 27.6
Non-Hispanic Asian/Pacific Islander | 106.9 | 11.7
Non-Hispanic American Indian/Alaska Native | 111.3 | 17.6
Hispanic | 99.9 | 13.7

* U.S. 5-year age-adjusted incidence (2015-2019), all stages.

† U.S. 5-Year age-adjusted mortality rates by age at death (2016-2020), all stages.

Source: SEER 5-Year Age-Adjusted Incidence Rates (2015-2019)^271^ and U.S. Mortality Rates by Age at Death (2016-2020)^23^

Stage at diagnosis also varies by age and race (breast cancer staging is described in Appendix F Table 1). Case incidence is the lowest for younger age groups (23.7 per 100,000 for all women ages 15 to 39 years), but younger women are more likely to be diagnosed at a later stage (50.2% at regional or distant stage for women ages 15 to 39 years) than older women (35.3% for women ages 40 to 64 years; 27.3% for women ages 65 to 74 years; 28.3% for women age 75+ years at either regional or distant stage at diagnosis).^11^ Non-Hispanic Black women are more likely to be diagnosed with cancer beyond stage 1 than other race and ethnic groups, and even small tumors are more likely to present with lymph node involvement or metastases.^18^

Breast cancer mortality has steadily declined since the 1990s but remains persistently higher for Black women than for all other race and ethnicity groups (Table 1).^19,20^ Black women are 40 percent more likely to die of breast cancer compared with White women,^21^ despite reporting similar or higher guideline concordant screening^22^ and lower overall breast cancer incidence. Current estimates of breast cancer mortality (2016 to 2020) are 27.6 per 100,000 among non-Hispanic Black women compared with 19.7 per 100,000 for non-Hispanic White women.^23^ Breast cancer mortality rates are lower among Hispanic (13.7 per 100,000), Asian/Pacific Islander (11.7 per 100,000), and AI/AN women (17.6 per 100,000). In terms of survival among those diagnosed with breast cancer, estimates from 2012–2018 showed an overall 5-year survival rate for breast cancer of 92.0 percent for White women and 82.6 percent for Black women.^13^ Five-year breast cancer survival from the estimates for Hispanic, Asian/Pacific Islander, and AI/AN women were also higher than for Black women (88.3%, 91.6%, and 90.1%, respectively). There are also disparities in incidence and survival among Black women under the age of 40. While screening is not currently recommended before age 40 because incidence rates are very low (23.7 per 100,000),^10^ Black women diagnosed with breast cancer before age 40 have the highest mortality (3.9 per 100,000)^10^ and lower 5-year survival (76.9% compared to 87.1% for White women),^24^ and the breast cancer mortality rate for Black women ages 35 to 39 is nearly double that of White women in the same age group (11.3 versus 6.2 deaths per 100,000).^23^ These inequities are discussed in detail later in this report (see Discussion).

### Etiology and Natural History

Breast cancer develops through inherited and acquired pathogenic variants in oncogenes and tumor suppressor genes that would otherwise support normal cellular growth and replication. Inherited pathogenic variants in breast cancer susceptibility genes (e.g., BRCA1, TP53, PTEN) represent the minority of breast cancer cases. Most cases are sporadic arising from endogenous and exogenous environmental factors. Specific external influences, such as toxic environmental exposures, known to act on specific regulatory gene have not yet been elucidated.^25,26^ Estrogen and progestin are also implicated in tumorigenesis and growth due to the observed associations of factors such as age of menarche and menopause and parity.^26^ Other potential pathways from external exposures to breast cancer continue to be investigated, including possible roles of biological aging related DNA methylation,^27^ vitamin D,^28^ inflammatory conditions,^29^ sleep patterns,^30^ and virally mediated carcinogenesis.^31^

Most breast cancers are invasive, meaning that they have infiltrated surrounding breast tissue beyond the ducts or glands where they originated. Cancer subtypes are classified according to their histology and molecular markers (e.g., ER, PR, HER2). The three main clinical subtypes of invasive breast cancer that are commonly assessed using biological markers are hormone receptor (HR) positive, human epidermal growth factor receptor 2 (HER2) positive, and triple-negative breast cancer that does not contain HR receptors (progesterone or estrogen) or HER2. Prognosis and treatment are informed by these factors.^32–35^ The most common breast cancer subtype defined by receptor status is HR+/HER2-, also referred to as Luminal A tumors, and this subtype represents nearly three-quarters of invasive breast cancers (73%). These tumors are usually less aggressive than other subtypes and responsive to hormone therapy, resulting in a better prognosis. Luminal B (HR+/HER2+) tumors, representing approximately 11 percent of invasive breast cancers, are often higher grade than Luminal A tumors and have poorer outcomes. (High positivity of an additional marker for protein Ki67 that indicates actively dividing cells is also sometimes used to help define this subtype.) Twelve percent of invasive breast cancers are triple negative (HR-/HER2-).^32^ Compared to the other subtypes, triple-negative cancers have the worst prognosis, and reductions in mortality over the past two decades have been smaller for people affected by these cancers than for all other subtypes.^36^ In the United States, triple-negative cancers are twice as common among Black women (24.1 per 100,000) compared with White women (12.4 per 100,000).^37^ Triple-negative cancers account for 19 percent of breast cancers diagnosed among Black women compared with 9 percent of cancers diagnosed among White women and 11 percent of cancers among Hispanic and among Asian/Pacific Islander women.^14^ Rates are also lower among Hispanic (11.0 per 100,000), AI/AN (10.8 per 100,000), and Asian/Pacific Islander (9.1 per 100,000) women.^37^ These cancers occur more often in premenopausal women and those with BRCA1 gene mutations.^38^ Regardless of the cancer subtype based on receptor status, stage at diagnosis is the strongest prognostic factor.

Ductal carcinoma in situ (DCIS) is the most common noninvasive breast condition detected with mammography.^14^ Approximately 16 percent of breast neoplasms (invasive cancer and in situ conditions) diagnosed in the United States are DCIS.^32^ Most DCIS cases are diagnosed with breast imaging, owing to the widespread use of screening mammography and its ability to identify microcalcifications.^39,40^ Older studies of palpable DCIS lesions indicated that 14 to 53 percent of untreated DCIS progress to invasive cancer over 8 to 22 years.^41^ These studies may have limited applicability, however, since the natural history of screen-detected lesions would likely differ from clinically presenting cancers, and represent the majority of DCIS cases in the current era of widespread mammography screening. It is also not clear whether some DCIS cases regress, and the potential for overdiagnosis of breast cancer hinges heavily upon this possibility.^42^ Because treatment is generally recommended, the natural history of screen-detected DCIS is unclear in terms of the percentage of cases that would have progressed to invasive cancer in the absence of treatment.^33^

DCIS is considered a precursor lesion or a risk marker for invasive cancer, especially for specific groups or when certain features are present.^4,43^ Characteristics found to be associated with subsequent invasive breast cancer include detection at a young age, clinical detection (palpation rather than screen detection), and detection in a person with Black race.^44^ Lesion characteristics such as involved margins, high histologic grade, and high p16 expression are also associated with risk for subsequent invasive cancer.^45–47^ A recent population-based analysis identified a threefold increase in breast cancer mortality over 20 years after DCIS diagnosis and treatment, half due to contralateral invasive breast cancer.^44^ These findings suggest that in addition to posing a risk of local progression to invasive cancer, DCIS is also a marker of elevated breast cancer risk.

### Breast Cancer Risk Factors

Risk for primary breast cancer is highest among women with previous high-risk breast cancer lesions (DCIS, LCIS, atypical ductal hyperplasia, atypical lobular hyperplasia); extensive family histories of breast and ovarian cancer; clinically significant genetic markers or syndromes associated with a high risk of breast cancer (e.g., BRCA1 or BRCA2 pathogenic variants, Li-Fraumeni syndrome); or previous large doses of chest radiation before age 30 years. Women in these high-risk groups require different screening regimens than the general population.^48,49^

Non-modifiable factors associated with increased risk among women eligible for routine screening include increased age;^10^ at least one first- or second-degree relative with breast cancer;^50–52^ and heterogeneously or extremely dense breast tissue.^53^ Women in their 40s with extremely dense breast tissue or at least one first-degree relative with breast cancer are estimated to have a twofold increased risk of breast cancer.^50^ Additional risk factors that have been associated with an increased risk of breast cancer include use of menopausal hormone therapy, increasing body mass index (BMI), alcohol use, and nulliparity or giving birth after age 35.^54^ Risk factors associated with a decreased risk of breast cancer include breastfeeding and increased physical activity.^54^

Breast density is a radiographic measure of breast tissue that is associated with increased risk for breast cancer and reduced mammography sensitivity. It describes the amount and distribution of dense fibrous and glandular tissue relative to surrounding fat tissue. Having more dense breast tissue may make it more difficult to find tumors using imaging technologies. Breast density is currently evaluated with the BI-RADS (Breast Imaging Reporting and Data System) to standardize the interpretation of mammography results using four categories: (a) almost entirely fatty, (b) scattered fibro glandular densities, (c) heterogeneously dense, and (d) extremely dense.^55^ These last two categories represent women considered to have dense breasts. Reproducibility of classifications is inconsistent and one in five women would be categorized into a different BI-RADS density category by the same radiologist during the next examination.^56^ Increased breast density is more common among younger women, although it occurs in roughly one-third of women older than 65 years.^57,58^ Distributions of breast density estimated from Breast Cancer Surveillance Consortium (BCSC) data^59^ indicate that among premenopausal women, over half are considered to have dense breasts (heterogeneously or extremely dense); proportions are highest among Asian women (80%) compared with White women (61%), Black women (56%), and Hispanic women (57%). In menopause, the proportion of women with dense breasts are lower, but remain highest among Asian women (55%) compared with White women (38%), Black women (32%), and Hispanic women (31%).

Interactions between hormonal status, breast density, and cancer risk suggest a complex relationship. Breast density can change over time, and associated risks of invasive breast cancer can vary within individuals across the lifespan.^60^ Breast density is influenced by hormonal medications (such as tamoxifen or postmenopausal hormone replacement therapy), pregnancy, BMI, and age.^61,62^ Data from the BCSC suggest that having heterogeneously or extremely dense breasts (compared with scattered fibroglandular density) accounts for higher population-attributable risk proportion of invasive breast cancers for premenopausal women (24%–35%) than for postmenopausal women (13%–17%).^59^ The study also reported differences according to race and ethnicity in the contributions of BMI, breast density, and menopausal status to invasive breast cancer risks. For example, while more Asian women are classified as having dense breasts, the magnitude of the association of extremely dense breasts with their invasive cancer risk was lower relative to Black, White, and Hispanic women. With regard to BMI, premenopausal White women with BMI >35 had increased breast cancer risk, but the association was not observed for Black, Asian, and Hispanic women, whereas for postmenopausal women, increased risks for breast cancer for all groups were seen among those with BMI >35, and the risk was most elevated for Asian and Black women.^59^

A large cohort study from the United States highlights the potential importance of including additional risk factors to inform supplemental screening strategies and reduce false-positive rates. Data for the years 2005 to 2014 from a prospective screening cohort of 638,856 women ages 40 to 74 years obtaining digital mammography at BCSC imaging facilities provides important epidemiologic information on the association of breast density with invasive cancer incidence.^63^ Nearly half (47%) of women screened were identified as having dense breasts (heterogeneously or extremely dense) and overall 60 percent of advanced cancers were in these women. One-third of women with dense breasts, however, had very low rates of advanced cancer within a year of screening. The highest rates of advanced cancer were seen in women with heterogeneously dense or extremely dense breasts and at least 2.5 percent 5-year risk of breast cancer calculated using the BCSC risk calculator (described below).

An analysis of temporal trends in BI-RADS density readings from over 2 million mammography screenings at BCSC facilities found that despite changes in classification guidelines and the increasing use of DBT for screening, the distribution of breast density across time and age groups has remained relatively stable.^64^ Breast density over the lifespan in individual women, however, is known to change, and there is evidence that reductions in density are associated with reduced risk for invasive cancer.^65^

#### Multivariable Risk Prediction

Models estimating risk for breast cancer include common clinical risk factors, such as age, age at menarche, age at birth of first child, number of first-degree relatives with breast cancer, and results of previous benign breast biopsies. Additional variables differ between models including race, BMI, breast density, menopause status, use of hormone therapy, and additional family histories, among others. Risk factors are categorized and weighted differently in each model.^66–73^ Risk estimation from genome wide association studies is also being used to develop polygenic risk scores.^74^ Estimates of lifetime risk of breast cancer of over 15 or 20 percent are considered high.^53^ Although several risk prediction models have been developed for clinical use, current versions demonstrated poor predictive performance in estimating an individual woman’s risk when validated in screening populations.^72^

## Rationale for Screening and Current Clinical Practices

Screening for breast cancer is a secondary prevention intervention that is initiated through primary care or other cancer prevention focused practice settings. Screening can prevent breast cancer morbidity and mortality by identifying cancer at an earlier stage than it would have presented clinically, allowing for lower intensity treatment and higher survival rates. Screening is based on mammography technology used to visually detect lesions before they become clinically apparent (Appendix F Table 2).

Randomized trials have established the overall effectiveness of mammography screening in reducing breast cancer mortality for women ages 50 to 69 years and were the focus of previous reviews for the USPSTF.^75,76^ Longer-term followup and secondary analyses of these foundational screening effectiveness trials have been published since the 2016 review conducted for the USPSTF, but the results do not substantively change earlier conclusions (see Discussion).^77–81^ Additionally, these older trials have limited value for identifying differential effectiveness for different subgroups of participants (apart from age differences) due to the populations enrolled and study designs. New trials of screening cannot ethically randomize participants to no screening since screening is now known to confer a mortality benefit. As for other topics that the USPSTF considers where an intervention is established, new trials seek to refine the approach using active comparators (comparative effectiveness trials).

Current practice guidelines from professional societies, guideline groups, and governmental agencies recommend breast cancer screening for average-risk women beginning no later than age 50 (Table 2). Differences across guidelines concern appropriate ages to begin and discontinue routine screening, role of risk assessment in screening decisions, appropriate screening interval, and type of screening modality. Only the American College of Obstetricians and Gynecologists (ACOG) practice guideline refers to supplemental testing in women with dense breasts.

Table 2 Breast Cancer Screening Guidelines From Other Organizations

| Society or Professional Organization, Year | Age to Begin Screening – Recommended | Screening Frequency – Recommended | Age to Stop Screening | Screening Test
| Society or Professional Organization, Year | Age to Begin Screening – Recommended | Screening Frequency – Recommended | Age to Stop Screening | DM/FM | DBT
United States-Based Society or Professional Organization | The American Cancer Society (ACS), 2015^272^ | 45^*^ | 45-54: Annual; 55+: Biennial | As long as in good health, and with 10+ years of life expectancy | Y | -
United States-Based Society or Professional Organization | The American Academy of Family Physicians (AAFP), 2020^273^ | 50^*^ | Biennial | 75, or with <10 years life expectancy | Y | N
United States-Based Society or Professional Organization | The American College of Obstetrics and Gynecology (ACOG), 2017^274^ | 50^*^ | Annual or Biennial | 75, or continue based on shared decision-making | Y | -
United States-Based Society or Professional Organization | The American College of Physicians (ACP), 2019^275^ | 50^*^ | Biennial | 75, or with <10 years of life expectancy | Y | Y
United States-Based Society or Professional Organization | The American College of Radiology (ACR), 2021^276^ | 40 | Annual | No limit, unless limited life expectancy | Y | O
United States-Based Society or Professional Organization | The National Comprehensive Cancer Network (NCCN), 2019^33^ | 40 | Annual | No limit, unless limited life expectancy | Y | Y
United States-Based Society or Professional Organization | Women’s Preventive Services Initiative (WPSI), 2020^277^ | 40-50^*^ | Annual or Biennial | As long as in good health | Y | -
International Society or Professional Organization | United Kingdom (UK) National Health Service, 2020^278^ | 50 | Triennial | 71 | Y | -
International Society or Professional Organization | The European Commission Initiative for Breast Cancer (ECIBC), 2022^279^ | 45 | 45-49: Biennial or Triennial; 50-69: Biennial; 70-74: Triennial | 75 | Y^†^ | Y^†^
International Society or Professional Organization | The Canadian Task Force on Preventive Health Care, 2018^280^ | 50 | Biennial or Triennial | 75 | Y | N
International Society or Professional Organization | Cancer Australia, 2020^281^ | 50^*^ | Biennial | 75; (Optional: no limit) | Y | -

* These organizations include recommendations to begin screening starting at age 40 years for some women based on shared decision-making.

† The ECIBC recommends using either DM or DBT, but not both. For women with dense breasts, it is recommended that DBT is used.

Abbreviations: DBT=digital breast tomosynthesis; DM=digital mammography; FM=film mammography; N=does not recommend; O=optional, based on shared decision-making between the patient and her provider; Y=recommended

Conventional digital mammography (DM) has essentially replaced film mammography as the primary method for breast cancer screening in the United States and involves conversion of x-rays that pass through the breast tissue to electronic signals that produce a digital image. Routine screening with DM images the breast from two angles (craniocaudal and mediolateral oblique). Digital breast tomosynthesis (DBT) is a newer technology that is increasingly being used as a primary breast cancer screening strategy. The technology acquires images from multiple angles and is sometimes referred to as 3D mammography. Screening with DBT is usually accompanied by DM imaging, but some imaging devices can produce “synthetic” 2D mammography (sDM) images equivalent to the two-view screening image from standard mammography.^82,83^ An increase of 20 to 30 percent in radiation dose has been observed with DBT compared with conventional DM. When DBT is performed in combination with DM the radiation dose is at least double that of DM alone. The use of sDM constructed based on DBT images reduces the total radiation dose by 30 to 40 percent compared with DBT plus DM screening.^84^ Recent systematic reviews have found no significant difference in the accuracy of DBT with DM or sDM.^85,86^ However, DBT/sDM was found to reduce the number of patient recalls (p=0.006) as well as improve the positive predictive value of screening (p=0.047) compared with DBT/DM.^86^

In addition to primary screening, the value of supplemental screening for women with dense breasts is an active area of research. The lack of a standardized and reliable assessment tool for measuring breast density, and its variability over a woman’s lifespan, pose challenges for research into the optimal screening strategy for women identified as having dense breasts. The supplemental screening modalities used to screen women with dense breasts include handheld breast ultrasonography, automated whole breast ultrasound, magnetic resonance imaging (MRI), and DBT. Limited data are available for evaluating its performance in average-risk populations with only breast density as a risk factor.

The potential harms of breast cancer screening include a risk of false-positive results which may lead to psychological harms, additional testing, and invasive diagnostic followup procedures (e.g., biopsy). In addition, overdiagnosis and overtreatment are harms from the detection, diagnosis, and treatment of DCIS or invasive cancers that would not have led to health problems without detection.^87,88^ The recurrent radiation exposure from a lifetime program of mammography screening has been proposed as increased risk for breast cancer, particularly for women with larger breasts.^89^ DBT screening has been associated with an increased risk for breast biopsy compared with conventional DM and higher radiation exposure when performed in conjunction with conventional DM, which has been estimated to be as much as two times greater than that associated with DM (with women with dense breasts exposed to even higher doses).^90,91^ However, this level of radiation exposure falls below the U.S. Food and Drug Administration limit for standard mammography^92,93^ and newer, synthetic 2D DBT can lower radiation to levels comparable to or slightly above those of a conventional mammogram.^94^ Potential harms of supplemental screening in women with dense breasts may include additional false-positive recall and biopsies when compared with standard screening mammography.^95^

There are several approaches to reading mammography images, including single and double reading, computer-aided detection (CAD), and artificial intelligence–supported reading. While mammography reading by two radiologists (double reading) is standard practice in parts of Europe,^96,97^ single reading is more common in the United States. These different approaches to mammography reading can affect the test performance of the different modalities.^98–100^

Although the USPSTF’s 2016 recommendation statement for screening in average-risk populations did not endorse use of DBT, a 2019 study found a strong increase in its utilization for breast cancer screening in the United States. In 2015, DBT was used for 12.9 percent of screening examinations, and by 2017, was used in 43.2 percent of screening examinations.^101^ As of December 2020, 74 percent of facilities certified by the Mammography Quality Standards Act (MQSA) program were certified for both DBT and full-field DM.^102^

Many U.S. states have enacted breast density notification laws that require insurance coverage for supplemental screening in women with dense breasts and notification directly to women regarding their breast density results and the potential effect of their breast density on the sensitivity of screening and breast cancer risk.

### Interventions and Treatment Approaches

Patients with suspicious mammographic abnormalities (or palpable breast masses) may undergo additional diagnostic imaging as well as biopsy.^103,104^ The most common type of biopsy is needle biopsy (core needle biopsy or fine needle aspiration); surgical biopsy is performed if the results of the needle biopsy are unclear.^105^ The pathologic stage of cancer is used to determine prognosis and inform treatment decisions.

The American Joint Committee on Cancer (AJCC) system defines cancer stages based on tumor size (T), lymph node involvement (N), and presence of metastasis (M) (Appendix F Table 1).^106^ The most recent eighth edition of the AJCC staging guidelines incorporates histologic grade and biomarkers, including estrogen receptor (ER) expression, progesterone receptor (PR) expression, human epidermal growth factor receptor 2 (HER2) expression, and commercially available gene-based assay results.^107^ Main categories are generally defined as noninvasive cancers, such as DCIS (stage 0), localized (stage I and some stage II), locally advanced or regional (some stage II and stage III), and metastatic disease (stage IV).

Treatment regimens are highly individualized according to each patient’s clinical status, cancer stage, tumor biomarkers, clinical subtype, and personal preferences, and vary in potential side effects.^33,108^ Surgical investigation is sometimes required to determine whether neighboring lymph nodes have been affected. Biopsy of sentinel nodes has demonstrated fewer long-term harms; however certain scenarios encourage investigation of the axillary nodes. Axillary lymph node dissection carries higher risk of long-term harms including numbness, swelling and pain, and is more likely to be utilized on Black and Hispanic women, as well as women without health insurance.^109,110^ Survival varies by stage, and the 5-year relative survival rates for breast cancer in the United States are 99.1 percent with localized disease, 86.1 percent with regional disease, and 30 percent with metastatic disease.^11^

## Previous Evidence Reviews

Multiple evidence reviews were used to update the 2016 USPSTF breast cancer screening recommendation.^95,111^ Previous reviews addressed key questions (KQs) on the effectiveness of mammography screening in reducing breast cancer–specific and all-cause mortality, advanced breast cancer, and treatment-related morbidity compared with no screening and harms of screening. Results of KQs for the evidence review on benefits and harms of screening are summarized in this section of the report because the current evidence update does not update the foundational evidence of the effectiveness of mammography compared with no screening. A detailed summary of these findings is provided in Appendix A.

### Screening Effectiveness

Nine fair-quality randomized controlled trials (RCTs) comparing mammography screening with nonscreening provided outcomes that addressed several KQs in the 2016 review.^76^ Trials enrolling over 600,000 women were conducted in the United States, Canada, United Kingdom, and Sweden. Across all trials, the mean or median screening intervention time ranged from 3.5 to 14.6 years, case accrual time from 7.0 to 17.4 years, and followup time from 11.2 to 21.9 years. Meta-analyses were conducted for breast cancer mortality outcomes using the longest followup data available. These analyses estimated that over a 10-year period, screening 10,000 women ages 50 to 69 would result in 12.5 (95% CI, 5.0 to 19.5) fewer breast cancer deaths; however, estimates were not statistically significant for women ages 39 to 49 years and those ages 70 to 74 years. All-cause mortality was not reduced with screening for any age group. A statistically significant reduction in advanced disease was found for women age 50 years or older who were randomly assigned to undergo screening, but not for women ages 39 to 49 years. In general, observational studies reported greater breast cancer mortality reduction (25% to 31% among women invited to screening) than RCTs (19% to 22% using intention-to-treat analysis) for women ages 50 to 69 years. Two observational studies of women in their 40s invited to or participating in screening indicated 26 to 44 percent reduction in breast cancer mortality.

### Screening Harms

Harms of screening summarized in the 2016 evidence review^76^ included false-positive and false-negative results, additional imaging, and biopsy; overdiagnosis; anxiety, distress, and other psychological responses; pain and discomfort; and radiation exposure. False-positive results were common and are higher for annual screening, younger women, and women with dense breasts. Although overdiagnosis, anxiety, pain, and radiation exposure may cause harm, their effects on individual women are difficult to estimate and vary widely.

## Previous USPSTF Recommendations

In 2016, the USPSTF recommended biennial screening mammography for women ages 50 to 74 years (B recommendation) and concluded that the decision to start screening mammography in women prior to age 50 years should be an individual one (C recommendation). Additionally, the USPSTF concluded that the current evidence is insufficient to assess the balance of benefits and harms of screening mammography in women age 75 years or older (I statement), the use of DBT as a primary screening method (I statement), or the use of supplemental screening methods in women identified to have dense breasts (I statement).^1^