# Appendix H Ongoing Studies

Appendix H Table 1 Ongoing Trials of Mammography Screening Strategies and Modalities

Intervention | Study Name; Trial Identifier; Location | Planned Study Population | Intervention | Relevant Outcomes | Status^*^
Age to Start/Stop | None identified
Screening Interval | MISS; (NCT04590560); Italy | 60,000 women ages 45 to 49 years | Annual vs. biennial screening with DBT and sDM (based on breast density) | Cancer detection; Interval cancer rate; Recall rate | Ongoing; Expected completion date, February 2026
Screening Interval | TBST; (NCT02619123); Italy | 33,200 women ages 44 to 45 years | Annual screening vs. tailored screening (women in the intervention group with BI-RADS 3 or 4 density will be invited to screen again after 1 year, while women with BI-RADS 1 or 2 density will be invited after 2 years. After age 50, all women will be screened according to usual care) | Cancer detection; Interval cancer rate; False positive rates | On hold; Results will be part of a pooled analysis with a recently funded study looking at screening intervals
Modality | PROSPECTS; (NCT03833106); United Kingdom | 100,000 women ages 49 to 71 years | DBT + DM vs. DM | Cancer detection; Interval cancer rate; Recall rate | Ongoing; Estimated completion date, July 2024
Modality | TOSYMA; (NCT03377036); Germany | 80,000 women ages 50 to 69 years | DBT vs. DM | Cancer detection; Interval cancer rate; Recall rate | Ongoing; Estimated completion date, March 2025
Modality | MAITA; (NCT04461808); Italy | 8,000 women ages 45 to 65 years | DBT vs. DM | Cancer detection; Interval cancer rate; Recall rates; Biopsy rates | Ongoing; Expected completion date, June 2026; Interim findings (first-round followup) will be published in 2024
Modality | TMIST; (NCT03233191); United States, Canada | 128,905 women ages 45 to 74 years | DBT vs. DM | Breast cancer–specific mortality; Cancer detection; Interval cancer rate; Recall rates; Biopsy rates | Ongoing; Expected completion date, December 2030
Modality | IMPETO; (NCT03587259); Italy | 6,000 women ages 45 to 46 years | DBT vs. DM | Cancer detection; Recall rate; Biopsy rate | Ongoing; Enrollment postponed due to COVID-19
Personalization | WISDOM; (NCT02620852); United States | 100,000 women ages 40 to 74 years | Annual screening vs. tailored screening (annual screening with an individualized, risk-based screening schedule) | Cancer detection; Interval cancer rate; Recall rate; Biopsy rate | Ongoing; Estimated completion date, March 2025; Interim findings (patient-centered outcomes, mutation carrier characteristics, polygenic risk score analysis) will be published in late 2022/early 2023
Personalization | MyPeBS; (NCT03672331); Europe, Israel | 85,000 women ages 40 to 70 years | Standard screening based on national/regional guidelines vs. risk-based screening (screening interval based on estimated 5-year risk of developing breast cancer, via DM and/or DBT every 1 to 4 years, with or without ultrasound, depending on breast density) | Breast cancer–specific survival (including combined analysis with WISDOM trial); Cancer detection; Interval cancers; False-positive imaging and benign breast biopsies | Ongoing; Estimated completion date, December 2025

* Status is based on published results, information provided by investigators, or expected completion date as reported in clinicaltrials.gov.