# Appendix G Detailed Methods and Results of Screening Harms

## Detailed Results for KQ3. What Are the Comparative Harms of Different Breast Mammography-Based Cancer Screening Strategies?

### Screening Age to Start or Stop

#### Study and Population Characteristics

One fair-quality NRSI (n = 1,058,013)^136^ analyzed data to emulate a trial of discontinuation of mammography screening at age 70 compared with continued annual screening beyond this age (described in detail in KQ1 in this report) (Table 4). The authors used statistical techniques to account for factors that could influence decisions to stop or continue screening using observed data from the U.S. Medicare population (ages 70 to 84 years) among individuals who received a screening mammogram, had a predicted life expectancy of at least 10 years, and had no previous breast cancer diagnosis. Results were presented separately for people ages 70 to 74 years and people ages 75 to 84 years. Individuals represented in this study were primarily White (92%), with an additional 5 percent described as Black and 3 percent as “other” (with no additional details) (Table 5).

#### Outcomes

##### Overdiagnosis

Based on the natural history of breast cancer, the additional cancers observed with continued annual screening after age 70 are a combination of aggressive asymptomatic cancers that could be treated once detected plus cancers that would never have become clinically apparent before the end of life (overdiagnosis). Overall, the 8-year cumulative risk of a breast cancer diagnosis was higher for the continued annual screening strategy after age 70 (5.5%) (5.3% ages 70 to 74, 5.8% ages 75 to 84) compared with the stop screening strategy (3.9%) (same proportion for both age groups) (Table 10). Paired with the mortality outcomes presented in this study, showing no benefit of continued screening for those ages 75 to 84 and only a trend toward a small mortality reduction for those ages 70 to 74, the detection of breast cancer is predominantly attributable to overdiagnosis. Additionally, the difference in diagnoses between the strategies reflects the proportion exposed to treatment harms that did not benefit, especially among those ages 75 to 84 (5.8% minus 3.9% = 1.9%).

##### Overtreatment

As noted above, there were more people diagnosed with breast cancer in the continue screening strategy beyond age 70 years, compared with the stop screening strategy. The specific cancer treatments received by those with a diagnosis were presented by study group (standardized to age distribution, comorbidity score, chronic conditions, and long-term care institutionalization). Lumpectomy and radiotherapy were more common for cancers diagnosed among individuals in the continued annual screening strategy compared with those who stopped screening after age 70, whereas radical mastectomy and chemotherapy were more common for cancers diagnosed in those who discontinued screening after age 70 (Table 10). Overall, because fewer individuals were diagnosed for the stop screening strategy (ages 70 to 84), there was a lower risk of undergoing followup and treatment (1.4% lower 8-year cumulative risk of a diagnosis).

#### KQ3a Does Comparative Effectiveness Differ by Population Characteristics and Risk Markers (e.g., Age, Breast Density, Race and Ethnicity, Family History)?

No studies of ages to start or stop screening presented data that would allow for testing of effect differences or stratification of results by different population characteristics or risk markers.

### Screening Interval

#### Study and Population Characteristics

Three of the studies included to address potential harms of different screening intervals have been described elsewhere in this report (Table 4). The United Kingdom Co-ordinating Committee on Cancer Research (UKCCCR) is a RCT that was conducted within the U.K. National Breast Screening Programme (described above in KQ2).^126^ The trial randomized 76,022 women to screening with DM at 50 to 62 years of age to receive an invitation for annual screening each year for the next three years or to one screening visit three years later. A fair-quality NRSI study by Parvinen et al.^159^ was conducted in one city (Turku) as part of the Finnish national screening program, and used quasi-randomization to assign women ages 40 to 49 years to screening very year or every three years depending on whether their birth year was odd or even (see detailed description in KQ1 results). A fair-quality BCSC NRSI by Miglioretti et al.^154^ compared cancer outcomes for women with at least two screening visits prior to a cancer diagnosis and a followup period (detailed description above for KQ2). The aim was to test whether the incidence and characteristics of cancer differed by the interval between the two visits (annual defined as 11 to 14 months versus biennial defined as 23 to 26 months) among 15,440 cancers identified in the BCSC screening program.

Two additional studies were identified to address potential harms of screening intervals by examining the potential cumulative harms across multiple rounds of screening (Table 4). A fair-quality NRSI by Ho et al.^140^ was conducted using BCSC data to compute the cumulative probability of a false-positive result after 10 years of screening on an annual or biennial basis with either DM or DBT during the years 2005 through 2018. The included observations were based on the screening visits of 903,495 women (444,704 DBT examinations and 2,524,351 DM examinations). The mean (SD) number of examinations per woman was 3.3 (2.5). The second additional study was the Know Your Risk: Assessment at Screening (KYRAS) study^153^ that calculated the cumulative risk of false-positive screens over a median of 8.9 years. Eligible women were those screened at the Columbia University Medical Center (New York) during 2014 and 2015; for these women, the study collected information on previous mammograms going back to 1989 based on their health record (N = 2,019; median age, 59 years). Overall, women underwent a median of seven mammograms during the study period.

Demographic characteristics were not commonly reported in the studies of screening interval (Table 5). As described in KQ2, the Miglioretti et al. BCSC^154^ study population was primarily White (78%) with the remaining participants reported as Black (5%), Asian (5%), Hispanic (5%), AI/AN (<1%), and 7% reported as “other” or unknown. In the KYRAS study,^153^ the population was majority Hispanic (76%) with the remaining reported as White (10%), Black (10%), or other (4%) including Asian, Pacific Islander, Native American, or Alaska Native. Twenty-four percent of the non-Hispanic White women were of Ashkenazi Jewish descent.

#### Outcomes

##### Interval Cancers

Three studies presented data on interval cancers by participant screening interval (Table 11). The UKCCCR RCT^126^ reported interval invasive cancers for women invited to annual screening (N = 37,530) compared with triennial screening following an initial prevalence screening visit (N = 38,492) during a three-year followup period. In the triennial screening group, these were cancers detected prior to rescreening after three years. In the annual screening group, these were cancers detected in the three intervals between screening visits during the three years of followup. Overall, the rate of interval cancers was significantly lower in the annual invitation group (1.84 per 1,000 women initially screened) than in the triennial invitation group (2.70 per 1,000 women initially screened) (RR, 0.68 [95% CI, 0.50 to 0.92]).

The Parvinen et al.^159^ quasi-randomized study comparing annual with triennial screening from ages 40 to 49 in Finland reported mortality and the number of invasive interval cancers that occurred from 1987 to the end of 1994. Interval cancers were defined as those occurring after a negative mammogram and between two subsequent screening visits. Similar numbers of cases were reported in the annual screening and triennial screening groups and a statistical test for the difference was null (p=0.22).

The Miglioretti et al. BCSC NRSI^154^ presented analyses comparing interval cancers occurring one year after annual screening or two years after biennial screening. In the group with an annual screening interval preceding their cancer diagnosis, 22.2 percent (2,680/12,070 [95% CI, 21.5% to 23.0%]) of all cancers diagnosed were interval cancers, and this rate was lower than in the group with a biennial screening interval preceding their cancer diagnosis, where 27.2 percent (917/3,370 [95% CI, 25.7% to 28.8%]) were interval cancers. The study considered interval cancers to be those occurring within 12 months following an annual screening interval and within 24 months following a biennial screening interval. This was based on the assumption that the screening interval before a diagnosis was received would have continued. The study did not provide adjusted comparisons, limiting the ability to draw inferences about differences in the interval cancer rate associated with biennial and annual screening.

##### False-Positive Recall

The comparative NRSI from Ho et al.^140^ used BCSC data to estimate the cumulative probability of having at least one false-positive recall over 10 years of screening with DBT or DM on an annual or biennial basis (Figure 8, Appendix F Tables 3 and 4). Most individuals in the cohort were screened on an annual basis (73% DBT, 72% DM) versus biennial (15% DBT, 17% DM) or triennial (12% DBT, 11% DM). Examinations were defined as a false positive if no diagnosis of invasive cancer or DCIS occurred within one year of screening. For individuals screened with DBT, the estimated cumulative probability of at least one false-positive recall was 49.6 percent for those screened annually and 35.7 percent for those screened biennially (proportion difference, −13.9% [95% CI, −14.9% to −12.8%]). For individuals screened with DM, the estimated cumulative probability of at least one false-positive recall was 56 percent for those screened annually and 38 percent for those screened biennially (proportion difference, −18.2% [95% CI, −18.6% to −17.7%]). The difference in cumulative false-positive recalls between annual and biennial screening was larger for DM (−18.2 [95% CI, −18.6 to −17.7]) than for DBT screening (−13.9 [95% CI, −14.9 to −12.8]). The study also reported cumulative probabilities of false-positive short-interval followup recommendations (return for diagnostic imaging after six months). Approximately 17 percent of screened individuals undergoing annual screening expected to experience at least one short-interval followup recommendation compared with 10 percent of those undergoing biennial screening. The probability of short-interval followup was slightly lower with DBT than DM.

In the KYRAS study,^153^ individuals screened with DM annually had 2.18 times the odds of having a false-positive result compared with those who screened biennially (odds ratio, 2.18 [95% CI, 1.70 to 2.80]) after controlling for total years of followup, age, race and ethnicity, BMI, breast density, and breast cancer risk status (Appendix F Table 4).

##### False-Positive Biopsy

The comparative NRSI from Ho et al.^140^ used data from the BCSC to estimate the cumulative probability of having at least one false-positive biopsy over 10 years of screening with DBT or DM on an annual or biennial basis (Figure 9, Appendix F Tables 3 and 4). Most individuals in the cohort were screened on an annual basis. A false-positive biopsy was defined as a false positive if no diagnosis of invasive cancer or DCIS occurred within one year of screening. Biennial screening compared with annual screening led to a 5 percent lower cumulative false-positive biopsy rate whether the screening was conducted with DBT or DM. For individuals screened with DBT, the estimated cumulative probability of at least one false-positive biopsy recommendation was 11.2% for those screened annually and 6.6% for those screened biennially (proportion difference, −4.6% [95% CI, −5.2 % to −3.9%]). For individuals screened with DM, the estimated cumulative probability of at least one false-positive biopsy was 11.7% for those screened annually and 6.7% for those screened biennially (proportion difference, −5.0% [95% CI, −5.4% to −4.7%]) among those screened with DM.

#### KQ3a Does Comparative Effectiveness Differ by Population Characteristics and Risk Markers (e.g., Age, Breast Density, Race and Ethnicity, Family History)?

The Ho et al. NRSI^140^ reported 10-year cumulative false-positive and biopsy rates by age and breast density category using BCSC data. Annual screening was associated with higher cumulative false-positive recall and biopsy for most age and density groups, though this difference in recall by screening interval was not seen among those with the lowest density (almost entirely fatty tissue) (Figures 8 and 9). The cumulative risk of experiencing a false-positive recall was positively associated with both younger age and higher breast density categories, except among those with the lowest breast density category, where age differences were less pronounced (Figure 8). A similar pattern was seen for the cumulative risk of false-positive biopsy (Figure 9). There was not a strong association between and age and cumulative false-positive biopsy regardless of the screening interval among those with the lowest breast density (Figure 8 and 9, Appendix F Tables 5 and 6).

### Digital Breast Tomosynthesis

#### Study and Population Characteristics

We identified 10 eligible studies, four RCTs (three good-quality, one fair-quality),^129,139,143,160^ and seven fair-quality NRSIs^79,132,140,144,147,162,168^ that reported on potential harms of screening associated with the use of DBT (plus DM or sDM) compared to DM only screening (Tables 4 and 5).

Four large trials were conducted with individuals participating in organized screening programs in Germany,^139^ Italy,^129,160^ and Norway.^143^ Three of these trials were previously discussed in KQ2. The population characteristics were not well reported for the trials of DBT compared with DM. No trial reported race or ethnicity characteristics of the population.

The fair-quality Proteus Donna (N = 73,866)^129^ and good-quality RETomo (N = 26,877)^30^ RCTs were both conducted in Italy (detailed description above for KQ2) and reported screening results from two rounds of screening with randomization to DBT/DM or DM for the first round of screening and DM screening for all participants at the second round of screening (annual screening for ages 45 to 49, biennial screening for ages 50 to 69). The To-Be study^143^ is a good-quality RCT conducted in Norway (described in detail for KQ2) that randomized participants to DBT/sDM screening (n = 14,380) or DM screening (n = 14,369) and followed them for two years, or until the next screening episode. The second screening round occurred two years later and consisted of DBT for all participants. Therefore, the study compares the findings from two rounds of screening with DBT (n = 11,201) compared with one round of DM screening followed by one round of DBT screening (n = 11,105).

One additional RCT was identified that addresses the potential harms of screening with DBT compared with DM. The TOmosynthesis plus SYnthesised MAmmography Study (TOSYMA)^139^ is a good-quality RCT conducted in Germany that assigned 99,634 women ages 50 to 69 to DBT/sDM (DBT with synthetic two-view imaging) versus DM alone between July 5, 2018, and December 30, 2020. Available results from the trial report on performance at a single round of screening and for this review was included only for rare or uncommonly reported harms (adverse events, radiation exposure). Future planned publications from the trial will report on interval cancers and cancer incidence at a second round of screening (see Discussion).

The seven NRSIs included for KQ3 were conducted using data from populations screened with DBT and DM in the United States,^132,140,147,162,168^ Sweden,^79^ and Norway.^144^ Additional details of the analysis for each of the NRSIs are included in Appendix E Table 1.

The fair-quality PROSPR NRSI^132^ used data from three U.S. academic research centers and connected health care delivery systems that are members of the NCI-funded PROSPR consortium to compare the performance of DM screening with DBT and DM screening combined. The study data included the findings from all bilateral screening mammography examinations provided at the study sites from approximately 2011 to 2014 (varied by study site) among women ages 40 to 74 years. Those with a history of breast cancer or imaging conducted in the three months prior to screening were excluded. The database included 103,401 individuals (55,998 DBT examinations; 142,883 DM examinations) and more than a quarter of women (28.3%) contributed three or more examinations to the analysis.

A fair-quality study using BCSC registry data was conducted by Sprague et al.^168^ to compare DBT with DM-only screening across multiple (non-baseline) rounds over the years 2011 to 2020 from 58 health care facilities (five BCSC registry members). The study reported intermediate screening outcomes related to the detection of invasive cancer, including advanced cancer (stage ≥IIB+), and potential harms from false-positive recall and biopsy. The analysis included 504,863 women contributing 1,531,608 mammography examinations.

A second fair-quality NRSI using BCSC data conducted by Ho et al.^140^ (described above in studies of screening interval) provided estimates of the cumulative probability of a false-positive result after 10 years of screening with DBT or DM during the years 2005 through 2018. The included observations were based on the screening visits of 903,495 women (444,704 DBT examinations; 2,524,351 DM examinations). The mean (SD) number of examinations per woman was 3.3 (2.5). These round-specific probabilities were used to generate the cumulative probability of having at least one false positive across 10 years of screening using discrete-time survival modeling to account for censoring. Over the study period, the proportion of examinations conducted with DBT increased but the age and breast density distributions of those screened with DBT and DM were similar, as were the proportion screened annually (nearly three-quarters) versus biennially.

A third study utilizing BCSC data was the fair-quality NRSI by Kerlikowske et al.^147^ conducted using data from screening visits at 44 BCSC facilities to compare outcomes of screening with DBT or DM during the years 2011 through 2018. Additional followup for cancer diagnoses obtained from state and regional cancer registries continued through 2019. The cohort included 504,427 women ages 40 to 79 years that had at least one DBT or DM screening visit (based on radiologist indication in medical record). Individuals with a history of breast cancer or mastectomy were excluded. The unit of analysis for the study was the screening examination and the analysis included 1,377,902 screening examinations.

The fair-quality Malmö Breast Tomosynthesis Screening Trial (MBTST)^79^ is an NRSI using prospectively collected cohort data in Sweden comparing women screened with DBT/DM through their participation in a screening performance cohort study (n = 13,369) with a concurrently screening period (2010 to 2015) for an age-matched control cohort screened with DM (n = 26,738). The age-matched controls were selected from the screening program registry records for women who did not participate in the DBT/DM study but were screened in the same setting, which relied on the same radiologists as the DBT/DM study.

A fair-quality NRSI by Richman et al.^162^ conducted in the United States used national medical claims registry data from the Blue Cross Blue Shield Axis data resource, which contains deidentified commercial insurance claims. The study comparing DBT/DM screening with DM screening among women ages 40 to 64 years included individuals receiving at least one screening mammogram between January 1, 2016, and December 31, 2017, who had been continuously enrolled for at least two years preceding the screen and for at least one year following the screen. Individuals with any breast cancer diagnosis in the two years preceding the screen and any insurance claims indicative of a genetic cancer syndrome or prophylactic mastectomy were excluded. The analytic sample included 7,602,869 screening mammograms conducted among 4,580,698 women.

The fair-quality OVVV study^144^ is an NRSI using a geographical comparison cohort design that was conducted within the BreastScreen national screening program in Norway (detailed description for KQ2 above). The cohort study reported cancer screening outcomes from one round of screening with DBT/sDM (n = 34,641) or DM (n = 57,763), followed two years later with DM for those attending a second round of screening (n = 72,017).

#### Outcomes

##### Interval Cancers

Three trials reported interval cancers following screening with DBT or DM (Table 12).^129,143,160^ The three RCTs did not show statistically significant differences in the risk of interval cancer following screening with DBT or DM (pooled RR, 0.87 [95% CI, 0.64 to 1.17]; I^2^=0%; 3 trials; n = 130,196) (Figure 10). Both Proteus Donna and RETomo used 12-month followup for those ages 45 to 49 years and 24-month followup for those ages 50 to 69 years. The relative risks for invasive interval cancers in these trials were 0.92 (95% CI, 0.60 to 1.42) and 0.96 (95% CI, 0.5 to 1.8), respectively. The To-Be RCT reported interval cancers from up to 24 months of followup for all participants (only individuals ages 50 to 69) and reported a relative risk of 0.71 (95% CI, 0.40 to 1.27).

Six observational studies used data from medical systems, registries, and cancer screening and surveillance programs to compare interval cancers occurring after screening with DBT or DM obtained through recommended mammography screening visits or screening programs (Table 12). These studies differed in the timeline of followup and method of identifying interval cancers (Appendix E Table 1), highlighting the variability in interval cancer definitions and data used to assess the outcome across the included NRSIs, and the need for more standardization of definitions and study protocols.

Four of the NRSIs found no significant difference in the rate of interval cancers diagnosed following screening with DBT or DM (including data from the BCSC,^147,168^ PROSPR consortium,^132^ and the OVVV comparative cohort study^144^). The Richman et al.^162^ NRSI analysis of commercial insurance claims included an exploratory analysis of rates of cancers occurring between five and 12 months following the index screening with DBT or DM. These cancers were presumed to be identified clinically before the next scheduled mammogram. The study did not report invasive cancers separately from DCIS. Results from an adjusted multilevel model suggested small but statistically significantly higher incidence of interval cancer in the DBT/DM arm (0.52 per 1,000 [99% CI, 0.47 to 0.56]) compared with the DM arm (0.45 per 1,000 [99% CI, 0.43 to 0.48]) with an adjusted difference of 0.07 interval cancers per 1,000 screens (99% CI, 0.01 to 0.12). The NRSI comparing the MBTST single-arm trial with an age-matched population-based cohort^79^ examined rates of interval cancers 18 to 24 months after screening (depending on age). The rate of invasive interval cancers for DBT/DM was 1.4 per 1,000 women screened and for DM was 2.7 per 1,000 women screened (unadjusted RR, 0.53 [95% CI, 0.32 to 0.87]). The study did not report or adjust for characteristics of the MBTST NRSI participants and the comparison cohort. Both groups were drawn from a population-based screening program, but participants and outcome ascertainment in the MBTST NRSI could have differed from those not participating in a study.

##### Recall

The same three RCTs^129,143,160^ and two NRSIs^144,168^ included for KQ2 reporting data across multiple rounds of screening were also included to assess screening recall rates (Table 13). Recall was defined similarly across the studies, with any positive or suspicious results after double-reading and arbitration leading to recall for additional followup, which could include or lead to additional imaging, percutaneous biopsy, open biopsy, or surgery. Results regarding recall rates were mixed across the first round of screening. In the RETomo RCT,^160^ recall was similar in both study arms (RR, 0.99 [95% CI, 0.88 to 1.10]). The Proteus Donna RCT^129^ reported a higher recall rate in the DBT/sDM study group (63.4 per 1,000) compared with the DM group (50.9 per 1,000) at round one (RR, 1.24 [95% CI, 1.17 to 1.32]). In the To-Be trial,^143^ a lower proportion were recalled at round one in the DBT/sDM group (30.9 per 1,000) compared with the DM group (39.7 per 1,000) (RR, 0.78 [95% CI, 0.69 to 0.88]). Inconsistency in the recall rates across trials at round one resulted in high statistical heterogeneity, so a pooled effect is not presented. The studies varied in their approaches to screening at round two: two RCTs used DM screening for both study groups (Proteus Donna, RETomo) and one used DBT for both study groups (To-Be) at round two. Recall rates at round two were more consistent and did not suggest a difference in recall between study groups when combined using meta-analysis (pooled RR, 0.97 [95% CI, 0.91 to 1.03]; I^2^=0%; 3 trials; n = 105,244) (Figure 11).

Among those recalled, further evaluation was conducted and those without a DCIS or cancer diagnosis were reported as false positives (Table 14). Results were inconsistent across the four studies included for this outcome. In the Proteus Donna RCT, the risk of a false-positive result was higher in the DBT/sDM group (55.1 per 1,000 screened) compared with the DM group (45.2 per 1,000 screened) at the first screening round (RR, 1.22 [95% CI, 1.14 to 1.30]). In the To-Be RCT, the first round of screening with DBT/sDM resulted in fewer false-positive recalls compared with DM (24.3 versus 33.7 per 1,000; RR, 0.72 [95% CI, 0.63 to 0.83]). There was not a statistically significant difference in the false-positive recall rates in the RETomo RCT^160^ (RR, 0.90 [95% CI, 0.79 to 1.00]). Again, in round one inconsistency in effects for the two Italian trials compared with the To-Be trial resulted in high statistical heterogeneity; thus, a pooled effect is not presented for the effect of DBT on false-positive recall. In all three trials, the relative risks of false-positive recall were near 1.0 at round two and the effects were sufficiently homogeneous to combine (pooled RR, 0.99 [95% CI, 0.92 to 1.05]; I^2^=0%; 3 trials; n = 105,244) (Figure 12).

The fair-quality BSCS NRSI by Sprague et al.^168^ reported lower recall and lower false-positive recall at round one and round two screening with DBT compared with DM (Tables 13 and 14). The difference in false-positive recall at round one was 34 fewer per 1,000 examinations with DBT versus DM (95% CI, 27 to 47 fewer) and at round two was 18 per 1,000 fewer with DBT (95% CI, 7 to 30 fewer). False-positive recall was not statistically lower with DBT versus DM among those included for round three comparisons (11 fewer per 1,000 [95% CI, 23 fewer to 2 additional]).

The fair-quality NRSI OVVV study did not report a statistically significant difference in recall rates between the DBT and DM arms at round one (RR, 1.02 [95% CI, 0.95 to 1.09]) and reported slightly lower false-positive recall rates for those screened with DBT at the first screening round (RR, 0.91 [95% CI, 0.84 to 0.98]). At round two, both groups received DM and the recall and false-positive rates were higher (~25%) in the DM compared with the DBT group (31 versus 24 per 1,000) (Tables 13 and 14).

##### Biopsy

Two of the included RCTs reported on the rate of biopsy following screening (Table 13). The RETomo study specified these biopsies were percutaneous needle biopsies, while the type of biopsy was not defined in the ToBe study. The RETomo RCT^160^ reported more people had a biopsy in the group randomized to DBT/DM (11.9 per 1,000) compared to those randomized to DM (8.1 per 1,000); the relative risk was 1.50 (95% CI, 1.10 to 1.90). At the second round of screening, when all participants underwent screening with DM, there were fewer percutaneous biopsy referrals in the study arm originally screened with DBT/DM (6.1 per 1,000) compared with the DM study arm (8.1 per 1,000), although the relative risk was on the margin of statistical significance (RR, 0.76 [95% CI, 0.57 to 1.00]). Thus, cumulatively over the two rounds of screening a similar proportion of study participants were referred for percutaneous biopsy regardless of the screening modality used at the first screening round. Since both arms received DM screening at round two, it is unclear whether an additional round of screening with DBT/DM would have resulted in higher biopsy rates for the intervention arm.

In the ToBe study, there was no evidence that rates of biopsy reported differed between the DBT/sDM arm (17.5 per 1,000) and the DM arm (18.9 per 1,000), with a relative risk of 0.93 (95% CI, 0.78 to 1.10). Similarly, no difference in the rates of biopsy were reported at round two, when all participants were screened with DBT/sDM (RR, 0.95 [95% CI, 0.80 to 1.13]). Only the To-Be RCT reported the necessary data to compute false-positive biopsy rates (Table 14). There was not a statistically significant difference between study arms in this outcome at either round of screening. At the first round, false-positive biopsies occurred for 10.9 per 1,000 screened in the intervention group and 12.8 per 1,000 in the DM control group (RR, 0.85 [95% CI, 0.69 to 1.05]). The false-positive biopsy rate was approximately 14 per 1,000 in both study groups at the second screening round (RR, 0.99 [95% CI, 0.80 to 1.24]).

The RETomo RCT^160^ also reported referrals to surgical followup on screening results, including open biopsy (Table 13). Similar to the percutaneous biopsy findings, surgical followup was higher in the DBT/DM group at round one (8.7 versus 5.0 per 1,000; RR, 1.70 [95% CI, 1.3 to 2.30]) but was not statistically different at round two, when both arms received screening with DM (5.3 versus 6.4 per 1,000; RR, 0.83 [95% CI, 0.60 to 1.10]). In the Proteus Donna RCT, there were more surgery referrals in the DBT/sDM group at round one (9.9 versus 6.4 per 1,000; RR, 1.54 [95% CI, 1.31 to 1.82]) and fewer at round two in the intervention group (4.3 versus 5.7 per 1,000; RR, 0.76 [95% CI, 0.59 to 0.97]) after all participants were screened with DM.

One fair-quality BCSC NRSI by Sprague et al.^168^ reported slightly lower biopsy and false-positive biopsy at round one with DBT compared with DM (Tables 13 and 14). The difference in false-positive biopsy at round one was 3 fewer per 1,000 screening examinations with DBT (95% CI, 2 to 5 fewer). False-positive biopsy rates were similar for DBT and DM for those included for two or more screening rounds.

##### Cumulative False-Positive Recall

The comparative BCSC NRSI from Ho et al. reported the estimated cumulative probability of having at least one false-positive recall over 10 years of screening with DBT or DM on an annual or biennial basis (Figure 13, Appendix F Tables 3 and 4). Probabilities were lower with DBT screening compared with DM screening, regardless of the screening interval, but the difference was greater with annual screening. With annual screening, the 10-year cumulative probability of a false-positive recall was 49.6% with DBT and 56.3% with DM (difference, −6.7% [95% CI, −7.4 to −6.1]). With biennial screening, the 10-year cumulative probability was 35.7% for DBT and 38.1% for DM (difference, −2.4% [95% CI, −3.4 to −1.5]). The study also reported cumulative probabilities of receiving a false-positive short-interval followup recommendation, which was 16.6% for DBT and 17.8% for DM annual screening (difference, −1.1 [95% CI, −1.7 to −0.6]) and ~10% for both modalities with biennial screening (difference, −0.1 [95% CI, −0.7 to 0.5]).

##### Cumulative False-Positive Biopsy

The comparative BCSC NRSI from Ho et al. reported the estimated cumulative probability of having at least one false-positive biopsy over 10 years of screening with DBT or DM on an annual or biennial basis (Figure 14, Appendix F Tables 3 and 4). Differences were small, and not statistically significant when comparing biennial DBT and DM. With annual screening, the 10-year cumulative probability of a false-positive biopsy was 11.2% with DBT and 11.7% with DM (difference, −0.5 [95% CI, −1.0 to −0.1]). With biennial screening, the 10-year cumulative probability was 6.6% for DBT and 6.7% for DM (difference, −0.1% [95% CI, −0.5 to 0.4]).

##### Overdetection and Overtreatment

In the three RCTS (To-Be, RETomo,^160^ and Proteus Donna), rates of DCIS detected at each screening round and between study arms were similar, ranging from 0.7 to 1.3 per 1,000 screened at the first screening round and from 0.6 to 1.3 per 1,000 screened at the second screening round, with no statistical differences between the DBT and DM screened groups (Table 15). Meta-analysis was used to generate combined estimates that also did not show statistically significant differences at round one (pooled RR, 1.33 [95% CI, 0.92 to 1.93]; I^2^=0%; 3 RCTs; n = 130,196) or round two (pooled RR, 0.75 [95% CI, 0.49 to 1.14]; I^2^=0%; 3 RCTs; n = 130,196,) (Figure 14). The OVVV NRSI reported higher DCIS detection at the first screening round in the DBT group compared with the DM group (1.8 versus 0.8 per 1,000 screened; RR, 2.16 [95% CI, 1.49 to 3.12]).

##### Adverse Events

The TOSYMA RCT reported on adverse events from a single round of screening using DBT/sDM compared with DM only. The study randomized 49,804 individuals to DBT/sDM and 49,830 to DM. Six adverse events were reported in each study arm and none were serious (e.g., fainting, circulatory collapse/problem, allergic skin reaction). Device deficiencies occurred in 0.05 percent (23/49,179) of examinations in the DBT/sDM group and 0.01 percent (5/50,455) of DM examinations. None were determined to cause any serious adverse events.

##### Radiation Exposure

Five studies (four RCTs, one NRSI) reported the median, mean, or relative radiation dose by study arms from a single screening round (Table 16). In three of these studies, participants underwent a DBT and DM screening (in one or two compressions) and in two studies, participants underwent DBT with a synthetic reconstruction of a 2D DM image.

Studies using DBT/DM screening reported radiation exposure approximately two times higher in the intervention group compared with the DM-only control group. The RETomo RCT^160^ reported higher median dosages, with the DBT/DM group having 6.40 mGy (interquartile range, 5.68 to 7.36) and the DM group having 4.84 mGy (interquartile range, 4.24 to 5.72), with the dose in the DBT/DM arm reported to be 2.3 times higher than in the DM study arm. The Proteus Donna RCT reported that the DBT/DM study group received radiation doses approximately 2.5 times higher than the DM-only study group but did not report details. The MBTST NRSI reported mean radiation doses with DBT (mean 2.3, mGy [SD, 0.7]) and DM (2.7 mGy [SD, 0.8]) screening in the study population that comprised the intervention group for the larger analysis presented in this NRSI. Assuming the radiation dose with DM in the comparison population was similar, the DBT/DM group was exposed to nearly two times more radiation than the DM only group.

Differences between study groups in radiation exposure were smaller in studies using DBT/sDM. The TOSYMA RCT reported that median glandular radiation dose in the DBT/sDM group was 1.86 mGy (interquartile range, 1.48 to 2.45) and in the DM group was 1.36 mGy (interquartile range, 1.02 to 1.85). In the To-Be RCT, which also used DBT/sDM, the mean radiation dose was 2.96 mGy compared with 2.95 mGy in the DM group.

#### KQ3a Does Comparative Effectiveness Differ by Population Characteristics and Risk Markers (e.g., Age, Breast Density, Race and Ethnicity, Family History)?

None of the included studies were designed to enroll populations to support comparisons in the screening outcomes of DBT and DM by race or ethnicity or family history.

Two RCTs and four NRSIs that compared DBT-based screening strategies with DM-only screening strategies presented results stratified by age and/or breast density.

##### Age

The RETomo RCT^160^ reported the effects of DBT/sDM versus DM on recall, biopsy, and surgical procedures stratified by age category (45 to 49 versus 50 to 69) (Table 17). Recall rates at the first round of screening were similar for both age groups regardless of study intervention (~40 per 1,000 screened). At the second screening (DM for both groups), those ages 45 to 49 in the DBT group had lower recall (34 versus 40 per 1,000 screened; RR, 0.84 [95% CI, 0.69 to 1.00]) and lower rates of percutaneous biopsy (3 versus 6 per 1,000 screened; RR, 0.50 [95% CI, 0.27 to 0.94]).

Conversely, those ages 50 to 69 screened with DBT experienced no difference in recall at either round, but more percutaneous biopsy (14 versus 9 per 1,000 screened; RR, 1.40 [95% CI, 1.10 to 1.90]) at the first screening round and no difference at round two. False-positive recall was not statistically different for either age group at either screening round, although a trend toward lower false-positive recall at the first round was seen for those ages 50 to 69 screened with DBT (Table 18). After the first screening round, both age groups were more likely to have surgical procedures, including open biopsy, in the DBT-screened intervention group. At the second round, participants ages 45 to 49 were less likely to have surgical procedures, but the effect was on the margin of statistical significance (RR, 0.50 [95% CI, 0.24 to 1.00]). There was no difference in surgical procedures for those ages 50 to 69 at round two.

RETomo^160^ also presented stratified analyses comparing interval cancer incidence by age groups; the event rates were low and all confidence intervals contained null (Table 19). The study did not report interaction tests and was not designed to test for subgroup differences, making it difficult to draw conclusions about differences by age. Overall, these stratified results suggest some risk of increased biopsy or surgery with DBT screening at the first round for all, followed by lower rates at the next round for those ages 45 to 49. Analytic and study design limitations preclude firm subgroup conclusions.

The Richman et al. NRSI using administrative data from a large U.S. private insurer compared invasive interval cancers occurring five to 12 months after negative DBT or DM screening among individuals ages 40 to 64 years and conducted a test for interaction across 5-year age group categories (Table 19). Although there was a main effect of DBT screening (increased odds of invasive interval cancer—reported above), the age group by intervention interaction term was not statistically significant (p=0.54; α=0.01).

The MBTST NRSI reported interval cancers stratified by two age groups: 40 to 54 versus 55 to 74 years (Table 19). The adjusted odds ratio of being diagnosed with an interval cancer among women younger than 55 years of age was 0.5 (95% CI, 0.2 to 1.1) and 0.6 (95% CI, 0.3 to 1.1) among women 55 years and older, similar to the overall effect for both groups combined, which was statistically significant. The study did not report interaction tests and was not designed to test these subgroup comparisons, making it difficult to draw conclusions about differences by age group.

##### Breast Density

The RETomo RCT^160^ presented stratified analyses comparing interval cancer incidence by density groups; event rates were low, and all confidence intervals contained null (Table 19). The study did not report interaction tests and was not designed to test for subgroup differences, making it difficult to draw conclusions about differences by age.

The To-Be trial reported recall and biopsy stratified by Volpara density grade categories (VDG1–VDG4). There was lower recall at the first screening round for those screened with DBT who had lower density breasts (VDG1 and VDG2) but not for those with higher density breasts (VDG3 and VDG4), and no statistical difference in recall at the second screening (Table 17). No statistical difference in biopsy at round one or two was reported for any of the breast density categories. The risk of a false-positive recall in the DBT/sDM group was, however, lower at round one for those with less dense breasts (VDG1 RR, 0.58 [95% CI, 0.43 to 0.80]; VDG2 RR, 0.66 [95% CI, 0.54 to 0.81]) and this trend was also seen for false-positive biopsy (VDG1 RR, 0.57 [95% CI, 0.33 to 1.00]; VDG2 RR, 0.64 [95% CI, 0.46 to 0.89]). Those in density category VDG3 had a higher risk of false-positive biopsy (RR, 1.79 [95% CI, 1.23 to 2.61]). At the second round of screening, there was no evidence of a difference in false-positive recall for any of the density categories, but in the highest density category, false-positive biopsy risk neared statistical significance (RR, 2.08 [95% CI, 0.98 to 4.41]) (Table 18) and was not statistically different for those in the VDG3 or VDG4 breast density categories. In density-stratified comparisons of invasive interval cancer, event rates were small, and the confidence intervals contained null (Table 19). The study did not report interaction tests and was not designed to test these subgroup comparisons, making it difficult to draw conclusions about differences by breast density.

The Kerlikowske et al. BCSC NRSI presented comparisons of interval cancer incidence following DBT and DM screening examinations stratified by breast density category and additionally stratified within density categories by BCSC risk score (<1.67% versus ≥1.67). No statistically significant differences in the incidence of interval cancer were reported for the breast density–stratified comparisons (Table 19) or the density and risk stratified comparisons.

The To-Be RCT reported mean radiation doses for the study groups, stratified by breast density, in a figure. The study reported that there were not statistically significant differences in radiation dose for DBT/sDM compared with DM for any of the density categories.

##### Age and Breast Density Subgroups

The Ho et al. BCSC NRSI presented 10-year cumulative false-positive recall and biopsy probabilities stratified by breast density and age and comparing DBT to DM screening. Overall, the study reported lower false-positive recall with DBT screening. In stratified analyses, however, there was not a statistical difference in cumulative false-positive recall among those with extremely dense breasts in any age group. Among individuals ages 50 to 59 with extremely dense breasts screened on a biennial basis, the risk of false-positive recall was higher with DBT compared with DM screening. Cumulative false-positive biopsy was also no different with DBT versus DM screening among individuals with extremely dense breasts.

### Magnetic Resonance Imaging

#### Study and Population Characteristics

The Dense Tissue and Early Breast Neoplasm Screening (DENSE) trial is a good-quality RCT conducted in The Netherlands that enrolled participants from December 2011 to November 2015 (N = 40,373) (Table 4). The aim of the study was to determine whether an invitation to supplemental MRI screening after a negative mammogram for those with extremely dense breast tissue would reduce the incidence of interval cancer.

Women ages 50 to 75 years old participating in the national digital mammography program who were assessed to have extremely dense breasts and had a negative screening result (BI-RADS 1 or 2) were randomized (1:4) to an invitation to supplemental MRI screening (n = 8,061) or usual care screening invitation (mammography in two years) (n = 32,312). The baseline characteristics of the study groups were balanced on the reported characteristics (Table 5). Among those invited to MRI screening, 59 percent underwent the MRI examination (n = 4,783). The characteristics of MRI completers and noncompleters were reported to be similar based on the limited set of variables, but the groups could differ in their motivation to be screened, access to health care, and risk factors for invasive breast cancer, such as family history and other characteristics. Therefore, study outcomes reported only for MRI screened participants (detection, recall, false-positives) are subject to higher risk of bias than outcomes based on all randomized study participants (interval cancer). Single-read MRI examinations were conducted by breast radiologists with findings of BI-RADS 3 referred for followup MRI imaging in six months and BI-RADS 4 or 5 recalled for diagnostic evaluation. Cancer diagnoses and tumor characteristics were obtained from The Netherlands Cancer Registry. While this study included two rounds of screening with MRI, findings from the second round of screening in the mammography-only arm have not been published. Therefore, this study was not eligible for inclusion in KQ2, but it is included for interval cancers and potential harms of supplemental MRI imaging.

A fair-quality NRSI compared commercially insured women ages 40 to 64 years in the MarketScan database who had received at least one bilateral screening breast MRI (n = 9,208) or mammogram (n = 9,208) between January 2017 and June 2018 (Tables 4 and 5). Propensity score matching was used to compare cascade events (mammary and extramammary) in the six months following the MRI or mammogram that were potentially attributable to having a breast MRI (see Appendix E for Detailed Methods).

##### Interval Cancers

In the DENSE RCT, the intention-to-treat analysis based on invitation to MRI screening found a rate of invasive interval cancers for the DM+MRI of 2.2 per 1,000 invited to screening compared with 4.7 per 1,000 screened for the DM-only control group (RR, 0.47 [95% CI, 0.29 to 0.77]) (Table 12).

##### Adverse Events

In the DENSE RCT, eight adverse events (including five classified as serious adverse events) occurred during or immediately after the MRI screening. Adverse events included two vasovagal reactions and three allergic reactions to the contrast agent (serious adverse events) as well as two reports of extravasation (leaking) of the contrast agents and one shoulder subluxation. Twenty-seven individuals (0.6% of MRI arm) reported a serious adverse event within 30 days of the MRI; however, the authors did not determine whether any of these were attributable to the MRI. Two of these serious adverse events were unspecified complications during or after a biopsy that took place after the initial MRI screening examination.

##### Downstream Consequences of Supplemental Imaging, Including Incidental Findings

Because women were selected for the DENSE trial based on a negative mammography, all of the additional imaging (including additional exposure to radiation and contrast agents) and biopsy procedures would not have occurred in the absence of MRI screening. Among those who underwent MRI in the first round of the DENSE trial, the rate of recall for additional imaging following MRI was 94.9 per 1,000 screened and the false-positive rate was 79.8 per 1,000 screened (Table 20). The rate of biopsy for those undergoing supplemental MRI was 62.7 per 1,000 screened. Among the cancers diagnosed by MRI, over 90 percent were classified as DCIS (stage 0) or stage 1 cancer. Without information for two rounds of screening from both arms of the study there is not sufficient information to weigh the relative benefit versus harms of these diagnoses and downstream imaging consequences. The DENSE trial did not report on incidental findings from MRI imaging.

In the U.S. insurance claims NRSI, individuals who had an MRI compared to those receiving only a mammogram were more likely in the subsequent six months to have additional cascade events, most related to breast conditions. Since individuals could contribute multiple events, rates were per 100 screened and could exceed that number. Events unrelated to breast diagnostic codes were higher in the MRI group (304.5 per 100) than in the mammography group (284.8 per 100), and the adjusted difference between groups (19.6 per 100 [95% CI, 8.6 to 30.7]) was mostly comprised of additional health care visits. There were no statistically significant differences in laboratory tests, imaging tests, procedures, hospitalizations, or new diagnoses (unrelated to breast conditions) (Table 20).

#### KQ3a Does Comparative Effectiveness Differ by Population Characteristics and Risk Markers (e.g., Age, Breast Density, Race and Ethnicity, Family History)?

No studies of supplemental MRI screening presented data that would allow for testing of effect differences or stratification of results by different population characteristics or risk markers.

### Ultrasound

#### Study and Population Characteristics

The Japan Strategic Anti-cancer Randomized Trial (J-START) is a fair-quality RCT that randomly assigned asymptomatic women ages 40 to 49 years in 23 prefectures in Japan to breast cancer screening with mammography plus handheld ultrasound (DM/US) (n = 36,859) or mammography only (DM) (n = 36,139) over two rounds of annual screening from 2007 to 2011 (Table 4). Those with a personal history of breast cancer or in situ lesions, any other cancers in the previous five years, or a life expectancy of five or fewer years were not eligible for the study. The two study groups were balanced across a range of characteristics, and for nearly one-quarter (23.2%) the first round of screening was their first breast cancer screen (Table 5). The authors note that 58 percent of women were classified as having dense breasts; however, the distribution of breast density across study arms was not reported. The findings of the DM, clinical examination (when performed), and ultrasound examinations were considered independently. An intention-to-treat analysis was published in 2016, reporting on the first screening round, but there have been no further publications from the main trial.^291^ The absence of second-round screening results limits conclusions that can be drawn with regard to the effectiveness of supplemental ultrasound screening. Therefore, this study was not eligible for inclusion in KQ2, but it is discussed here for interval cancers and potential harms related to supplemental ultrasound imaging.

An NRSI by Lee et al. reported results of an analysis using data from two BCSC registries to compare screening outcomes for individuals receiving ultrasonography on the same day as a screening mammogram (DM/US) (n = 3,386, contributing 6,081 screens) compared with those who received only a mammogram (DM) (n = 15,176, contributing 30,062 screens) (Tables 4 and 5, see Appendix E for Detailed Methods). Screening examinations occurred between 2000 and 2013 and followup was for 12 months after the screening examination visit, or until the next examination. The majority of individuals were White (accounting for 80% of the screening examinations), with 11 percent reported as Asian/Pacific Islander, 7 percent as Hispanic, less than 1 percent as Black, and 2 percent as “mixed/other.” Sixty-five percent of examinations were performed in individuals classified as having heterogeneously or extremely dense breasts. This study enrolled a higher-risk population, in which 31 percent of examinations were among those with a known first-degree family history of breast cancer and 35 percent of women were classified with at least an intermediate 5-year risk of breast cancer. Forty percent of examinations were among those with a previous breast biopsy. Propensity score matching was used to adjust for confounding on using variables available in survey, EMR, and registry data.

#### Outcomes

##### Interval Cancers

In the J-START RCT, there were 16 interval cancers reported (0.4 per 1,000) in the DM/US group and 27 (0.8 per 1,000) in the DM group after the round one examination (Table 12). The relative risk was not statistically different (RR, 0.58 [95% CI, 0.31 to 1.08]) when calculated based on the study reported event rates. The study reported effect of the intervention was estimated with a GEE, aimed at accounting for the mix of cluster and individual randomization. The analysis produced a population-averaged effect that was on the margin of statistical significance for a difference in the risk for invasive interval cancer by study arm (proportion difference, −0.05 [95% CI, −0.09 to 0]). We calculated the individual-level relative risk to support comparability across the studies in this review. Not accounting for clustering in analysis usually results in narrower confidence intervals, so the naïve estimate we calculated is more likely to be biased toward a statistically significant effect (type II error).

The Lee et al. NRSI using BCSC found no statistical difference in the interval cancer rate, with 9 interval cancers (invasive and DCIS) following examinations with DM/US (1.5 per 1,000 screens) and 56 interval cancers following examinations with DM only (1.9 per 1,000 screens) in the propensity-matched comparison groups (aRR, 0.67 [95% CI, 0.33 to 1.37]) (Table 12).

##### Downstream Consequences of Supplemental Imaging

The findings of each modality were considered separately in the J-START trial, allowing estimation of additional followup (including imaging and biopsy) attributable to supplemental ultrasound screening. The rate of recall based only on ultrasound was 49.7 per 1,000 in the ultrasound arm, and 48.0 per 1,000 had a false-positive recall (Table 20). Of those cancers identified only by ultrasound, 76.2 percent was classified as stage 0 or 1 cancer. Without information on cancers detected over two rounds of screening from both arms of the study, or health outcomes, there is not sufficient information to weigh the relative benefit versus harms of these diagnoses and downstream imaging consequences. The J-START trial did not report on any incidental findings from ultrasound imaging.

The NRSI by Lee did not report the findings of ultrasound and mammography separately; therefore, we are unable to account for how much followup is attributable to the use of ultrasound alone (Table 20). Referral to biopsy and false-positive biopsy recommendations were twice as high and short-interval followup three times as high for the group screened with ultrasound, despite there being no statistical difference in cancer detection. Despite the use of propensity scoring to adjust analyses, unmeasured differences in the groups screened with ultrasound and those not screened may confound the results and bias estimates.

#### KQ3a Does Comparative Effectiveness Differ by Population Characteristics and Risk Markers (e.g., Age, Breast Density, Race and Ethnicity, Family History)?

A secondary analysis of J-START reported results for trial participants from a single screening center in one Japanese prefecture (Miyagi) to compare interval cancer rates for DM/US and DM screening among women ages 40 to 49. The interval cancer rates (invasive and DCIS) were reported stratified by two breast density groups: nondense (BI-RADS A, B) and dense (BI-RADS C, D). Among those with nondense breasts, the rate of invasive interval cancers among the DM/US arm was 0.5 per 1,000 compared with 2.3 per 1,000 for those undergoing DM only (RR, 0.229 [95% CI, 0.05 to 1.03]). For those with dense breasts, the invasive interval cancer rate was 0.5 per 1,000 among those randomized to DM/US compared with 1.8 per 1,000 for DM only (RR, 0.29 [95% CI, 0.08 to 1.05]) (Table 19). The study used GEE to estimate population-averaged effects accounting for the mix of cluster and individual randomization per the statistical analysis protocol. As noted above, we present raw calculated relative risks for consistency across studies. By not accounting for the clustered data, the relative risks we calculated based on event rates would be more likely to underestimate correlations in the error terms, leading to narrower confidence intervals than analyses that use robust standard errors to account for clustering.

The rates of recall based only on ultrasound were 69.7 per 1,000 (95% CI, 63.3 to 76.6) among those with dense breasts and 39.4 per 1,000 (95% CI, 33.5 to 46.0) among those with nondense breasts. Of cancers identified only by ultrasound, 76.5 percent was classified as stage 0 or 1 cancer among those with dense breasts, and 86.7 percent was classified as stage 0 or 1 among those with nondense breasts. Without data for two rounds of screening from both arms of the study, there is not sufficient information to weigh the relative benefit versus harms of these diagnoses and downstream imaging consequences.

### Personalized Screening Programs Using Risk Assessment

No eligible studies were identified that reported on the potential harms of screening comparing usual care mammography with personalized screening programs using risk assessment.