# Appendix F Evidence Tables

Appendix F Table 1 Breast Cancer Staging System

Appendix F Table 2 Imaging Technologies Approved for Primary and Supplemental Breast Cancer Screening

Appendix F Table 3 Cumulative False-Positive Followup Over Multiple Rounds of Screening in One Nonrandomized Study Comparing Digital Breast Tomosynthesis and Digital Mammography

Appendix F Table 4 Cumulative False-Positive Followup Over Multiple Rounds of Screening in Nonrandomized Studies Comparing Breast Cancer Screening Frequencies

Appendix F Table 5 False-Positive Followup Over Multiple Rounds of Screening in One Nonrandomized Study Comparing Digital Breast Tomosynthesis and Digital Mammography, by Population Subgroup

Appendix F Table 6 Cumulative False-Positive Followup Over Multiple Rounds of Screening in Nonrandomized Studies Comparing Breast Cancer Screening Frequencies, by Population Subgroup

Appendix F Table 7 Summary of Evidence, by Population Subgroup