# Appendix E Additional Intervention Details on Included Trials and NRSIs

## Additional Details on Included NRSIs

### Population-based Research to Optimize the Screening Process (PROSPR)

The fair-quality PROSPR NRSI^132^ used data from three different academic U.S. research centers and connected health care delivery systems that are members of the NCI-funded PROSPR consortium to compare the performance of DM screening with DBT and DM screening combined. The three study sites were the University of Pennsylvania (integrated health care delivery system), University of Vermont (statewide cancer surveillance system), and Geisel School of Medicine at Dartmouth College (in association with Brigham and Women’s Hospital’s primary care network). The study data included the findings from all bilateral screening mammography examinations provided at the study sites from approximately 2011 to 2014 (varied by study site) among women ages 40 to 74 years where screening was the coded indication. Those with a history of breast cancer or imaging conducted in the three months prior to screening were excluded. The study data were further limited to include only those examinations provided by radiologists that had interpreted at least 50 DBT and 50 DM examinations. Data from the same individuals could contribute multiple observations (e.g., two screening visits plus followup from the same individual could be eligible for inclusion). Screening visits were coded as first ever mammograms if there were no prior imaging examinations available in PROSPR and no self-reported prior imaging.

The database included 103,401 individuals (55,998 DBT examinations; 142,883 DM examinations) and over a quarter of women (28.3%) contributed three or more examinations to the analysis. The study reported interval cancers occurring in the year following DBT/DM or DM screening for the subset of screening visits that had at least one year of followup observation (e.g., remained in the consortium database) (25,268 DBT/DM examinations; 113,061 DM examinations) (70% of examinations eligible for the study). Effects were estimated with logistic regression adjusted for research center, age (categorized 40-49, 50-59, 60-74), breast density (four BI-RADS density categories), and whether it was a first examination (prevalence screen). Additional analyses were conducted for some outcomes, including the use of generalized estimating equations (GEE) to account for effects of correlations within individuals contributing multiple screens, but the authors did not report these effects and stated that the results did not change based on the statistical model used.

### Breast Cancer Surveillance Consortium (BCSC)

#### Sprague et al. (2023)

A fair-quality NRSI by Sprague et al.^168^ used retrospective cohort data from 58 clinical sites from five BCSC registries (Carolina, Chicago, New Hampshire, San Francisco, Vermont) to compare DBT with DM-only screenings conducted within 30 months of a prior screening mammogram. All women ages 40 to 79 obtaining such DBT and DM screenings from the years 2011 to 2020 were included (n = 504,843). Thus, all included mammograms were subsequent screenings, and participants could contribute data from multiple consecutive screening rounds. The screening round was designated based on the number of prior examinations with the modality during the study period, with round one reflecting a screening examination occurring within 30 months of a prior examination (i.e., no prior examination in last 30 months excluded, so round one results are for a subsequent screen—no baseline prevalence screens included). Examinations were also excluded if supplemental screening with ultrasound (within three months) or MRI (within 12 months) was conducted. The screening modality was coded as DM only if there was no known prior history of DBT screening. Followup on screening outcomes was obtained using databases including SEER, BCSC, and state/regional tumor registries and examinations with less than one year of followup data for cancer diagnosis were excluded. Advanced statistical analyses were conducted to account for the clustered data structure (women within radiologists within facilities) and differences in breast cancer risk characteristics across modality and screening round. Adjustment for age, breast density, race or ethnicity, time since last mammogram, BCSC 5-year invasive cancer risk, benign breast disease history, first-degree family history of breast cancer, and examination year was conducted for all study estimates. The analytic sample included 1,531,608 examinations after exclusions for diagnostic evaluations and other factors. Screening using DBT was more common among non-Hispanic White women with a family history of breast cancer and individuals with an annual screening frequency. Overall, women receiving DBT examinations were at higher 5-year invasive breast cancer risk.

#### Ho et al. (2022)

The fair-quality Ho et al. BCSC NRSI^140^ was conducted using data from 126 radiology facilities participating in the BCSC to compute the cumulative probability of a false-positive result after 10 years of screening with DBT or DM during the years 2005 through 2018. The included observations were based on the screening visits of 903,495 women (444,704 DBT examinations, 2,524,351 DM examinations). The mean (SD) number of examinations per woman was 3.3 (2.5). First mammography examinations were excluded from the analysis, and had they been included, the estimated cumulative false-positive rates would have been higher. Logistic regression was used to estimate the probability of false-positive recall, short-interval recall, and biopsy after a single round of screening as a function of age, breast density, screening interval, modality, and interactions among these variables. In addition, the interaction of screening round and modality was included in the model along with the total number of screening rounds for the individual. These round-specific probabilities were used to generate the cumulative probability of having at least one false positive across 10 years of screening using discrete-time survival modeling to account for censoring. Estimates for annual compared with biennial screening and DBT compared with DM screening were presented and further stratified by age and breast density. Over the study period, the proportion of examinations conducted with DBT increased, but the age and breast density distributions of those screened with DBT and DM were similar, as were the proportion screened annually (nearly three-quarters) versus biennially.

#### Kerlikowske et al. (2022)

The fair-quality BCSC NRSI by Kerlikowske et al.^147^ was conducted using data from screening visits at 44 BCSC facilities to compare outcomes of screening with DBT or DM during the years 2011 through 2018. Additional followup for cancer diagnoses obtained from state and regional cancer registries continued through 2019. The cohort included 504,427 women ages 44 to 79 years who had at least one DBT or DM screening visit (based on radiologist indication in medical record). Individuals with a history of breast cancer or mastectomy were excluded. Screening visits were excluded from the analysis if they were: a first screening mammography (i.e., prevalence screening); unilateral screening; following a mammography within the previous nine months; included an ultrasound within three months; or included an MRI within 12 months. Demographic and health history information was obtained from questionnaires or the electronic medical record (EMR) and breast cancer diagnoses were obtained from regional and state tumor registries or the SEER database (estimated 94.3% complete outcome reporting). The unit of analysis for the study was the screening examination, and among the individuals in the cohort, 308,141 had only DM examinations (mean, 2.2 per person), 56,939 had only DBT (mean, 1.6 per person), and 139,347 had both DBT and DM (mean, 2.0 DBT and 2.3 DM per person). In total, the analysis included 1,377,902 screening examinations. To adjust for potential confounding related to the type of screening obtained, the statistical analysis used inverse-probability weighting (IPW) based on propensity scores. The propensity scores were obtained from a logistic model adjusted for age at examination, BCSC registry, facility type (academic versus not), calendar year, race and ethnicity, breast density, first-degree family history of breast cancer, time since last mammogram, and the most severe prior benign biopsy result. A generalized estimating equation was used to analyze the associations between the screening modality (with IPW) and cancer outcomes while accounting for clustering by BCSC facility and time since last mammogram. The study did not account for the patterns of screening over time when making comparisons between the two modalities. The potential remains in this observational study for unmeasured confounding and selection by indication related to access to health care, comorbidities, and ongoing screening patterns relative to studies that allocate participants to modality and observe outcomes across multiple screening rounds.

#### Lee et al. (2019)

An NRSI by Lee et al.^152^ reported results of an analysis using two BCSC registries (Vermont Breast Cancer Surveillance System and San Francisco Mammography Registry) to compare screening outcomes for individuals receiving ultrasonography on the same day as a screening mammogram (DM/US) compared with those who received only a mammogram (DM). Breast ultrasound examinations with a screening indication occurring from January 1, 2000, to December 31, 2013, were identified in the registries. Observations with the following characteristics were excluded: personal history of breast cancer, mastectomy, or known malignant neoplasm; unilateral breast examination; and self-reported breast symptoms (except pain). In one of the registries, data from radiology reports were abstracted from 14 percent of included observations to confirm the screening indication for ultrasonography—since 96% were confirmed, the remainder were included and assumed to be for screening indications. In the second registry, all reports were abstracted and the 78% confirmed to have screening indication for the ultrasound examination were included. Followup was for 12 months after the screening examination visit or until the next examination. Outcomes were obtained from the cancer registries and their linkages to other data sources (e.g., SEER, state tumor registries, clinical data). Propensity scores were estimated using logistic regression. The probabilities for the screening type were calculated using the following variables: BCSC registry, age, year of examination, race and ethnicity, menopausal status, first-degree family history of breast cancer, time since last mammogram, breast density, and prior benign biopsy result. These probabilities were used to conduct 1:5 matching for mammography plus ultrasound (n = 6,081 examinations, 3,386 women) and mammography only (n = 30,062 examinations, 113,293 women) from the same registries and without replacement. Comparisons between groups were tested using relative risk estimated from log binomial regression with adjustment for residual confounding using the propensity matching variables and a random effect for the matched sets to account for possible correlations. Before matching, those receiving ultrasonography were more likely to be younger, non-Hispanic White, have dense breasts, have a first-degree family history of breast cancer, and to have a BCSC risk score of 2.50 percent or greater. Over a quarter (26%) of those having ultrasonography screening did not have dense breasts.

#### Miglioretti et al. (2015)

A fair-quality BCSC NRSI by Miglioretti et al.^154^ used data on cancers detected in the BCSC registries from 1996 to 2012. The study compared the interval of screening relative to the characteristics of screen-detected and interval cancers. Individuals were included in the analysis if their cancer was preceded by at least two screening mammograms either 11 to 14 months apart (annual interval) or 23 to 26 months apart (biennial interval). Cancers were designated interval cancers if they followed a negative mammogram screening result and screen-detected interval cancers if they followed a positive screening result. The time of followup to assess interval cancers was 12 months for those with an annual interval before their cancer diagnosis and was 24 months for those with a biennial interval before their cancer diagnosis. Examinations were included as screening mammograms unless they were unilateral or if there was a mammography or ultrasonography visit within the prior nine months. Cancers were defined as having “less favorable prognostic characteristics” if they were at AJCC stage IIB or higher, size 15 mm or greater, or had positive nodes. Comparisons of prognostic characteristics by screening interval were presented, with adjustments for race and ethnicity, first-degree family history of breast cancer, and BCSC registry using logistic binomial regression. Notably, the analysis of cancer prognostic characteristics grouped together screen-detected and interval cancers (23% of total cancer cases). The characteristics of women with cancers preceded by an annual screening interval (n = 12,070) and those preceded by a biennial interval (n = 3,370) differed on some reported factors; those with an annual interval preceding a cancer diagnosis were less likely to be ages 40 to 49 (14% versus 18%) or 70 to 85 (29% vs 27%), and more likely to have a first-degree family history of breast cancer (23% versus 18%). The groups did not differ in race and ethnicity composition, and over three-quarters of the study population was non-Hispanic White (78%), with the remaining participants reported as Black (5%), Asian (5%), Hispanic (5%), AI/AN (<1%), and 7% reported as “other” or unknown. This study did not report overall effects of the screening interval on the types of cancers diagnosed, but provides results stratified by age and menopausal status that are reported as KQ2a results below.

### Malmö Breast Tomosynthesis Screening Trial (MBTST)

The fair-quality MBTST^79^ is an NRSI using prospectively collected cohort data in Sweden comparing women screened with DBT/DM through their participation in a screening performance cohort study (n = 13,369) with a concurrently screening period (2010 to 2015) for an age-matched control cohort screened with DM (n = 26,738). Those screened with DBT/DM had two independent readings of their DBT image (read first), DM image from the visit, and any previous DM images. The age-matched controls were selected from the screening program registry records for women who did not participate in the DBT/DM study but were screened in the same setting, which relied on the same radiologists as the DBT/DM study. A random selection of a single DM reading instance was drawn from the registry and used for 2:1 age-matching (+/− 1 year) and date of screen matching (+/− 1 year) with the DBT/DM trial participants. Matches were made for all but 1,479 DBT/DM screened individuals. Apart from the age- and date-matching, no descriptions of or additional adjustments for potential differences between the two groups were provided.

### Blue Cross Blue Shield

A fair-quality NRSI by Richman et al.^162^ conducted in the United States used national medical claims registry data from the Blue Cross Blue Shield Axis, which contains deidentified commercial insurance claims. The study comparing DBT/DM screening with DM screening among women ages 40 to 64 years included individuals receiving at least one screening mammogram between January 1, 2016, and December 31, 2017, who had been continuously enrolled for at least two years preceding the screen and for at least one year following the screen. Exclusions were any breast cancer diagnosis in the two years preceding the screen and any insurance claims indicative of a genetic cancer syndrome or prophylactic mastectomy. To distinguish screening mammograms from diagnostic mammograms in the claims data, a previously validated algorithm was used. The analytic sample included 7,602,869 screening mammograms conducted among 4,580,698 women.

### Know Your Risk: Assessment at Screening (KYRAS) study

The KYRAS study^153^ calculated the cumulative risk of false-positive screens over a median of 8.9 years. Eligible women were those screened at the Columbia University Medical Center (New York) during 2014 and 2015; for these women, the study collected information on previous mammograms going back to 1989 based on their health record (N = 2,019; median age, 59 years). Women with a previous diagnosis of breast cancer or who did not speak English or Spanish were excluded from the study. Frequency of screening was determined in the electronic health record by calculating the median number of days between mammograms. If the median screening interval was between 274 days (9 months) and 548 days (18 months), then it was coded as yearly screening; a median interval between 548 days (18 months) and 913 days (30 months) was coded as biennial screening. Overall, women underwent a median of 7 mammograms during the study period.

The screening interval was categorized as annual if the previous examination was within nine to 18 months and biennial if it was within 19 to 30 months. Intervals longer than 30 months were coded as triennial or longer (accounting for 11% of examinations) but were not reported on in the study results. First mammography examinations were excluded from the analysis, and had they been included, the estimated cumulative false-positive rates would have been higher. Logistic regression was used to estimate the probability of false-positive recall, short-interval recall, and biopsy after a single round of screening as a function of age, breast density, screening interval, modality, and interactions among these variables. In addition, the interaction of screening round and modality was included in the model along with the total number of screening rounds for the individual. These round-specific probabilities were used to generate the cumulative probability of having at least one false positive across 10 years of screening using discrete-time survival modeling to account for censoring. Estimates for annual compared with biennial screening and DBT compared with DM screening were presented and further stratified by age and breast density.

Appendix E Table 1 Additional Details on Included Trials and NRSIs

Intervention Category | Study Design | Author, Year; Study/Trial Name | Country | Comparison (IG vs. CG) | Number of Readers | Reader Experience/Training | Type of Reading | Consensus Method | Case and Mortality Ascertainment Method
Age to Stop | NRSI | Garcia-Albeniz, 2020 | US | Continuing annual DM beyond 70 years of age vs. Stopping annual DM at 70 years of age | NR | NR | NR | NR | Medicare data and National Death Index
Screening Frequency | RCT | Blamey, 2002; UKCCCR | UK | Annual DM vs. Triennial DM | NR | NR | NR | NR | Local hospital data and regional cancer registries
Screening Frequency | NRSI | Ho, 2022; BCSC | US | Annual DBT/DM or DM vs. Biennial DBT/DM or DM | NR | NR | NR | NR | BCSC registry data, pathology databases, stage/regional tumor registries, state death records
Screening Frequency | NRSI | McGuinness, 2018; KYRAS | US | Annual DM vs. Biennial DM | NR | NR | NR | NR | Electronic health record
Screening Frequency | NRSI | Miglioretti, 2015; BCSC | US | Annual DM vs. Biennial DM | NR | NR | NR | NR | BCSC registry data, pathology databases, stage/regional tumor registries
Screening Frequency | NRSI | Parvinen, 2011 | Finland | Annual DM vs. Biennial DM | 8 | NR | Dual | NR | National cancer and mortality databases
Digital Breast Tomosynthesis | RCT | Armaroli, 2022; Proteus; Donna; Fair | Italy | DBT/DM (round 1), DM (round 2) vs. DM | 38 | Radiologists received basic training in integrated DM and DBT and pass a trial evaluation with the interpretation of 40 DBT cases. Readers met regional quality assurance of 5,000+ mammograms per year with periodic audits of performance. | Dual independent | If either radiologist gave a score of 3 (probably benign) or higher the case was considered positive and recalled for investigation without consensus or arbitration | Population screening database, histology reports, hospital and population cancer registry
Digital Breast Tomosynthesis | RCT | Heindel, 2022; TOSYMA; Good | Germany | DBT/sDM vs. DM | NR | Participated in all regular teaching courses for mammography screening program and having passed the yearly test of 50 screening case studies, a volume of at least 5,000 screening mammograms the year before participating in the study, readers regularly assessed with an emphasis on a comparable number of sets for DBT/sDM and DM images | Dual independent | In case of any suspicious abnormality, reading results were clarified with an arbitrator to decide whether women had to be recalled for further diagnostic tests | Cancer registries
Digital Breast Tomosynthesis | RCT | Pattacini, 2022; RETomo; Good | Italy | DBT/DM (round 1), DM (round 2) vs. DM | 10 | 4 to 20 years. Regional quality assurance criterion of at least 5,000 mammograms per year and period audits of individual performance indications and interval cancer imagining review | Dual independent | Arbitration by third reviewer | Screening database and cancer registry
Digital Breast Tomosynthesis | RCT | Hofvind, 2021; To-Be; Good | Norway | DBT/sDM vs. DM (round 1), DBT/sDM (round 2) | 8 | Their experience in screen reading (screen film and digital mammography) before start-up of the trial varied from zero to approximately 110,000 examinations | Dual independent | Consensus was done by pairs of radiologists, and a third radiologist was consulted if the pair could not agree | National cancer registry
Digital Breast Tomosynthesis | NRSI | Sprague, 2023; BCSC | US | DBT vs. DM | NR | NR | NR | NR | BCSC registry data, pathology databases, stage/regional tumor registries
Digital Breast Tomosynthesis | | Ho, 2022; BCSC-2022a | US | DBT vs. DM | 699 | NR | NR | NR | BCSC registry data, pathology databases, stage/regional tumor registries, state death records
Digital Breast Tomosynthesis | | Kerlikowske, 2022; BCSC-2022b | US | DBT vs. DM | NR | NR | NR | NR | BCSC registry data, pathology databases, regional/state tumor registries, SEER programs
Digital Breast Tomosynthesis | | Johnson, 2021; MBTST | Sweden | DBT/DM vs. DM | 7 | 2 to 41 years. Previous experience with DBT from clinical work or studies of previous DBT | Dual independent | Examinations that scored as suspicious based on any modality were evaluated at a consensus meeting | National cancer registry
Digital Breast Tomosynthesis | | Richman, 2021 | US | DBT/DM vs. DM | NR | NR | NR | NR | Commercial insurance claims
Digital Breast Tomosynthesis | | Hovda, 2020; OVVV | Sweden | DBT/sDM (round 1), DM (round 2) vs. DM | NR | 0 to 14 (using DM), 0 to 3 (using DBT) | Dual independent | Readings given a score of 1-5. If at least one radiologist gave score of 2 (probably benign) or greater a consensus meeting was held to determine recall Consensus with random pairs of radiologists | National cancer registry
Digital Breast Tomosynthesis | | Conant, 2016; PROSPR | US | DBT/DM vs. DM | NR | NR | NR | NR | Electronic health records, pathology databases, institutional and state cancer registries
Supplemental MRI | RCT | Veenhuizen, 2021; DENSE | The Netherlands | DM plus MRI vs. DM | NR | 5 to 23 years | Single reader | For those with a BI-RADS 3 score, double reading was performed, consensus on level 3 lead to repeat MRI within 6 months | National cancer registry
Supplemental MRI | NRSI | Ganguli, 2022 | US | MRI vs. DM | NR | NR | NR | NR | Medical claims database
Supplemental Ultrasound | RCT | Ohuchi, 2016; J-START | Japan | DM plus US vs. DM | NR | <1 for ultrasound training. Ultrasonography is performed by qualified physicians, laboratory technologists, clinical radiological technologists, or nurses having experience with breast ultrasonography and completed the breast ultrasonography training program. The technologists and the physicians involved in this trial are asked to finish 2-day, 16-hour education program for the standardization of ultrasound screening for breast cancer | Dual independent | Results of ultrasound were reassessed by physicians at the study sites, including radiologists and breast surgeons | Study database, postal survey, vital registry
Supplemental Ultrasound | NRSI | Lee, 2019; BCSC | US | DM plus US vs. DM | NR | NR | NR | NR | BCSC registry data, pathology databases, stage/regional tumor registries, state death records

Abbreviations: BCSC=Breast Cancer Surveillance Consortium; BI-RADS=Breast Imaging Reporting and Data System; DBT=digital breast tomosynthesis; DENSE=Dense Tissue and Early Breast Neoplasm Screening; DM=digital mammography; J-START=Japan Strategic Anti-cancer Randomized Trial; MBTST=Malmo Breast Tomosynthesis Screening Trial; NR=not reported; NRSI=nonrandomized study of intervention; RCT=randomized controlled trial; RETomo=Reggio Emilia Tomosynthesis Trial; sDM=synthetic mammography; PROSPR=Population-based Research Optimizing Screening through Personalized Regimens; To-Be=Tomosynthesis Trial in Bergen; TOSYMA=TOmosynthesis plus SYnthesized MAmmography study; OVVV=Oslo-Vestfold-Vestre Viken; UKCCR=United Kingdom Coordinating Committee on Cancer Research trial; US=ultrasound