# Appendix D Excluded Studies

Reason for Exclusion
E1 | Population
E1a | Population: Limited to high-risk women
E1b | Population: Limited to women referred for diagnosis/surveillance or combines screening and referred populations but does not stratify outcomes
E2 | Intervention
E2a | Intervention: Limited to excluded screening methods (BSE, CBE)
E2b | Intervention: Limited to DM or FM and is not assessing a screening strategy that differs from usual care
E3 | Comparator
E3a | Comparator: Comparison arm limited to excluded screening methods (BSE, CBE)
E4 | Outcomes: No relevant outcomes
E5 | Timing (single round of screening only [KQ1, KQ2 exclusion])
E6 | Setting
E6a | Setting: Screening not done in primary care or setting with a primary care-comparable population
E6b | Setting: Study was not conducted in a very high HDI country
E7 | Study design
E7a | Study design: (systematic) reviews, editorials, opinions
E7b | Study design: Case series
E7c | Study design: Cohort study using non-contemporaneous selection of study groups
E7d | Study design: Studies using paired designs (i.e., within-person comparison)
E7e | Study design: Case control study, but not a large population-based nested case-control (KQ3 only)
E7f | Study design: Cross sectional study, but not from an included trial (KQ3 only)
E7g | Study design: Large population-based registry or surveillance system using selected, nonrepresentative subset of data
E7h | Study design: Modeling study
E7i | Study design: Biased selection into study groups
E7j | Study design: Does not report cumulative harms by number of completed screens (KQ3 only)
E8 | Non-English language publication
E9 | Unable to locate article
E10 | Abstract only or study ongoing, no outcomes published
E11 | Poor quality

1 Reduction in breast cancer mortality from organized service screening with mammography: 1. Further confirmation with extended data. Cancer Epidemiol Biomarkers Prev. 15(1): 45–51. 2006. 10.1158/1055-9965.Epi-05-0349. KQ1E2b, KQ2E2b, KQ3E2b16434585
2 The benefits and harms of breast cancer screening: an independent review. Lancet. 380(9855): 1778–86. 2012. 10.1016/s0140-6736(12)61611-0. KQ1E7a, KQ2E7a, KQ3E7a23117178
3 Advani, S, Abraham, L, . Breast biopsy patterns and findings among older women undergoing screening mammography: The role of age and comorbidity. J Geriatr Oncol. 13(2): 161–169. 2022. 10.1016/j.jgo.2021.11.013. KQ1E4, KQ2E4, KQ3E7j34896059
4 Advani, SM, Zhu, W, . Association of Breast Density With Breast Cancer Risk Among Women Aged 65 Years or Older by Age Group and Body Mass Index. JAMA Netw Open. 4(8): e2122810. 2021. 10.1001/jamanetworkopen.2021.22810. KQ1E3, KQ2E3, KQ3E334436608
5 Ahmadiyeh, N, Mendez, MA, . Factors Associated with Late-Stage Breast Cancer Diagnosis in an Urban Safety-net Hospital. J Health Care Poor Underserved. 31(3): 1152–1165. 2020. 10.1353/hpu.2020.0087. KQ1E3, KQ2E3, KQ3E333416687
6 Alabousi, A, Patlas, MN. Annual Mammographic Screening Reduces the Risk of Interval or Higher Stage Invasive Breast Cancers: Lessons for Today and Tomorrow. Can Assoc Radiol J. 73(3): 446–447. 2022. 10.1177/08465371211070555. KQ1E7a, KQ2E7a, KQ3E7a35094609
7 Allgood, PC, Warwick, J, . A case-control study of the impact of the East Anglian breast screening programme on breast cancer mortality. Br J Cancer. 98(1): 206–9. 2008. 10.1038/sj.bjc.6604123. KQ1E2b, KQ2E2b, KQ3E2b18059396
8 Alsheik, N, Blount, L, . Outcomes by Race in Breast Cancer Screening With Digital Breast Tomosynthesis Versus Digital Mammography. J Am Coll Radiol. 18(7): 906–918. 2021. 10.1016/j.jacr.2020.12.033. KQ1E4, KQ2E4, KQ3E7j33607065
9 Alsheik, NH, Dabbous, F, . Comparison of Resource Utilization and Clinical Outcomes Following Screening with Digital Breast Tomosynthesis Versus Digital Mammography: Findings From a Learning Health System. Acad Radiol. 26(5): 597–605. 2019. 10.1016/j.acra.2018.05.026. KQ1E4, KQ2E7, KQ3E1130057195
10 Ambinder, EB, Oluyemi, E, . Disparities in the uptake of digital breast tomosynthesis for breast cancer screening: A retrospective cohort study. Breast Journal. 27(12): 872–876. 2021. 10.1111/tbj.14292. KQ1E4, KQ2E4, KQ3E7j34668275
11 Ambinder, EB, Harvey, SC, . Synthesized Mammography: The New Standard of Care When Screening for Breast Cancer with Digital Breast Tomosynthesis?. Acad Radiol. 25(8): 973–976. 2018. 10.1016/j.acra.2017.12.015. KQ1E7c, KQ2E7c, KQ3E7c29395801
12 Amir, T, Ambinder, EB, . Benefits of digital breast tomosynthesis: A lesion-level analysis. J Med Screen. 28(3): 311–317. 2021. 10.1177/0969141320978267. KQ1E5, KQ2E5, KQ3E7j33334233
13 Aron, JL, Prorok, PC. An analysis of the mortality effect in a breast cancer screening study. Int J Epidemiol. 15(1): 36–43. 1986. 10.1093/ije/15.1.36. KQ1E2b, KQ2E2b, KQ3E2b3957541
14 Ascunce, EN, Moreno-Iribas, C, . Changes in breast cancer mortality in Navarre (Spain) after introduction of a screening programme. J Med Screen. 14(1): 14–20. 2007. 10.1258/096914107780154558. KQ1E2b, KQ2E2b, KQ3E2b17362566
15 Aujero, MP, Gavenonis, SC, . Clinical Performance of Synthesized Two-dimensional Mammography Combined with Tomosynthesis in a Large Screening Population. Radiology. 283(1): 70–76. 2017. 10.1148/radiol.2017162674. KQ1E4, KQ2E5, KQ3E7j28221096
16 Autier, P, Boniol, M, . Breast cancer mortality in neighbouring European countries with different levels of screening but similar access to treatment: trend analysis of WHO mortality database. BMJ. 343:d4411. 2011. 10.1136/bmj.d4411. KQ1E3, KQ2E3, KQ3E321798968
17 Autier, P, Boniol, M, . Effectiveness of and overdiagnosis from mammography screening in the Netherlands: population based study. BMJ. 359: j5224. 2017. 10.1136/bmj.j5224. KQ1E2b, KQ2E2b, KQ3E2b29208760
18 Bae, MS, Sung, JS, . Survival Outcomes of Screening with Breast MRI in Women at Elevated Risk of Breast Cancer. J Breast Imaging. 2(1): 29–35. 2020. 10.1093/jbi/wbz083. KQ1E1a, KQ2E1a, KQ3E1a32055796
19 Bahl, M, Gaffney, S, . Breast Cancer Characteristics Associated with 2D Digital Mammography versus Digital Breast Tomosynthesis for Screening-detected and Interval Cancers. Radiology. 287(1): 49–57. 2018. 10.1148/radiol.2017171148. KQ1E7c, KQ2E7c, KQ3E7c29272213
20 Bahl, M, Mercaldo, S, . Breast Cancer Screening with Digital Breast Tomosynthesis: Are Initial Benefits Sustained?. Radiology. 295(3): 529–539. 2020. 10.1148/radiol.2020191030. KQ1E7c, KQ2E7c, KQ3E7c32255414
21 Bahl, M, Mercaldo, S, . Comparison of performance metrics with digital 2D versus tomosynthesis mammography in the diagnostic setting. Eur Radiol. 29(2): 477–484. 2019. 10.1007/s00330-018-5596-7. KQ1E1b, KQ2E1b, KQ3E1b29967957
22 Bahl, M, Pinnamaneni, N, . Digital 2D versus Tomosynthesis Screening Mammography among Women Aged 65 and Older in the United States. Radiology. 291(3): 582–590. 2019. 10.1148/radiol.2019181637. KQ1E7c, KQ2E7c, KQ3E7c30938625
23 Balamou, C, Koivogui, A, . Impact of tomosynthesis on the evolution of the cancer detection rate in the French National Breast Cancer Screening Program. Public Health. 210: 65–73. 2022. 10.1016/j.puhe.2022.06.011. KQ1E4, KQ2E4, KQ3E435870323
24 Ban, K, Tsunoda, H, . Comparative study of the usefulness of adjunctive tomosynthesis in breast cancer screening by mammography and ultrasound in Japan. Breast Cancer. 29(5): 790–795. 2022. 10.1007/s12282-022-01358-w. KQ1E3, KQ2E3, KQ3E335585469
25 Ban, K, Tsunoda, H, . Breast cancer screening using digital breast tomosynthesis compared to digital mammography alone for Japanese women. Breast Cancer. 28(2): 459–464. 2021. 10.1007/s12282-020-01180-2. KQ1E4, KQ2E5, KQ3E7j33165757
26 Barchielli, A, Paci, E. Trends in breast cancer mortality, incidence, and survival, and mammographic screening in Tuscany, Italy. Cancer Causes Control. 12(3): 249–55. 2001. 10.1023/a:1011280204842. KQ1E2b, KQ2E2b, KQ3E2b11405330
27 Beckmann, K, Duffy, SW, . Estimates of over-diagnosis of breast cancer due to population-based mammography screening in South Australia after adjustment for lead time effects. J Med Screen. 22(3): 127–35. 2015. 10.1177/0969141315573978. KQ1E2b, KQ2E2b, KQ3E2b25896926
28 Berg, WA, Bandos, AI, . Ultrasound as the Primary Screening Test for Breast Cancer: Analysis From ACRIN 6666. J Natl Cancer Inst. 108(4). 2016. 10.1093/jnci/djv367. KQ1E7d, KQ2E7d, KQ3E7d
29 Berg, WA, Zhang, Z, . Detection of breast cancer with addition of annual screening ultrasound or a single screening MRI to mammography in women with elevated breast cancer risk. JAMA. 307(13): 1394–404. 2012. 10.1001/jama.2012.388. KQ1E1, KQ2E1, KQ3E122474203
30 Bernardi, D, Caumo, F, . Effect of integrating 3D-mammography (digital breast tomosynthesis) with 2D-mammography on radiologists’ true-positive and false-positive detection in a population breast screening trial. Eur J Cancer. 50(7): 1232–8. 2014. 10.1016/j.ejca.2014.02.004. KQ1E7d, KQ2E7d, KQ3E7d24582915
31 Bernardi, D, Ciatto, S, . Application of breast tomosynthesis in screening: incremental effect on mammography acquisition and reading time. Br J Radiol. 85(1020): e1174–8. 2012. 10.1259/bjr/19385909. KQ1E3, KQ2E3, KQ3E323175484
32 Bernardi, D, Gentilini, MA, . Effect of implementing digital breast tomosynthesis (DBT) instead of mammography on population screening outcomes including interval cancer rates: Results of the Trento DBT pilot evaluation. Breast. 50: 135–140. 2020. 10.1016/j.breast.2019.09.012. KQ1E7c, KQ2E7c, KQ3E7c31607526
33 Bernardi, D, Li, T, . Effect of integrating digital breast tomosynthesis (3D-mammography) with acquired or synthetic 2D-mammography on radiologists’ true-positive and false-positive detection in a population screening trial: A descriptive study. Eur J Radiol. 106: 26–31. 2018. 10.1016/j.ejrad.2018.07.008. KQ1E7d, KQ2E7d, KQ3E7d30150047
34 Bernardi, D, Macaskill, P, . Breast cancer screening with tomosynthesis (3D mammography) with acquired or synthetic 2D mammography compared with 2D mammography alone (STORM-2): a population-based prospective study. Lancet Oncol. 17(8): 1105–1113. 2016. 10.1016/S1470-2045(16)30101-2. KQ1E7d, KQ2E7d, KQ3E7d27345635
35 Bernardi, G, Cavallaro, G, . Usefulness of ultrasounds in the management of breast phyllodes tumors. G Chir. 33(3): 81–5. 2012. KQ1E1b, KQ2E1b, KQ3E1b22525552
36 Bian, T, Lin, Q, . Digital Breast Tomosynthesis: A New Diagnostic Method for Mass-Like Lesions in Dense Breasts. Breast Journal. 22(5): 535–40. 2016. 10.1111/tbj.12622. KQ1E6b, KQ2E6b, KQ3E6b27296324
37 Biesheuvel, C, Barratt, A, . Effects of study methods and biases on estimates of invasive breast cancer overdetection with mammography screening: a systematic review. Lancet Oncol. 8(12): 1129–1138. 2007. 10.1016/s1470-2045(07)70380-7. KQ1E7a, KQ2E7a, KQ3E7a18054882
38 Bjurstam, N, Björneld, L, . The Gothenburg Breast Screening Trial. Cancer. 97(10): 2387–96. 2003. 10.1002/cncr.11361. KQ1E3, KQ2E3, KQ3E312733136
39 Blackmore, KM, Chiarelli, AM, . Annual Mammographic Screening Reduces the Risk of Interval or Higher Stage Invasive Breast Cancers Among Postmenopausal Women in the Ontario Breast Screening Program. Can Assoc Radiol J. 73(3): 524–534. 2022. 10.1177/08465371211062883. KQ1E7i, KQ2E7i, KQ3E7i35068172
40 Blamey, RW Duffy S. The frequency of breast cancer screening results of a randomised trial. 2004. KQ1E10, KQ2E10, KQ3E10
41 Blanks, RG, Moss, SM, . Effect of NHS breast screening programme on mortality from breast cancer in England and Wales, 1990-8: comparison of observed with predicted mortality. BMJ. 321(7262): 665–9. 2000. 10.1136/bmj.321.7262.665. KQ1E2b, KQ2E2b, KQ3E2b10987769
42 Blue, Cross, Blue Shield Association, . Use of digital breast tomosynthesis with mammography for breast cancer screening or diagnosis. Technol Eval Cent Assess Program Exec Summ. 28(6): 1–6. 2014. KQ1E7a, KQ2E7a, KQ3E7a
43 Bolejko, A, Hagell, P, . Prevalence, Long-term Development, and Predictors of Psychosocial Consequences of False-Positive Mammography among Women Attending Population-Based Screening. Cancer Epidemiol Biomarkers Prevent. 24(9): 1388–97. 2015. 10.1158/1055-9965.EPI-15-0060. KQ1E3, KQ2E3, KQ3E3
44 Bond, M, Pavey, T, . Psychological consequences of false-positive screening mammograms in the UK. Evid Based Med. 18(2): 54–61. 2013. 10.1136/eb-2012-100608. KQ1E7a, KQ2E7a, KQ3E7a22859786
45 Bottorff, JL, Ratner, PA, . Women’s responses to information on mammographic breast density. Can J Nurs Res. 39(1): 38–57. 2007. KQ1E2, KQ2E2, KQ3E217450704
46 Brancato, B, Bonardi, R, . Negligible advantages and excess costs of routine addition of breast ultrasonography to mammography in dense breasts. Tumori. 93(6): 562–6. 2007. 10.1177/030089160709300608. KQ1E7, KQ2E7, KQ3E718338490
47 Brem, RF, Tabar, L, . Assessing improvement in detection of breast cancer with three-dimensional automated breast US in women with dense breast tissue: the SomoInsight Study. Radiology. 274(3): 663–73. 2015. 10.1148/radiol.14132832. KQ1E7d, KQ2E7d, KQ3E7d25329763
48 Brem, RF, Tabár, László, . Assessing Improvement in Detection of Breast Cancer with Three-dimensional Automated Breast US in Women with Dense Breast Tissue: The SomoInsight Study. Radiology. 274(3): 663–673. 2015. 10.1148/radiol.14132832. KQ1E7d, KQ2E7d, KQ3E7d25329763
49 Brett, J, Austoker, J. Women who are recalled for further investigation for breast screening: psychological consequences 3 years after recall and factors affecting re-attendance. J Public Health Med. 23(4): 292–300. 2001. 10.1093/pubmed/23.4.292. KQ1E2b, KQ2E2b, KQ3E2b11873891
50 Brett, J, Bankhead, C, . The psychological impact of mammographic screening. A systematic review. Psychooncology. 14(11): 917–38. 2005. 10.1002/pon.904. KQ1E7a, KQ2E7a, KQ3E7a15786514
51 Brewer, NT, Salz, T, . Systematic review: the long-term effects of false-positive mammograms. Ann Intern Med. 146(7): 502–10. 2007. 10.7326/0003-4819-146-7-200704030-00006. KQ1E7a, KQ2E7a, KQ3E7a17404352
52 Brodersen, J, Siersma, VD. Long-term psychosocial consequences of false-positive screening mammography. Ann Fam Med. 11(2): 106–15. 2013. 10.1370/afm.1466. KQ1E2b, KQ2E2b, KQ3E2b23508596
53 Broeders, M, Moss, S, . The impact of mammographic screening on breast cancer mortality in Europe: a review of observational studies. J Med Screen. 19 Suppl 1: 14–25. 2012. 10.1258/jms.2012.012078. KQ1E7a, KQ2E7a, KQ3E7a
54 Bucchi, L, Ravaioli, A, . Annual mammography at age 45-49 years and biennial mammography at age 50-69 years: comparing performance measures in an organised screening setting. Eur Radiol. 29(10): 5517–5527. 2019. 10.1007/s00330-019-06050-w. KQ1E7c, KQ2E7c, KQ3E7c30887204
55 Buchberger, W, Geiger-Gritsch, S, . Combined screening with mammography and ultrasound in a population-based screening program. Eur J Radiol. 101: 24–29. 2018. 10.1016/j.ejrad.2018.01.022. KQ1E4, KQ2E5, KQ3E7d29571797
56 Buchberger, W, Niehoff, A, . Clinically and mammographically occult breast lesions: detection and classification with high-resolution sonography. Semin Ultrasound CT MR. 21(4): 325–36. 2000. 10.1016/s0887-2171(00)90027-1. KQ1E7d, KQ2E7d, KQ3E7d11014255
57 Bull, AR, Campbell, MJ. Assessment of the psychological impact of a breast screening programme. Br J Radiol. 64(762): 510–5. 1991. 10.1259/0007-1285-64-762-510. KQ1E2b, KQ2E2b, KQ3E2b2070180
58 Buseman, S, Mouchawar, J, . Mammography screening matters for young women with breast carcinoma: evidence of downstaging among 42-49-year-old women with a history of previous mammography screening. Cancer. 97(2): 352–8. 2003. 10.1002/cncr.11050. KQ1E3, KQ2E3, KQ3E312518359
59 Cabanes, A, Vidal, E, . Age-specific breast, uterine and ovarian cancer mortality trends in Spain: changes from 1980 to 2006. Cancer Epidemiol. 33(3–4): 169–75. 2009. 10.1016/j.canep.2009.08.010. KQ1E7, KQ2E7, KQ3E719766076
60 Castellano, CR, Aguilar Angulo, PM, . Breast cancer mortality after eight years of an improved screening program using digital breast tomosynthesis. J Med Screen. 9691413211002556. 2021. 10.1177/09691413211002556. KQ1E2, KQ2E2, KQ3E2
61 Caumo, F, Bernardi, D, . Incremental effect from integrating 3D-mammography (tomosynthesis) with 2D-mammography: Increased breast cancer detection evident for screening centres in a population-based trial. Breast. 23(1): 76–80. 2014. 10.1016/j.breast.2013.11.006. KQ1E7d, KQ2E7d, KQ3E7d24316152
62 Caumo, F, Montemezzi, S, . Repeat Screening Outcomes with Digital Breast Tomosynthesis Plus Synthetic Mammography for Breast Cancer Detection: Results from the Prospective Verona Pilot Study. Radiology. 298(1): 49–57. 2021. 10.1148/radiol.2020201246. KQ1E4, KQ2E11, KQ3E1133170101
63 Caumo, F, Romanucci, G, . Comparison of breast cancers detected in the Verona screening program following transition to digital breast tomosynthesis screening with cancers detected at digital mammography screening. Breast Cancer Res Treat. 170(2): 391–397. 2018. 10.1007/s10549-018-4756-4. KQ1E5, KQ2E7c, KQ3E7c29557996
64 Caumo, F, Zorzi, M, . Digital Breast Tomosynthesis with Synthesized Two-Dimensional Images versus Full-Field Digital Mammography for Population Screening: Outcomes from the Verona Screening Program. Radiology. 287(1): 37–46. 2018. 10.1148/radiol.2017170745. KQ1E7c, KQ2E7c, KQ3E7c29237146
65 Chae, EY, Kim, HH, . Evaluation of screening whole-breast sonography as a supplemental tool in conjunction with mammography in women with dense breasts. J Ultrasound Med. 32(9): 1573–8. 2013. 10.7863/ultra.32.9.1573. KQ1E5, KQ2E5, KQ3E1123980217
66 Chan, HP, Helvie, MA, . Characterization of Breast Masses in Digital Breast Tomosynthesis and Digital Mammograms: An Observer Performance Study. Acad Radiol. 24(11): 1372–1379. 2017. 10.1016/j.acra.2017.04.016. KQ1E1b, KQ2E1b, KQ3E1b28647388
67 Chen, SQ, Huang, M, . Abbreviated MRI Protocols for Detecting Breast Cancer in Women with Dense Breasts. Korean J Radiol. 18(3): 470–475. 2017. 10.3348/kjr.2017.18.3.470. KQ1E7d, KQ2E7d, KQ3E7d28458599
68 Chiarelli, AM, Blackmore, KM, . Annual vs Biennial Screening: Diagnostic Accuracy Among Concurrent Cohorts Within the Ontario Breast Screening Program. J Natl Cancer Inst. 112(4): 400–409. 2020. 10.1093/jnci/djz131. KQ1E4, KQ2E7i, KQ3E7i31233138
69 Chiarelli, AM, Blackmore, KM, . Performance Measures of Magnetic Resonance Imaging Plus Mammography in the High Risk Ontario Breast Screening Program. J Natl Cancer Inst. 112(2): 136–144. 2020. 10.1093/jnci/djz079. KQ1E1a, KQ2E1a, KQ3E1a31233143
70 Chiarelli, AM, Majpruz, V, . The contribution of clinical breast examination to the accuracy of breast screening. J Natl Cancer Inst. 101(18): 1236–43. 2009. 10.1093/jnci/djp241. KQ1E3a, KQ2E3a, KQ3E3a19720967
71 Cho, KR, Seo, BK, . Breast Cancer Detection in a Screening Population: Comparison of Digital Mammography, Computer-Aided Detection Applied to Digital Mammography and Breast Ultrasound. J Breast Cancer. 19(3): 316–323. 2016. 10.4048/jbc.2016.19.3.316. KQ1E7d, KQ2E7d, KQ3E7d27721882
72 Choi, E, Jun, JK, . Effectiveness of the Korean National Cancer Screening Program in reducing breast cancer mortality. NPJ Breast Cancer. 7(1): 83. 2021. 10.1038/s41523-021-00295-9. KQ1E3, KQ2E3, KQ3E334183679
73 Chough, Denise M, Berg, Wendie A, . A Prospective Study of Automated Breast Ultrasound Screening of Women with Dense Breasts in a Digital Breast Tomosynthesis-based Practice. J Breast Imaging. 2(2): 125–133. 2020. 10.1093/jbi/wbaa006. KQ1E7d, KQ2E7d, KQ3E7d38424893
74 Chu, KC, Smart, CR, . Analysis of breast cancer mortality and stage distribution by age for the Health Insurance Plan clinical trial. J Natl Cancer Inst. 80(14): 1125–32. 1988. 10.1093/jnci/80.14.1125. KQ1E3, KQ2E3, KQ3E33411625
75 Ciatto, S, Houssami, N, . Integration of 3D digital mammography with tomosynthesis for population breast-cancer screening (STORM): a prospective comparison study. Lancet Oncol. 14(7): 583–9. 2013. 10.1016/s1470-2045(13)70134-7. KQ1E7d, KQ2E7d, KQ3E7d23623721
76 Cochon, LR, Giess, CS, . Comparing Diagnostic Performance of Digital Breast Tomosynthesis and Full-Field Digital Mammography. J Am Coll Radiol. 17(8): 999–1003. 2020. 10.1016/j.jacr.2020.01.010. KQ1E7c, KQ2E7c, KQ3E7c32068009
77 Cohen, EO, Weaver, OO, . Breast Cancer Screening via Digital Mammography, Synthetic Mammography, and Tomosynthesis. Am J Prev Med. 58(3): 470–472. 2020. 10.1016/j.amepre.2019.09.016. KQ1E4, KQ2E5, KQ3E7j31732323
78 Cohen, EO, Perry, RE, . Breast cancer screening in women with and without implants: retrospective study comparing digital mammography to digital mammography combined with digital breast tomosynthesis. Eur Radiol. 20: 20. 2021. 10.1007/s00330-021-08040-3. KQ1E4, KQ2E5, KQ3E7j
79 Cohen, EO, Tso, HH, . Screening Mammography Findings From One Standard Projection Only in the Era of Full-Field Digital Mammography and Digital Breast Tomosynthesis. AJR Am J Roentgenol. 211(2): 445–451. 2018. 10.2214/AJR.17.19023. KQ1E5, KQ2E5, KQ3E7j29792742
80 Cohen, EO, Weaver, OO, . Breast Cancer Screening via Digital Mammography, Synthetic Mammography, and Tomosynthesis. Am J Prev Med. 58(3): 470–472. 2020. 10.1016/j.amepre.2019.09.016. KQ1E5, KQ2E5, KQ3E7j31732323
81 Coldman, A, Phillips, N, . Pan-Canadian study of mammography screening and mortality from breast cancer. J Natl Cancer Inst. 106(11). 2014. 10.1093/jnci/dju261. KQ1E2b, KQ2E2b, KQ3E2b
82 Coldman, A, Phillips, N. Incidence of breast cancer and estimates of overdiagnosis after the initiation of a population-based mammography screening program. CMAJ. 185(10): E492–8. 2013. 10.1503/cmaj.121791. KQ1E4, KQ2E4, KQ3E2b23754101
83 Coldman, AJ, Phillips, N, . Impact of changing from annual to biennial mammographic screening on breast cancer outcomes in women aged 50-79 in British Columbia. J Med Screen. 15(4): 182–7. 2008. 10.1258/jms.2008.008064. KQ1E7c, KQ2E7c, KQ3E7c19106258
84 Comstock, CE, Gatsonis, C, . Comparison of Abbreviated Breast MRI vs Digital Breast Tomosynthesis for Breast Cancer Detection Among Women With Dense Breasts Undergoing Screening. JAMA. 323(8): 746–756. 2020. 10.1001/JAMA.2020.0572. KQ1E7d, KQ2E7d, KQ3E7d32096852
85 Conant, EF, Barlow, WE, . Association of Digital Breast Tomosynthesis vs Digital Mammography With Cancer Detection and Recall Rates by Age and Breast Density. JAMA Oncology. 5(5): 635–642. 2019. 10.1001/JAMAoncol.2018.7078. KQ1E4, KQ2E7, KQ3E7j30816931
86 Conant, EF, Zuckerman, SP, . Five Consecutive Years of Screening with Digital Breast Tomosynthesis: Outcomes by Screening Year and Round. Radiology. 295(2): 285–293. 2020. 10.1148/radiol.2020191751. KQ1E7c, KQ2E7c, KQ3E7c32154771
87 Corsetti, V, Houssami, N, . Evidence of the effect of adjunct ultrasound screening in women with mammography-negative dense breasts: interval breast cancers at 1 year follow-up. Eur J Cancer. 47(7): 1021–6. 2011. 10.1016/j.ejca.2010.12.002. KQ1E3, KQ2E3, KQ3E321211962
88 Crystal, P, Strano, SD, . Using sonography to screen women with mammographically dense breasts. AJR Am J Roentgenol. 181(1): 177–82. 2003. 10.2214/ajr.181.1.1810177. KQ1E7d, KQ2E7d, KQ3E7d12818853
89 Dang, PA, Wang, A, . Comparing Tumor Characteristics and Rates of Breast Cancers Detected by Screening Digital Breast Tomosynthesis and Full-Field Digital Mammography. AJR Am J Roentgenol. 214(3): 701–706. 2020. 10.2214/AJR.18.21060. KQ1E5, KQ2E5, KQ3E431613659
90 de Gelder, R, Fracheboud, J, . Digital mammography screening: weighing reduced mortality against increased overdiagnosis. Prev Med. 53(3): 134–40. 2011. 10.1016/j.ypmed.2011.06.009. KQ1E2b, KQ2E2b, KQ3E2b21718717
91 de Gelder, R, Heijnsdijk, EA, . Interpreting overdiagnosis estimates in population-based mammography screening. Epidemiol Rev. 33(1): 111–21. 2011. 10.1093/epirev/mxr009. KQ1E7h, KQ2E7h, KQ3E7h21709144
92 de Glas, NA, de Craen, AJ, . Effect of implementation of the mass breast cancer screening programme in older women in the Netherlands: population based study. BMJ. 349: g5410. 2014. 10.1136/bmj.g5410. KQ1E2b, KQ2E2b, KQ3E2b25224469
93 de Koning, HJ, Draisma, G, . Overdiagnosis and overtreatment of breast cancer: microsimulation modelling estimates based on observed screen and clinical data. Breast Cancer Res. 8(1): 202. 2006. 10.1186/bcr1369. KQ1E7h, KQ2E7h, KQ3E7h16524452
94 Destounis, S, Arieno, A, . Comparison of Cancers Detected by Screening Breast Ultrasound and Digital Breast Tomosynthesis. Acad Radiol. 12: 12. 2021. 10.1016/j.acra.2021.01.008. KQ1E7d, KQ2E7d, KQ3E7d
95 Destounis, S, Arieno, A, . Initial experience with combination digital breast tomosynthesis plus full field digital mammography or full field digital mammography alone in the screening environment. J Clin Imaging Sci. 4: 9. 2014. 10.4103/2156-7514.127838. KQ1E4, KQ2E11, KQ3E1124744966
96 Destounis, S, Arieno, A, . New York State Breast Density Mandate: Follow-up Data With Screening Sonography. J Ultrasound Med. 36(12): 2511–2517. 2017. 10.1002/jum.14294. KQ1E3, KQ2E3, KQ3E328656638
97 Dibble, EH, Singer, TM, . BI-RADS 3 on dense breast screening ultrasound after digital mammography versus digital breast tomosynthesis. Clin Imaging. 80: 315–321. 2021. 10.1016/j.clinimag.2021.07.030. KQ1E4, KQ2E4, KQ3E434482242
98 Dibble, EH, Singer, TM, . Dense Breast Ultrasound Screening After Digital Mammography Versus After Digital Breast Tomosynthesis. AJR Am J Roentgenol. 213(6): 1397–1402. 2019. 10.2214/AJR.18.20748. KQ1E1b, KQ2E1b, KQ3E1b31553658
99 Ding, L, Greuter, MJW, . Irregular screening participation increases advanced stage breast cancer at diagnosis: A population-based study. Breast. 65: 61–66. 2022. 10.1016/j.breast.2022.07.004. KQ1E3, KQ2E3, KQ3E335820298
100 DiPrete, O, Lourenco, AP, . Screening Digital Mammography Recall Rate: Does It Change with Digital Breast Tomosynthesis Experience?. Radiology. 286(3): 838–844. 2018. 10.1148/radiol.2017170517. KQ1E7c, KQ2E7c, KQ3E7c29173123
101 Dodelzon, K, Starikov, A, . Breast cancer in women under age 40: A decade of trend analysis at a single institution. Clin Imaging. 78: 165–170. 2021. 10.1016/j.clinimag.2021.03.031. KQ1E1, KQ2E1, KQ3E133836424
102 Domingo, L, Hofvind, S, . Cross-national comparison of screening mammography accuracy measures in U.S., Norway, and Spain. Eur Radiol. 26(8): 2520–8. 2016. 10.1007/s00330-015-4074-8. KQ1E2b, KQ2E2b, KQ3E2b26560729
103 Duffy, S, Vulkan, D, . Annual mammographic screening to reduce breast cancer mortality in women from age 40 years: long-term follow-up of the UK Age RCT. Health Technol Assess. 24(55): 1–24. 2020. 10.3310/hta24550. KQ1E7, KQ2E7, KQ3E7
104 Duffy, SW, Agbaje, O, . Overdiagnosis and overtreatment of breast cancer: estimates of overdiagnosis from two trials of mammographic screening for breast cancer. Breast Cancer Res. 7(6): 258–65. 2005. 10.1186/bcr1354. KQ1E3, KQ2E3, KQ3E316457701
105 Duffy, SW, Tabar, L, . Absolute numbers of lives saved and overdiagnosis in breast cancer screening, from a randomized trial and from the Breast Screening Programme in England. J Med Screen. 17(1): 25–30. 2010. 10.1258/jms.2009.009094. KQ1E3, KQ2E3, KQ3E320356942
106 Duffy, SW, Tabar, L, . Beneficial Effect of Consecutive Screening Mammography Examinations on Mortality from Breast Cancer: A Prospective Study. Radiology. 299(3): 541–547. 2021. 10.1148/radiol.2021203935. KQ1E3, KQ2E3, KQ3E333650900
107 Duffy, SW, Tabar, L, . The Swedish Two-County Trial of mammographic screening: cluster randomisation and end point evaluation. Ann Oncol. 14(8): 1196–8. 2003. 10.1093/annonc/mdg322. KQ1E3, KQ2E3, KQ3E312881376
108 Duffy, SW, Vulkan, D, . Effect of mammographic screening from age 40 years on breast cancer mortality (UK Age trial): final results of a randomised, controlled trial. Lancet Oncol. 21(9): 1165–1172. 2020. 10.1016/S1470-2045(20)30398-3. KQ1E3, KQ2E4, KQ3E332800099
109 Duijm, LEM, Broeders, MJM, . Effects of nonparticipation at previous screening rounds on the characteristics of screen-detected breast cancers. Eur J Radiol. 154: 110391. 2022. 10.1016/j.ejrad.2022.110391. KQ1E3, KQ2E3, KQ3E335679699
110 Durand, MA, Friedewald, SM, . False-Negative Rates of Breast Cancer Screening with and without Digital Breast Tomosynthesis. Radiology. 298(2): 296–305. 2021. 10.1148/radiol.2020202858. KQ1E5, KQ2E5, KQ3E7c33258744
111 Durand, MA, Haas, BM, . Early clinical experience with digital breast tomosynthesis for screening mammography. Radiology. 274(1): 85–92. 2015. 10.1148/radiol.14131319. KQ1E4, KQ2E5, KQ3E7j25188431
112 Ekpo, EU, Ujong, UP, . Assessment of Interradiologist Agreement Regarding Mammographic Breast Density Classification Using the Fifth Edition of the BI-RADS Atlas. AJR Am J Roentgenol. 206(5): 1119–23. 2016. 10.2214/ajr.15.15049. KQ1E4, KQ2E4, KQ3E426999655
113 El Bakry, Rehab Abdel Rahman. Breast tomosynthesis: A diagnostic addition to screening digital mammography. The Egyptian Journal of Radiology and Nuclear Medicine. 49(2): 529–535. 2018. 10.1016/j.ejrnm.2017.12.004. KQ1E7d, KQ2E7d, KQ3E7d
114 Elbakkoush, AA, Atique, S, . Screening Mammography Efficacy: A Comparison Between Screen-Film, Computed Radiography and Digital Mammography in Taiwan. Stud Health Technol Inform. 216: 914. 2015. KQ1E2b, KQ2E2b, KQ3E2b26262216
115 Ellman, R, Angeli, N, . Psychiatric morbidity associated with screening for breast cancer. Br J Cancer. 60(5): 781–4. 1989. 10.1038/bjc.1989.359. KQ1E3, KQ2E3, KQ3E32803955
116 Elmore, JG, Barton, MB, . Ten-year risk of false positive screening mammograms and clinical breast examinations. N Engl J Med. 338(16): 1089–96. 1998. 10.1056/nejm199804163381601. KQ1E3a, KQ2E3a, KQ3E3a9545356
117 El-Zaemey, S, Liz, W, . Impact of the age expansion of breast screening on screening uptake and screening outcomes among older women in BreastScreen western. Breast. 56: 96–102. 2021. 10.1016/j.breast.2021.02.006. KQ1E7c, KQ2E7c, KQ3E7c33647788
118 Endo, T, Morita, T, . Diagnostic performance of digital breast tomosynthesis and full-field digital mammography with new reconstruction and new processing for dose reduction. Breast Cancer. 25(2): 159–166. 2018. 10.1007/s12282-017-0805-9. KQ1E7d, KQ2E7d, KQ3E7d28956298
119 Espasa, R, Murta-Nascimento, C, . The psychological impact of a false-positive screening mammogram in Barcelona. J Cancer Educ. 27(4): 780–5. 2012. 10.1007/s13187-012-0349-9. KQ1E2b, KQ2E2b, KQ3E2b22477233
120 Etzioni, R, Gulati, R, . Influence of study features and methods on overdiagnosis estimates in breast and prostate cancer screening. Ann Intern Med. 158(11): 831–8. 2013. 10.7326/0003-4819-158-11-201306040-00008. KQ1E7a, KQ2E7a, KQ3E7a23732716
121 Falk, RS, Hofvind, S, . Overdiagnosis among women attending a population-based mammography screening program. Int J Cancer. 133(3): 705–12. 2013. 10.1002/ijc.28052. KQ1E3, KQ2E3, KQ3E323355313
122 Fann, JC, Chang, KJ, . Impact of Overdiagnosis on Long-Term Breast Cancer Survival. Cancers (Basel). 11(3): 07. 2019. 10.3390/cancers11030325. KQ1E7h, KQ2E7h, KQ3E7h
123 Field, LR, Wilson, TE, . Mammographic screening in women more than 64 years old: a comparison of 1- and 2-year intervals. AJR Am J Roentgenol. 170(4): 961–5. 1998. 10.2214/ajr.170.4.9530044. KQ1E4, KQ2E11, KQ3E49530044
124 Fielder, HM, Warwick, J, . A case-control study to estimate the impact on breast cancer death of the breast screening programme in Wales. J Med Screen. 11(4): 194–8. 2004. 10.1258/0969141042467304. KQ1E7, KQ2E7, KQ3E2b15563774
125 Fitzpatrick, P, Fleming, P, . False-positive mammographic screening: factors influencing re-attendance over a decade of screening. J Med Screen. 18(1): 30–3. 2011. 10.1258/jms.2010.010104. KQ1E3, KQ2E3, KQ3E321536814
126 Freer, PE, Riegert, J, . Clinical implementation of synthesized mammography with digital breast tomosynthesis in a routine clinical practice. Breast Cancer Res Treat. 166(2): 501–509. 2017. 10.1007/s10549-017-4431-1. KQ1E5, KQ2E5, KQ3E7j28780702
127 Friedewald, SM, Grimm, LJ. Digital Breast Tomosynthesis and Detection of Interval Invasive and Advanced Breast Cancers. JAMA. 327(22): 2198–2200. 2022. 10.1001/jama.2021.25018. KQ1E7a, KQ2E7a, KQ3E7a35699719
128 Friedewald, SM, Rafferty, EA, . Breast cancer screening using tomosynthesis in combination with digital mammography. JAMA. 311(24): 2499–507. 2014. 10.1001/JAMA.2014.6095. KQ1E7c, KQ2E7c, KQ3E7c25058084
129 Fujii, MH, Herschorn, SD, . Detection Rates for Benign and Malignant Diagnoses on Breast Cancer Screening With Digital Breast Tomosynthesis in a Statewide Mammography Registry Study. AJR Am J Roentgenol. 212(3): 706–711. 2019. 10.2214/AJR.18.20255. KQ1E7, KQ2E7, KQ3E7j30673339
130 Gabe, R, Tryggvadóttir, L, . A case-control study to estimate the impact of the Icelandic population-based mammography screening program on breast cancer death. Acta Radiol. 48(9): 948–55. 2007. 10.1080/02841850701501725. KQ1E3, KQ2E3, KQ3E318080359
131 Garayoa, J, Chevalier, M, . Diagnostic value of the stand-alone synthetic image in digital breast tomosynthesis examinations. Eur Radiol. 28(2): 565–572. 2018. 10.1007/s00330-017-4991-9. KQ1E7d, KQ2E7d, KQ3E7d28812190
132 García Fernández, A, Chabrera, C, . Mortality and recurrence patterns of breast cancer patients diagnosed under a screening programme versus comparable non-screened breast cancer patients from the same population: analytical survey from 2002 to 2012. Tumour Biol. 35(3): 1945–53. 2014. 10.1007/s13277-013-1260-7. KQ1E3a, KQ2E3a, KQ3E3a24114015
133 Gard, CC, Aiello Bowles, EJ, . Misclassification of Breast Imaging Reporting and Data System (BI-RADS) Mammographic Density and Implications for Breast Density Reporting Legislation. Breast J. 21(5): 481–9. 2015. 10.1111/tbj.12443. KQ1E4, KQ2E4, KQ3E426133090
134 Gastounioti, A, McCarthy, AM, . Effect of Mammographic Screening Modality on Breast Density Assessment: Digital Mammography versus Digital Breast Tomosynthesis. Radiology. 291(2): 320–327. 2019. 10.1148/radiol.2019181740. KQ1E7c, KQ2E7c, KQ3E7c30888933
135 Gatta, G, Cappabianca, S, . Second-Generation 3D Automated Breast Ultrasonography (Prone ABUS) for Dense Breast Cancer Screening Integrated to Mammography: Effectiveness, Performance and Detection Rates. J Pers Med. 11(9): 31. 2021. 10.3390/jpm11090875. KQ1E7d, KQ2E7d, KQ3E7g33419057
136 Geiger-Gritsch, S, Daniaux, M, . Performance of 4 years of population-based mammography screening for breast cancer combined with ultrasound in Tyrol / Austria. Wien Klin Wochenschr. 130(3–4): 92–99. 2018. 10.1007/s00508-017-1293-9. KQ1E2b, KQ2E2b, KQ3E2b29209825
137 Gennaro, G, Hendrick, RE, . Performance comparison of single-view digital breast tomosynthesis plus single-view digital mammography with two-view digital mammography. Eur Radiol. 23(3): 664–72. 2013. 10.1007/s00330-012-2649-1. KQ1E1b, KQ2E1b, KQ3E1b22976919
138 Gibson, CJ, Weiss, J, . False-positive mammography and depressed mood in a screening population: findings from the New Hampshire Mammography Network. J Public Health. 31(4): 554–60. 2009. 10.1093/pubmed/fdp064. KQ1E3, KQ2E3, KQ3E3
139 Giess, CS, Pourjabbar, S, . Comparing Diagnostic Performance of Digital Breast Tomosynthesis and Full-Field Digital Mammography in a Hybrid Screening Environment. AJR Am J Roentgenol. 209(4): 929–934. 2017. 10.2214/AJR.17.17983. KQ1E4, KQ2E5, KQ3E7j28639832
140 Giger, ML, Inciardi, MF, . Automated Breast Ultrasound in Breast Cancer Screening of Women With Dense Breasts: Reader Study of Mammography-Negative and Mammography-Positive Cancers. AJR Am J Roentgenol. 206(6): 1341–50. 2016. 10.2214/ajr.15.15367. KQ1E7d, KQ2E7d, KQ3E7d27043979
141 Gilbert, FJ, Tucker, L, . Accuracy of Digital Breast Tomosynthesis for Depicting Breast Cancer Subgroups in a UK Retrospective Reading Study (TOMMY Trial). Radiology. 277(3): 697–706. 2015. 10.1148/radiol.2015142566. KQ1E1b, KQ2E1b, KQ3E1b26176654
142 Gilbert, FJ, Tucker, L, . The TOMMY trial: a comparison of TOMosynthesis with digital MammographY in the UK NHS Breast Screening Programme--a multicentre retrospective reading study comparing the diagnostic performance of digital breast tomosynthesis and digital mammography with digital mammography alone. Health Technol Assess. 19(4): i–xxv, 1–136. 2015. 10.3310/hta19040. KQ1E1b, KQ2E1b, KQ3E1b
143 Giorgi Rossi, P, Djuric, O, . Validation of a new fully automated software for 2D digital mammographic breast density evaluation in predicting breast cancer risk. Sci Rep. 11(1): 19884. 2021. 10.1038/s41598-021-99433-3. KQ1E3, KQ2E3, KQ3E334615978
144 Girardi, V, Tonegutti, M, . Breast ultrasound in 22,131 asymptomatic women with negative mammography. Breast. 22(5): 806–9. 2013. 10.1016/j.breast.2013.02.010. KQ1E3, KQ2E3, KQ3E323558244
145 Giuliano, V, Giuliano, C. Improved breast cancer detection in asymptomatic women using 3D-automated breast ultrasound in mammographically dense breasts. Clin Imaging. 37(3): 480–6. 2013. 10.1016/j.clinimag.2012.09.018. KQ1E7c, KQ2E7c, KQ3E7c23116728
146 Gong, AJ, Nguyen, DL, . Comparison of Outcomes for One-View Asymmetries Recalled From Digital Breast Tomosynthesis Versus Full-Field Digital Mammography Screening Examinations. AJR Am J Roentgenol. 15: 15. 2022. 10.2214/ajr.22.27820. KQ1E4, KQ2E4, KQ3E7j
147 Gorini, G, Zappa, M, . Breast cancer mortality trends in two areas of the province of Florence, Italy, where screening programmes started in the 1970s and 1990s. Br J Cancer. 90(9): 1780–3. 2004. 10.1038/sj.bjc.6601744. KQ1E2b, KQ2E2b, KQ3E2b15150601
148 Gøtzsche, PC, Jørgensen, KJ. Screening for breast cancer with mammography. Cochrane Database Syst Rev. 2013(6): Cd001877. 2013. 10.1002/14651858.CD001877.pub5. KQ1E7a, KQ2E7a, KQ3E7a23737396
149 Greenberg, JS, Javitt, MC, . Clinical performance metrics of 3D digital breast tomosynthesis compared with 2D digital mammography for breast cancer screening in community practice. AJR Am J Roentgenol. 203(3): 687–93. 2014. 10.2214/AJR.14.12642. KQ1E5, KQ2E5, KQ3E7j24918774
150 Gunsoy, NB, Garcia-Closas, M, . Estimating breast cancer mortality reduction and overdiagnosis due to screening for different strategies in the United Kingdom. Br J Cancer. 110(10): 2412–9. 2014. 10.1038/bjc.2014.206. KQ1E7h, KQ2E7h, KQ3E7h24762956
151 Gurando, AV, Babkina, TM, . Digital Breast Tomosynthesis and Full-Field Digital Mammography in Breast Cancer Detection Associated with Four Asymmetry Types. Wiadomosci Lekarskie. 74(4): 842–848. 2021. KQ1E1b, KQ2E1b, KQ3E1b34155990
152 Haas, BM, Kalra, V, . Comparison of tomosynthesis plus digital mammography and digital mammography alone for breast cancer screening. Radiology. 269(3): 694–700. 2013. 10.1148/radiol.13130307. KQ1E5, KQ2E5, KQ3E7j23901124
153 Haas, JS, Hill, DA, . Disparities in the use of screening magnetic resonance imaging of the breast in community practice by race, ethnicity, and socioeconomic status. Cancer. 122(4): 611–7. 2016. 10.1002/cncr.29805. KQ1E4, KQ2E4, KQ3E426709819
154 Habbema, JD, van Oortmarssen, GJ, . Age-specific reduction in breast cancer mortality by screening: an analysis of the results of the Health Insurance Plan of Greater New York study. J Natl Cancer Inst. 77(2): 317–20. 1986. KQ1E3, KQ2E3, KQ3E33461193
155 Hafslund, B, Espehaug, B, . Effects of false-positive results in a breast screening program on anxiety, depression and health-related quality of life. Cancer Nurs. 35(5): E26–34. 2012. 10.1097/NCC.0b013e3182341ddb. KQ1E4, KQ2E4, KQ3E322067696
156 Hafslund, B, Nortvedt, MW. Mammography screening from the perspective of quality of life: a review of the literature. Scand J Caring Sci. 23(3): 539–48. 2009. 10.1111/j.1471-6712.2008.00634.x. KQ1E7a, KQ2E7a, KQ3E7a19170959
157 Hakama, M, Pukkala, E, . Effectiveness of the public health policy for breast cancer screening in Finland: population based cohort study. BMJ. 314(7084): 864–7. 1997. 10.1136/bmj.314.7084.864. KQ1E3, KQ2E3, KQ3E39093096
158 Hanley, JA, Hannigan, A, . Mortality reductions due to mammography screening: Contemporary population-based data. PLoS ONE. 12(12): e0188947. 2017. 10.1371/journal.pone.0188947. KQ1E3, KQ2E3, KQ3E329261685
159 Harris, R, Yeatts, J, . Breast cancer screening for women ages 50 to 69 years a systematic review of observational evidence. Prev Med. 53(3): 108–14. 2011. 10.1016/j.ypmed.2011.07.004. KQ1E3, KQ2E3, KQ3E321820465
160 Harvey, JA, Gard, CC, . Reported mammographic density: film-screen versus digital acquisition. Radiology. 266(3): 752–8. 2013. 10.1148/radiol.12120221. KQ1E4, KQ2E4, KQ3E423249570
161 Haukka, J, Byrnes, G, . Trends in breast cancer mortality in Sweden before and after implementation of mammography screening. PLoS One. 6(9): e22422. 2011. 10.1371/journal.pone.0022422. KQ1E7h, KQ2E7h, KQ3E7h21966354
162 Heleno, B, Siersma, VD, . Diagnostic invasiveness and psychosocial consequences of false-positive mammography. Ann Fam Med. 13(3): 242–9. 2015. 10.1370/afm.1762. KQ1E1b, KQ2E1b, KQ3E1b25964402
163 Hellquist, BN, Czene, K, . Effectiveness of population-based service screening with mammography for women ages 40 to 49 years with a high or low risk of breast cancer: socioeconomic status, parity, and age at birth of first child. Cancer. 121(2): 251–8. 2015. 10.1002/cncr.29011. KQ1E3, KQ2E3, KQ3E325242087
164 Hellquist, BN, Duffy, SW, . Effectiveness of population-based service screening with mammography for women ages 40 to 49 years: evaluation of the Swedish Mammography Screening in Young Women (SCRY) cohort. Cancer. 117(4): 714–22. 2011. 10.1002/cncr.25650. KQ1E2b, KQ2E2b, KQ3E2b20882563
165 Hellquist, BN, Duffy, SW, . Overdiagnosis in the population-based service screening programme with mammography for women aged 40 to 49 years in Sweden. J Med Screen. 19(1): 14–9. 2012. 10.1258/jms.2012.011104. KQ1E2b, KQ2E2b, KQ3E2b
166 Hendrick, RE. Radiation doses and cancer risks from breast imaging studies. Radiology. 257(1): 246–53. 2010. 10.1148/radiol.10100570. KQ1E7, KQ2E7, KQ3E720736332
167 Heywang-Kobrunner, S, Jaensch, A, . Value of Digital Breast Tomosynthesis versus Additional Views for the Assessment of Screen-Detected Abnormalities - a First Analysis. Breast Care. 12(2): 92–97. 2017. 10.1159/000456649. KQ1E1b, KQ2E1b, KQ3E1b28559765
168 Hislop, TG, Harris, SR, . Satisfaction and anxiety for women during investigation of an abnormal screening mammogram. Breast Cancer Res Treat. 76(3): 245–54. 2002. 10.1023/a:1020820103126. KQ1E1b, KQ2E1b, KQ3E1b12462385
169 Hofvind, S, Skaane, P. Stage distribution of breast cancer diagnosed before and after implementation of population-based mammographic screening. Rofo. 184(5): 437–42. 2012. 10.1055/s-0031-1299352. KQ1E2b, KQ2E2b, KQ3E2b22426937
170 Hofvind, S, Ursin, G, . Breast cancer mortality in participants of the Norwegian Breast Cancer Screening Program. Cancer. 119(17): 3106–12. 2013. 10.1002/cncr.28174. KQ1E2b, KQ2E2b, KQ3E2b23720226
171 Hofvind, S, Wang, H, . Do the results of the process indicators in the Norwegian Breast Cancer Screening Program predict future mortality reduction from breast cancer? Acta Oncol. 43(5): 467–73. 2004. 10.1080/02841860410034315. KQ1E3, KQ2E3, KQ3E315360051
172 Hong, S, Song, SY, . Effect of Digital Mammography for Breast Cancer Screening: A Comparative Study of More than 8 Million Korean Women. Radiology. 294(2): 247–255. 2020. 10.1148/radiol.2019190951. KQ1E2b, KQ2E2b, KQ3E2b31793847
173 Honig, EL, Mullen, LA, . Factors Impacting False Positive Recall in Screening Mammography. Acad Radiol. 26(11): 1505–1512. 2019. 10.1016/j.acra.2019.01.020. KQ1E5, KQ2E5, KQ3E7j30772138
174 Hooley, RJ, Greenberg, KL, . Screening US in patients with mammographically dense breasts: initial experience with Connecticut Public Act 09-41. Radiology. 265(1): 59–69. 2012. 10.1148/radiol.12120621. KQ1E3, KQ2E3, KQ3E322723501
175 Houssami, N, Bernardi, D, . Breast cancer detection using single-reading of breast tomosynthesis (3D-mammography) compared to double-reading of 2D-mammography: Evidence from a population-based trial. Cancer Epidemiol. 47: 94–99. 2017. 10.1016/j.canep.2017.01.008. KQ1E7d, KQ2E7d, KQ3E7d28192742
176 Houssami, N, Bernardi, D, . Interval breast cancers in the ‘screening with tomosynthesis or standard mammography’ (STORM) population-based trial. Breast. 38: 150–153. 2018. 10.1016/j.breast.2018.01.002. KQ1E4, KQ2E11, KQ3E429328943
177 Houssami, N, Hofvind, S, . Interval breast cancer rates for digital breast tomosynthesis versus digital mammography population screening: An individual participant data meta-analysis. E Clinical Medicine. 34: 100804. 2021. 10.1016/j.eclinm.2021.100804. KQ1E7, KQ2E7, KQ3E7
178 Houssami, N, Lockie, D, . Pilot trial of digital breast tomosynthesis (3D mammography) for population-based screening in BreastScreen Victoria. Med J Aust. 211(8): 357–362. 2019. 10.5694/mja2.50320. KQ1E5, KQ2E5, KQ3E7j31448816
179 Houssami, N, Macaskill, P, . Breast screening using 2D-mammography or integrating digital breast tomosynthesis (3D-mammography) for single-reading or double-reading--evidence to guide future screening strategies. Eur J Cancer. 50(10): 1799–1807. 2014. 10.1016/j.ejca.2014.03.017. KQ1E7d, KQ2E7d, KQ3E7d24746887
180 Houssami, N, Macaskill, P, . Breast screening using 2D-mammography or integrating digital breast tomosynthesis (3D-mammography) for single-reading or double-reading--evidence to guide future screening strategies. Eur J Cancer. 50(10): 1799–1807. 2014. 10.1016/j.ejca.2014.03.017. KQ1E7d, KQ2E7d, KQ3E7d24746887
181 Hovda, T, Brandal, SHB, . Screening outcome for consecutive examinations with digital breast tomosynthesis versus standard digital mammography in a population-based screening program. Eur Radiol. 29(12): 6991–6999. 2019. 10.1007/s00330-019-06264-y. KQ1E4, KQ2E7c, KQ3E7c31187221
182 Huang, C, Fann, C, . A Population-Based Cross-Over Randomized Controlled Trial of Breast Cancer Screening with Alternate Mammography and Ultrasound for Women Aged 40 to 49 Years in Taiwan. Cancer Res. 69(24 Supplement). 2009. 10.1158/0008-5472.SABCS-09-73. KQ1E10, KQ2E10, KQ3E10
183 Hunt, KA, Rosen, EL, . Outcome analysis for women undergoing annual versus biennial screening mammography: a review of 24,211 examinations. AJR Am J Roentgenol. 173(2): 285–9. 1999. 10.2214/ajr.173.2.10430120. KQ1E4, KQ2E11, KQ3E1110430120
184 Hunter, SA, Morris, C, . Digital Breast Tomosynthesis: Cost-Effectiveness of Using Private and Medicare Insurance in Community-Based Health Care Facilities. AJR Am J Roentgenol. 208(5): 1171–1175. 2017. 10.2214/ajr.16.16987. KQ1E4, KQ2E4, KQ3E7j28177646
185 Huzarski, T, Gorecka-Szyld, B, . Screening with magnetic resonance imaging, mammography and ultrasound in women at average and intermediate risk of breast cancer. Hered Cancer Clin Pract. 15:4. 2017. 10.1186/s13053-017-0064-y. KQ1E7d, KQ2E7d, KQ3E7d28265306
186 Hwang, JY, Han, BK, . Screening Ultrasound in Women with Negative Mammography: Outcome Analysis. Yonsei Med J. 56(5): 1352–8. 2015. 10.3349/ymj.2015.56.5.1352. KQ1E3, KQ2E3, KQ3E326256979
187 Jacklyn, G, McGeechan, K, . Trends in stage-specific breast cancer incidence in New South Wales, Australia: insights into the effects of 25 years of screening mammography. Breast Cancer Res Treat. 166(3): 843–854. 2017. 10.1007/s10549-017-4443-x. KQ1E2b, KQ2E2b, KQ3E2b28822001
188 Jensen, AR, Garne, JP, . Stage and survival in breast cancer patients in screened and non-screened Danish and Swedish populations. Acta Oncol. 42(7): 701–9. 2003. 10.1080/02841860310010556. KQ1E2b, KQ2E2b, KQ3E2b14690155
189 Jeter, LK, Morello, R, . Impact of Launching A High-Risk Breast Cancer Screening Program Using the Tyrer-Cuzick Model. Am Surg. 3134820956922. 2020. 10.1177/0003134820956922. KQ1E1a, KQ2E1a, KQ3E1a
190 Jørgensen, KJ, Zahl, PH, . Breast cancer mortality in organised mammography screening in Denmark: comparative study. BMJ. 340: c1241. 2010. 10.1136/bmj.c1241. KQ1E3, KQ2E3, KQ3E320332505
191 Jørgensen, KJ, Zahl, PH, . Overdiagnosis in organised mammography screening in Denmark. A comparative study. BMC Womens Health. 9: 36. 2009. 10.1186/1472-6874-9-36. KQ1E3, KQ2E3, KQ3E320028513
192 Kalager, M, Adami, HO, . Overdiagnosis of invasive breast cancer due to mammography screening: results from the Norwegian screening program. Ann Intern Med. 156(7): 491–9. 2012. 10.7326/0003-4819-156-7-201204030-00005. KQ1E7h, KQ2E7h, KQ3E7h22473436
193 Kalager, M, Zelen, M, . Effect of screening mammography on breast-cancer mortality in Norway. N Engl J Med. 363(13): 1203–10. 2010. 10.1056/NEJMoa1000727. KQ1E2b, KQ2E2b, KQ3E2b20860502
194 Kamal, Rasha, Mansour, Sahar, . Detection and diagnosis of breast lesions: Performance evaluation of digital breast tomosynthesis and magnetic resonance mammography. The Egyptian Journal of Radiology and Nuclear Medicine. 47(3): 1159–1172. 2016. 10.1016/j.ejrnm.2016.06.008. KQ1E7d, KQ2E7d, KQ3E7d
195 Kang, E, Lee, EJ, . Reliability of Computer-Assisted Breast Density Estimation: Comparison of Interactive Thresholding, Semiautomated, and Fully Automated Methods. AJR Am J Roentgenol. 207(1): 126–34. 2016. 10.2214/ajr.15.15469. KQ1E4, KQ2E4, KQ3E427187523
196 Kaplan, SS. Clinical utility of bilateral whole-breast US in the evaluation of women with dense breast tissue. Radiology. 221(3): 641–9. 2001. 10.1148/radiol.2213010364. KQ1E7d, KQ2E7d, KQ3E7d11719658
197 Karzai, S, Port, E, . Impact of Screening Mammography on Treatment in Young Women Diagnosed with Breast Cancer. Ann Surg Oncol. 01: 01. 2022. 10.1245/s10434-022-11581-6. KQ1E3, KQ2E3, KQ3E3
198 Kelly, KM, Dean, J, . Breast cancer detection using automated whole breast ultrasound and mammography in radiographically dense breasts. Eur Radiol. 20(3): 734–42. 2010. 10.1007/s00330-009-1588-y. KQ1E7d, KQ2E7d, KQ3E7d19727744
199 Kemp Jacobsen, K, Abraham, L, . Comparison of cumulative false-positive risk of screening mammography in the United States and Denmark. Cancer Epidemiol. 39(4): 656–63. 2015. 10.1016/j.canep.2015.05.004. KQ1E4, KQ2E4, KQ3E1126013768
200 Keyzer-Dekker, CM, De Vries, J, . Anxiety after an abnormal screening mammogram is a serious problem. Breast. 21(1): 83–8. 2012. 10.1016/j.breast.2011.08.137. KQ1E2b, KQ2E2b, KQ3E2b21924905
201 Kim, G, Mercaldo, S, . Impact of digital breast tomosynthesis (DBT) on finding types leading to true-positive and false-positive examinations. Clin Imaging. 71:155–159. 2021. 10.1016/j.clinimag.2020.10.046. KQ1E7c, KQ2E7c, KQ3E7c33276203
202 Kim, G, Mikhael, PG, . Ductal carcinoma in situ on digital mammography versus digital breast tomosynthesis: rates and predictors of pathologic upgrade. Eur Radiol. 30(11): 6089–6098. 2020. 10.1007/s00330-020-07021-2. KQ1E7c, KQ2E7c, KQ3E7c32591884
203 Kim, Wh, Chang, Jm, . Diagnostic performance of tomosynthesis and breast ultrasonography in women with dense breasts: a prospective comparison study. Breast Cancer Res Treat. 162(1): 85–94. 2017. 10.1007/s10549-017-4105-z. KQ1E7d, KQ2E7d, KQ3E7d28083822
204 Kim, WH, Chang, JM, . Impact of prior mammograms on combined reading of digital mammography and digital breast tomosynthesis. Acta Radiol. 58(2): 148–155. 2017. 10.1177/0284185116647211. KQ1E7d, KQ2E7d, KQ3E7d27178032
205 Klevos, GA, Collado-Mesa, F, . Utility of supplemental screening with breast ultrasound in asymptomatic women with dense breast tissue who are not at high risk for breast cancer. Indian Journal of Radiology & Imaging. 27(1): 52–58. 2017. 10.4103/0971-3026.202962. KQ1E3, KQ2E3, KQ3E328515586
206 Klompenhouwer, EG, Duijm, LE, . Re-attendance at biennial screening mammography following a repeated false positive recall. Breast Cancer Res Treat. 145(2): 429–37. 2014. 10.1007/s10549-014-2959-x. KQ1E2b, KQ2E2b, KQ3E2b24748569
207 Korpraphong, P, Limsuwarn, P, . Improving breast cancer detection using ultrasonography in asymptomatic women with non-fatty breast density. Acta Radiol. 55(8): 903–8. 2014. 10.1177/0284185113507711. KQ1E7d, KQ2E7d, KQ3E7d24103915
208 Kriege, M, Brekelmans, CT, . Factors affecting sensitivity and specificity of screening mammography and MRI in women with an inherited risk for breast cancer. Breast Cancer Res Treat. 100(1): 109–19. 2006. 10.1007/s10549-006-9230-z. KQ1E1a, KQ2E1a, KQ3E1a16791481
209 Kuhl, CK, Schrading, S, . Abbreviated breast magnetic resonance imaging (MRI): first postcontrast subtracted images and maximum-intensity projection-a novel approach to breast cancer screening with MRI. J Clin Oncol. 32(22): 2304–10. 2014. 10.1200/jco.2013.52.5386. KQ1E7d, KQ2E7d, KQ3E7d24958821
210 Kuhl, CK, Strobel, K, . Supplemental Breast MR Imaging Screening of Women with Average Risk of Breast Cancer. Radiology. 283(2): 361–370. 2017. 10.1148/radiol.2016161444. KQ1E7d, KQ2E7d, KQ3E7d28221097
211 Lai, YC, Ray, KM, . Microcalcifications Detected at Screening Mammography: Synthetic Mammography and Digital Breast Tomosynthesis versus Digital Mammography. Radiology. 289(3): 630–638. 2018. 10.1148/radiol.2018181180. KQ1E1b, KQ2E1b, KQ3E1b30277445
212 Lampic, C, Thurfjell, E, . The influence of a false-positive mammogram on a woman’s subsequent behaviour for detecting breast cancer. Eur J Cancer. 39(12): 1730–7. 2003. 10.1016/s0959-8049(02)00451-3. KQ1E2b, KQ2E2b, KQ3E2b12888368
213 Lee, SH, Yi, A, . Supplemental Screening Breast US in Women with Negative Mammographic Findings: Effect of Routine Axillary Scanning. Radiology. 286(3): 830–837. 2018. 10.1148/radiol.2017171218. KQ1E3, KQ2E3, KQ3E329083988
214 Lehman, CD, Arao, RF, . National Performance Benchmarks for Modern Screening Digital Mammography: Update from the Breast Cancer Surveillance Consortium. Radiology. 283(1): 49–58. 2017. 10.1148/radiol.2016161174. KQ1E3, KQ2E3, KQ3E327918707
215 Leong, LC, Gogna, A, . Supplementary breast ultrasound screening in Asian women with negative but dense mammograms-a pilot study. Ann Acad Med Singap. 41(10): 432–9. 2012. KQ1E7d, KQ2E7d, KQ3E7d23138139
216 Li, FY, Hollingsworth, A, . Feasibility of Breast MRI as the Primary Imaging Modality in a Large Asian Cohort. Cureus. 13(5): e15095. 2021. 10.7759/cureus.15095. KQ1E3, KQ2E3, KQ3E334159005
217 Lo, G, Scaranelo, AM, . Evaluation of the Utility of Screening Mammography for High-Risk Women Undergoing Screening Breast MR Imaging. Radiology. 285(1): 36–43. 2017. 10.1148/radiol.2017161103. KQ1E7d, KQ2E7d, KQ3E7d28586291
218 Lourenco, AP, Barry-Brooks, M, . Changes in recall type and patient treatment following implementation of screening digital breast tomosynthesis. Radiology. 274(2): 337–42. 2015. 10.1148/radiol.14140317. KQ1E7c, KQ2E7c, KQ3E7c25247407
219 Lowe, JB, Balanda, KP, . Psychologic distress in women with abnormal findings in mass mammography screening. Cancer. 85(5): 1114–8. 1999. 10.1002/(sici)1097-0142(19990301)85:5<1114::aid-cncr15>3.0.co;2-y. KQ1E4, KQ2E4, KQ3E310091796
220 Lowry, KP, Coley, RY, . Screening Performance of Digital Breast Tomosynthesis vs Digital Mammography in Community Practice by Patient Age, Screening Round, and Breast Density. JAMA Netw Open. 3(7): e2011792. 2020. 10.1001/JAMAnetworkopen.2020.11792. KQ1E7, KQ2E5, KQ3E7j32721031
221 Malik, B, Iuanow, E, . An Exploratory Multi-reader, Multi-case Study Comparing Transmission Ultrasound to Mammography on Recall Rates and Detection Rates for Breast Cancer Lesions. Acad Radiol. 03: 03. 2020. 10.1016/j.acra.2020.11.011. KQ1E7e, KQ2E7e, KQ3E7e
222 Mao, Z, Nystrom, L, . Breast cancer screening with mammography in women aged 40-49 years: Impact of length of screening interval on effectiveness of the program. J Med Screen. 28(2): 200–206. 2021. 10.1177/0969141320918283. KQ1E7h, KQ2E7h, KQ3E7h32404033
223 Mao, Z, Nystrom, L, . Effectiveness of Population-Based Service Screening with Mammography for Women Aged 70-74 Years in Sweden. Cancer Epidemiol Biomarkers Prevent. 29(11): 2149–2156. 2020. 10.1158/1055-9965.EPI-20-0523. KQ1E7c, KQ2E7c, KQ3E7c
224 Mariscotti, G, Durando, M, . Digital breast tomosynthesis as an adjunct to digital mammography for detecting and characterising invasive lobular cancers: a multi-reader study. Clin Radiol. 71(9): 889–95. 2016. 10.1016/j.crad.2016.04.004. KQ1E1b, KQ2E1b, KQ3E1b27210245
225 Maxwell, AJ, Beattie, C, . The effect of false positive breast screening examinations on subsequent attendance: retrospective cohort study. J Med Screen. 20(2): 91–8. 2013. 10.1177/0969141313499147. KQ1E2b, KQ2E2b, KQ3E2b24009091
226 Maxwell, AJ, Michell, M, . A randomised trial of screening with digital breast tomosynthesis plus conventional digital 2D mammography versus 2D mammography alone in younger higher risk women. Eur J Radiol. 94: 133–139. 2017. 10.1016/j.ejrad.2017.06.018. KQ1E1, KQ2E1, KQ3E128716454
227 McCann, J, Stockton, D, . Impact of false-positive mammography on subsequent screening attendance and risk of cancer. Breast Cancer Res. 4(5): R11. 2002. 10.1186/bcr455. KQ1E3, KQ2E3, KQ3E312223128
228 McCarthy, AM, Kontos, D, . Screening outcomes following implementation of digital breast tomosynthesis in a general-population screening program. J Natl Cancer Inst. 106(11). 2014. 10.1093/jnci/dju316. KQ1E7c, KQ2E7c, KQ3E7c
229 McDonald, ES, McCarthy, AM, . Baseline Screening Mammography: Performance of Full-Field Digital Mammography Versus Digital Breast Tomosynthesis. AJR Am J Roentgenol. 205(5): 1143–8. 2015. 10.2214/AJR.15.14406. KQ1E7c, KQ2E7c, KQ3E7c26496565
230 McDonald, ES, McCarthy, AM, . BI-RADS Category 3 Comparison: Probably Benign Category after Recall from Screening before and after Implementation of Digital Breast Tomosynthesis. Radiology. 285(3): 778–787. 2017. 10.1148/radiol.2017162837. KQ1E7c, KQ2E7c, KQ3E7c28715278
231 McDonald, ES, Oustimov, A, . Effectiveness of Digital Breast Tomosynthesis Compared With Digital Mammography: Outcomes Analysis From 3 Years of Breast Cancer Screening. JAMA Oncol. 2(6): 737–43. 2016. 10.1001/JAMAoncol.2015.5536. KQ1E7c, KQ2E7c, KQ3E7c26893205
232 Meldrum, P, Turnbull, D, . Tailored written invitations for second round breast cancer screening: a randomised controlled trial. J Med Screen. 1(4): 245–8. 1994. 10.1177/096914139400100412. KQ1E2b, KQ2E2b, KQ3E2b8790529
233 Mesurolle, B, El Khoury, M, . Is there any added value to substitute the 2D digital MLO projection for a MLO tomosynthesis projection and its synthetic view when a 2D standard digital mammography is used in a one-stop-shop immediate reading mammography screening? Eur Radiol. 28: 28. 2021. 10.1007/s00330-021-07999-3. KQ1E7c, KQ2E7c, KQ3E7c
234 Miller, AB, Wall, C, . Twenty five year follow-up for breast cancer incidence and mortality of the Canadian National Breast Screening Study: randomised screening trial. BMJ. 348: g366. 2014. 10.1136/bmj.g366. KQ1E3, KQ2E3, KQ3E324519768
235 Miller, D, Livingstone, V, . Interventions for relieving the pain and discomfort of screening mammography. Cochrane Database Syst Rev. (1): Cd002942. 2008. 10.1002/14651858.CD002942.pub2. KQ1E7a, KQ2E7a, KQ3E7a18254010
236 Miltenburg, GA, Peeters, PH, . Seventeen-year evaluation of breast cancer screening: the DOM project, The Netherlands. Diagnostisch Onderzoek (investigation) Mammacarcinoom. Br J Cancer. 78(7): 962–5. 1998. 10.1038/bjc.1998.609. KQ1E3, KQ2E3, KQ3E39764591
237 Moger, TA, Swanson, JO, . Cost differences between digital tomosynthesis and standard digital mammography in a breast cancer screening programme: results from the To-Be trial in Norway. Eur J Health Econ. 20(8): 1261–1269. 2019. 10.1007/s10198-019-01094-7. KQ1E4, KQ2E4, KQ3E431399773
238 Mook, S, Van ’t Veer, LJ, . Independent prognostic value of screen detection in invasive breast cancer. J Natl Cancer Inst. 103(7): 585–97. 2011. 10.1093/jnci/djr043. KQ1E3, KQ2E3, KQ3E321350218
239 Moon, HJ, Jung, I, . Comparison of Cancer Yields and Diagnostic Performance of Screening Mammography vs. Supplemental Screening Ultrasound in 4394 Women with Average Risk for Breast Cancer. Ultraschall Med. 36(3): 255–63. 2015. 10.1055/s-0034-1366288. KQ1E7i, KQ2E7i, KQ3E7i24764212
240 Moorman, SEH, Pujara, AC, . Annual Screening Mammography Associated With Lower Stage Breast Cancer Compared With Biennial Screening. AJR Am J Roentgenol. 217(1): 40–47. 2021. 10.2214/AJR.20.23467. KQ1E4, KQ2E11, KQ3E433955776
241 Morrell, S, Barratt, A, . Estimates of overdiagnosis of invasive breast cancer associated with screening mammography. Cancer Causes Control. 21(2): 275–82. 2010. 10.1007/s10552-009-9459-z. KQ1E7h, KQ2E7h, KQ3E7h19894130
242 Moss, S, Thomas, I, . Randomised controlled trial of mammographic screening in women from age 40: results of screening in the first 10 years. Br J Cancer. 92(5): 949–54. 2005. 10.1038/sj.bjc.6602396. KQ1E3, KQ2E3, KQ3E315726102
243 Moss, S. Overdiagnosis and overtreatment of breast cancer: overdiagnosis in randomised controlled trials of breast cancer screening. Breast Cancer Res. 7(5): 230–4. 2005. 10.1186/bcr1314. KQ1E7a, KQ2E7a, KQ3E7a16168145
244 Moss, SM, Cuckle, H, . Effect of mammographic screening from age 40 years on breast cancer mortality at 10 years’ follow-up: a randomised controlled trial. Lancet. 368(9552): 2053–60. 2006. 10.1016/s0140-6736(06)69834-6. KQ1E4, KQ2E4, KQ3E417161727
245 Moss, SM, Nyström, L, . The impact of mammographic screening on breast cancer mortality in Europe: a review of trend studies. J Med Screen. 19 Suppl 1: 26–32. 2012. 10.1258/jms.2012.012079. KQ1E7a, KQ2E7a, KQ3E7a
246 Moss, SM, Wale, C, . Effect of mammographic screening from age 40 years on breast cancer mortality in the UK Age trial at 17 years’ follow-up: a randomised controlled trial. Lancet Oncol. 16(9): 1123–1132. 2015. 10.1016/S1470-2045(15)00128-X. KQ1E1a, KQ2E1a, KQ3E1a26206144
247 Narayan, AK, Visvanathan, K, . Comparative effectiveness of breast MRI and mammography in screening young women with elevated risk of developing breast cancer: a retrospective cohort study. Breast Cancer Res Treat. 158(3): 583–9. 2016. 10.1007/s10549-016-3912-y. KQ1E1a, KQ2E1a, KQ3E1a27444927
248 Narod, SA, Sun, P, . Impact of screening mammography on mortality from breast cancer before age 60 in women 40 to 49 years of age. Current Oncology. 21(5): 217–21. 2014. 10.3747/co.21.2067. KQ1E3, KQ2E3, KQ3E325302030
249 Njor, S, Nyström, L, . Breast cancer mortality in mammographic screening in Europe: a review of incidence-based mortality studies. J Med Screen. 19 Suppl 1: 33–41. 2012. 10.1258/jms.2012.012080. KQ1E7, KQ2E7, KQ3E722972809
250 Njor, SH, Olsen, AH, . Overdiagnosis in screening mammography in Denmark: population based cohort study. BMJ. 346: f1064. 2013. 10.1136/BMJ.f1064. KQ1E3, KQ2E3, KQ3E323444414
251 Noguchi, N, Marinovich, ML, . Evidence from a BreastScreen cohort does not support a longer inter-screen interval in women who have no conventional risk factors for breast cancer. Breast. 62: 16–21. 2022. 10.1016/j.breast.2022.01.015. KQ1E3, KQ2E3, KQ3E335114637
252 Nyström, L, Andersson, I, . Long-term effects of mammography screening: updated overview of the Swedish randomised trials. Lancet. 359(9310): 909–19. 2002. 10.1016/s0140-6736(02)08020-0. KQ1E3, KQ2E3, KQ3E311918907
253 Ohashi, R, Nagao, M, . Improvement in diagnostic performance of breast cancer: comparison between conventional digital mammography alone and conventional mammography plus digital breast tomosynthesis. Breast Cancer. 25(5): 590–596. 2018. 10.1007/s12282-018-0859-3. KQ1E1b, KQ2E1b, KQ3E1b29651638
254 Olivotto, IA, Kan, L, . False positive rate of screening mammography. N Engl J Med. 339(8): 560; author reply 563. 1998. 10.1056/nejm199808203390812. KQ1E7a, KQ2E7a, KQ3E7a
255 Olivotto, IA, Mates, D, . Prognosis, treatment, and recurrence of breast cancer for women attending or not attending the Screening Mammography Program of British Columbia. Breast Cancer Res Treat. 54(1): 73–81. 1999. 10.1023/a:1006152918283. KQ1E2b, KQ2E2b, KQ3E2b10369083
256 Olsen, AH, Agbaje, OF, . Overdiagnosis, sojourn time, and sensitivity in the Copenhagen mammography screening program. Breast J. 12(4): 338–42. 2006. 10.1111/j.1075-122X.2006.00272.x. KQ1E3, KQ2E3, KQ3E316848843
257 Olsen, AH, Njor, SH, . Breast cancer mortality in Copenhagen after introduction of mammography screening: cohort study. BMJ. 330(7485): 220. 2005. 10.1136/BMJ.38313.639236.82. KQ1E2b, KQ2E2b, KQ3E2b15649904
258 Olsson, A, Garne, JP, . Overweight in relation to tumour size and axillary lymph node involvement in postmenopausal breast cancer patients-differences between women invited to vs. not invited to mammography in a randomized screening trial. Cancer Epidemiol. 33(1): 9–15. 2009. 10.1016/j.canep.2009.04.008. KQ1E3, KQ2E3, KQ3E319679041
259 O’Meara, ES, Zhu, W, . Mammographic screening interval in relation to tumor characteristics and false-positive risk by race/ethnicity and age. Cancer. 119(22): 3959–67. 2013. 10.1002/cncr.28310. KQ1E4, KQ2E11, KQ3E1124037812
260 Ong, G, Austoker, J, . Breast screening: adverse psychological consequences one month after placing women on early recall because of a diagnostic uncertainty. A multicentre study. J Med Screen. 4(3): 158–68. 1997. 10.1177/096914139700400309. KQ1E3, KQ2E3, KQ3E39368874
261 Orton, M, Fitzpatrick, R, . Factors affecting women’s response to an invitation to attend for a second breast cancer screening examination. Br J Gen Pract. 41(349): 320–2. 1991. http://www.ncbi.nlm.nih.gov/pmc/articles/pmc1371753/. KQ1E4, KQ2E4, KQ3E41777275
262 Osteras, BH, Martinsen, ACT, . Digital Mammography versus Breast Tomosynthesis: Impact of Breast Density on Diagnostic Performance in Population-based Screening. Radiology. 293(1): 60–68. 2019. 10.1148/radiol.2019190425. KQ1E7d, KQ2E7d, KQ3E7d31407968
263 O’Sullivan, I, Sutton, S, . False positive results do not have a negative effect on reattendance for subsequent breast screening. J Med Screen. 8(3): 145–8. 2001. 10.1136/jms.8.3.145. KQ1E3, KQ2E3, KQ3E311678554
264 Otto, SJ, Fracheboud, J, . Initiation of population-based mammography screening in Dutch municipalities and effect on breast-cancer mortality: a systematic review. Lancet. 361(9367): 1411–7. 2003. 10.1016/s0140-6736(03)13132-7. KQ1E3, KQ2E3, KQ3E312727393
265 Paci, E, Giorgi, D, . Assessment of the early impact of the population-based breast cancer screening programme in Florence (Italy) using mortality and surrogate measures. Eur J Cancer. 38(4): 568–73. 2002. 10.1016/s0959-8049(01)00382-3. KQ1E2b, KQ2E2b, KQ3E2b11872351
266 Paci, E, Mantellini, P, . Tailored Breast Screening Trial (TBST). Epidemiol Prev. 37(4–5): 317–327. 2013. KQ1E8, KQ2E8, KQ3E824293498
267 Paci, E, Miccinesi, G, . Estimate of overdiagnosis of breast cancer due to mammography after adjustment for lead time. A service screening study in Italy. Breast Cancer Res. 8(6): R68. 2006. 10.1186/bcr1625. KQ1E7h, KQ2E7h, KQ3E7h17147789
268 Paci, E, Warwick, J, . Overdiagnosis in screening: is the increase in breast cancer incidence rates a cause for concern? J Med Screen. 11(1): 23–7. 2004. 10.1177/096914130301100106. KQ1E7h, KQ2E7h, KQ3E7h15006110
269 Padia, SA, Freyvogel, M, . False-positive Extra-Mammary Findings in Breast MRI: Another Cause for Concern. Breast Journal. 22(1): 90–5. 2016. 10.1111/tbj.12524. KQ1E1b, KQ2E1b, KQ3E1b26511429
270 Pan, HB, Wong, KF, . Breast cancer screening with digital breast tomosynthesis - 4 year experience and comparison with national data. JCMA. 81(1): 70–80. 2018. 10.1016/j.jcma.2017.05.013. KQ1E4, KQ2E5, KQ3E7c29129518
271 Pang, JX, Newsome, J, . Impact of switching from digital mammography to tomosynthesis plus digital mammography on breast cancer screening in Alberta, Canada. J Med Screen. 9691413211032265. 2021. 10.1177/09691413211032265. KQ1E7c, KQ2E7c, KQ3E7c
272 Park, HL, Chang, J, . Mammography screening and mortality by risk status in the California teachers study. BMC Cancer. 21(1): 1341. 2021. 10.1186/s12885-021-09071-1. KQ1E11, KQ2E4, KQ3E434922473
273 Parris, T, Wakefield, D, . Real world performance of screening breast ultrasound following enactment of Connecticut Bill 458. Breast J. 19(1): 64–70. 2013. 10.1111/tbj.12053. KQ1E7c, KQ2E7c, KQ3E7c23240937
274 Parvinen, I, Heinavaara, S, . Mammography screening in three Finnish residential areas: comprehensive population-based study of breast cancer incidence and incidence-based mortality 1976-2009. Br J Cancer. 112(5): 918–24. 2015. 10.1038/bjc.2014.642. KQ1E7c, KQ2E7c, KQ3E7c25688742
275 Philadelpho, F, Calas, MJG, . Comparison of Automated Breast Ultrasound and Hand-Held Breast Ultrasound in the Screening of Dense Breasts. Rev Bras Ginecol Obstet. 43(3): 190–199. 2021. 10.1055/s-0040-1722156. KQ1E7d, KQ2E7d, KQ3E7d33860502
276 Poplack, SP, Patel, AK, . The impact of adjunctive tomosynthesis on screening mammography outcomes in two widely diverse radiology practices. Breast Journal. 27(1): 13–20. 2021. 10.1111/tbj.14121. KQ1E4, KQ2E5, KQ3E7j33274490
277 Porter, AJ, Evans, EB, . Full-field digital mammography: Is the apparent increased detection of microcalcification leading to over-investigation and over-diagnosis?. J Med Imaging Radiat Oncol. 61(4): 470–475. 2017. 10.1111/1754-9485.12581. KQ1E2b, KQ2E2b, KQ3E2b28185408
278 Powell, JL, Hawley, JR, . Impact of the Addition of Digital Breast Tomosynthesis (DBT) to Standard 2D Digital Screening Mammography on the Rates of Patient Recall, Cancer Detection, and Recommendations for Short-term Follow-up. Acad Radiol. 24(3): 302–307. 2017. 10.1016/j.acra.2016.10.001, KQ1E5, KQ2E5, KQ3E7j27919540
279 Procasco, M. Comparison of Digital Breast Tomosynthesis vs Full-Field Digital Mammography in Recall Rates and Cancer Detection Rates. Radiol Technol. 87(3): 349–51. 2016. KQ1E5, KQ2E5, KQ3E1b26721849
280 Puliti, D, Duffy, SW, . Overdiagnosis in mammographic screening for breast cancer in Europe: a literature review. J Med Screen. 19 Suppl 1: 42–56. 2012. 10.1258/jms.2012.012082. KQ1E7a, KQ2E7a, KQ3E7a
281 Puliti, D, Miccinesi, G, . Effectiveness of service screening: a case-control study to assess breast cancer mortality reduction. Br J Cancer. 99(3): 423–7. 2008. 10.1038/sj.bjc.6604532. KQ1E2b, KQ2E2b, KQ3E2b18665188
282 Puliti, D, Zappa, M, . An estimate of overdiagnosis 15 years after the start of mammographic screening in Florence. Eur J Cancer. 45(18): 3166–71. 2009. 10.1016/j.ejca.2009.06.014. KQ1E2b, KQ2E2b, KQ3E2b19879130
283 Rafferty, EA, Durand, MA, . Breast Cancer Screening Using Tomosynthesis and Digital Mammography in Dense and Nondense Breasts. JAMA. 315(16): 1784–6. 2016. 10.1001/jama.2016.1708. KQ1E4, KQ2E5, KQ3E7j27115381
284 Rafferty, EA, Durand, MA, . Breast Cancer Screening Using Tomosynthesis and Digital Mammography in Dense and Nondense Breasts. JAMA. 315(16): 1784–6. 2016. 10.1001/jama.2016.1708. KQ1E5, KQ2E5, KQ3E7j27115381
285 Rafferty, EA, Park, JM, . Assessing radiologist performance using combined digital mammography and breast tomosynthesis compared with digital mammography alone: results of a multicenter, multireader trial. Radiology. 266(1): 104–13. 2013. 10.1148/radiol.12120674. KQ1E7d, KQ2E7d, KQ3E7d23169790
286 Rafferty, EA, Rose, SL, . Effect of age on breast cancer screening using tomosynthesis in combination with digital mammography. Breast Cancer Res Treat. 164(3): 659–666. 2017. 10.1007/s10549-017-4299-0. KQ1E7c, KQ2E7c, KQ3E7c28523569
287 Randall, D, Morrell, S, . Annual or biennial mammography screening for women at a higher risk with a family history of breast cancer: prognostic indicators of screen-detected cancers in New South Wales, Australia. Cancer Causes Control. 20(5): 559–66. 2009. 10.1007/s10552-008-9264-0. KQ1E4, KQ2E11, KQ3E419015941
288 Rauscher, GH, Murphy, AM, . The “Sweet Spot” Revisited: Optimal Recall Rates for Cancer Detection With 2D and 3D Digital Screening Mammography in the Metro Chicago Breast Cancer Registry. AJR Am J Roentgenol. 216(4): 894–902. 2021. 10.2214/AJR.19.22429. KQ1E3, KQ2E3, KQ3E333566635
289 Redondo, A, Comas, M, . Inter- and intraradiologist variability in the BI-RADS assessment and breast density categories for screening mammograms. Br J Radiol. 85(1019): 1465–70. 2012. 10.1259/bjr/21256379. KQ1E7d, KQ2E7d, KQ3E7d22993385
290 Regen-Tuero, HC, Ram, S, . Community-Based Breast Cancer Screening Using Digital Breast Tomosynthesis Versus Digital Mammography: Comparison of Screening Performance and Tumor Characteristics. AJR Am J Roentgenol. 218(2): 249–257. 2022. 10.2214/ajr.21.26384. KQ1E5, KQ2E5, KQ3E7j34523954
291 Romero Martin, S, Raya Povedano, JL, . Prospective study aiming to compare 2D mammography and tomosynthesis + synthesized mammography in terms of cancer detection and recall. From double reading of 2D mammography to single reading of tomosynthesis. Eur Radiol. 28(6): 2484–2491. 2018. 10.1007/s00330-017-5219-8. KQ1E7d, KQ2E7d, KQ3E7d29294150
292 Rose, SL, Shisler, JL. Tomosynthesis Impact on Breast Cancer Screening in Patients Younger Than 50 Years Old. AJR Am J Roentgenol. 210(6): 1401–1404. 2018. 10.2214/AJR.17.18839. KQ1E4, KQ2E5, KQ3E7j29629810
293 Rose, SL, Tidwell, AL, . A reader study comparing prospective tomosynthesis interpretations with retrospective readings of the corresponding FFDM examinations. Acad Radiol. 21(9): 1204–10. 2014. 10.1016/j.acra.2014.04.008. KQ1E7d, KQ2E7d, KQ3E7d25107868
294 Rose, SL, Tidwell, AL, . Implementation of breast tomosynthesis in a routine screening practice: an observational study. AJR Am J Roentgenol. 200(6): 1401–8. 2013. 10.2214/ajr.12.9672. KQ1E7c, KQ2E7c, KQ3E7c23701081
295 Roth, RG, Maidment, AD, . Digital breast tomosynthesis: lessons learned from early clinical implementation. Radiographics. 34(4): E89–102. 2014. 10.1148/rg.344130087. KQ1E4, KQ2E4, KQ3E7j25019451
296 Saadatmand, S, Geuzinge, HA, . MRI versus mammography for breast cancer screening in women with familial risk (FaMRIsc): a multicentre, randomised, controlled trial. Lancet Oncol. 20(8): 1136–1147. 2019. 10.1016/S1470-2045(19)30275-X. KQ1E1a, KQ2E1a, KQ3E1a31221620
297 Sanderson, M, Levine, RS, . Mammography Screening Among the Elderly: A Research Challenge. Am J Med. 128(12): 1362.e7–14. 2015. 10.1016/j.amjmed.2015.06.032. KQ1E3, KQ2E4, KQ3E4
298 Sarkeala, T, Heinävaara, S, . Breast cancer mortality with varying invitational policies in organised mammography. Br J Cancer. 98(3): 641–5. 2008. 10.1038/sj.bjc.6604203. KQ1E3, KQ2E3, KQ3E318231108
299 Sarkeala, T, Luostarinen, T, . Breast carcinoma detection modes and death in a female population in relation to population-based mammography screening. Springerplus. 3: 348. 2014. 10.1186/2193-1801-3-348. KQ1E7h, KQ2E7h, KQ3E7h27386170
300 Savaridas, SL, Gierlinski, M, . Opting into breast screening over the age of 70 years: seeking evidence to support informed choice. Clin Radiol. 13: 13. 2022. 10.1016/j.crad.2022.01.057. KQ1E3, KQ2E3, KQ3E3
301 Schou Bredal, I, Kåresen, R, . Recall mammography and psychological distress. Eur J Cancer. 49(4): 805–11. 2013. 10.1016/j.ejca.2012.09.001. KQ1E4, KQ2E4, KQ3E323021930
302 Scott, AM, Lashley, MG, . Comparison of Call-Back Rates between Digital Mammography and Digital Breast Tomosynthesis. Am Surg. 85(8): 855–857. 2019. KQ1E4, KQ2E4, KQ3E7j32051067
303 Seely, JM, Peddle, SE, . Breast Density and Risk of Interval Cancers: The Effect of Annual Versus Biennial Screening Mammography Policies in Canada. Can Assoc Radiol J. 73(1): 90–100. 2022. 10.1177/08465371211027958. KQ1E4, KQ2E4, KQ3E7i34279132
304 Seely, JM, Peddle, SE, . Breast Density and Risk of Interval Cancers: The Effect of Annual Versus Biennial Screening Mammography Policies in Canada. Can Assoc Radiol J. :8465371211027958. 2021. 10.1177/08465371211027958. KQ1E7, KQ2E7, KQ3E7
305 Seigneurin, A, François, O, . Overdiagnosis from non-progressive cancer detected by screening mammography: stochastic simulation study with calibration to population based registry data. BMJ. 343: d7017. 2011. 10.1136/BMJ.d7017. KQ1E7h, KQ2E7h, KQ3E7h22113564
306 Sharma, N, McMahon, M, . The Potential Impact of Digital Breast Tomosynthesis on the Benign Biopsy Rate in Women Recalled within the UK Breast Screening Programme. Radiology. 291(2): 310–317. 2019. 10.1148/radiol.2019180809. KQ1E1b, KQ2E1b, KQ3E1b30888932
307 Sharpe, RE, Jr, Venkataraman, . Increased Cancer Detection Rate and Variations in the Recall Rate Resulting from Implementation of 3D Digital Breast Tomosynthesis into a Population-based Screening Program. Radiology. 278(3): 698–706. 2016. 10.1148/radiol.2015142036. KQ1E5, KQ2E5, KQ3E7j26458206
308 Shaughnessy, AF. Adding Ultrasonography to Mammography Increases False-Positive Findings Without an Increase in Cancer Detection. Am Fam Physician. 101(1): 53–54. 2020. KQ1E7a, KQ2E7a, KQ3E7a
309 Shermis, RB, Wilson, KD, . Supplemental Breast Cancer Screening With Molecular Breast Imaging for Women With Dense Breast Tissue. AJR Am J Roentgenol. 207(2): 450–7. 2016. 10.2214/AJR.15.15924. KQ1E7d, KQ2E7d, KQ3E7d27186635
310 Shieh, Y, Eklund, M, . Breast Cancer Screening in the Precision Medicine Era: Risk-Based Screening in a Population-Based Trial. J Natl Cancer Inst. 109(5): 01. 2017. 10.1093/jnci/djw290. KQ1E10, KQ2E10, KQ3E10
311 Sia, J, Moodie, K, . A prospective study comparing digital breast tomosynthesis with digital mammography in surveillance after breast cancer treatment. Eur J Cancer. 61: 122–7. 2016. 10.1016/j.ejca.2016.04.007. KQ1E1b, KQ2E1b, KQ3E1b27163158
312 Simon, MS, Wassertheil-Smoller, S, . Mammography interval and breast cancer mortality in women over the age of 75. Breast Cancer Res Treat. 148(1): 187–95. 2014. 10.1007/s10549-014-3114-4. KQ1E11, KQ2E11, KQ3E425261290
313 Skaane, P, Bandos, AI, . Comparison of digital mammography alone and digital mammography plus tomosynthesis in a population-based screening program. Radiology. 267(1): 47–56. 2013. 10.1148/radiol.12121373. KQ1E7d, KQ2E7d, KQ3E7d23297332
314 Skaane, P, Bandos, Ai, . Comparison of digital mammography alone and digital mammography plus tomosynthesis in a populationbased screening program. Radiology. 267(1): 47–56. 2013. 10.1148/radiol.12121373. KQ1E7d, KQ2E7d, KQ3E7d23297332
315 Skaane, P, Bandos, AI, . Digital Mammography versus Digital Mammography Plus Tomosynthesis in Breast Cancer Screening: The Oslo Tomosynthesis Screening Trial. Radiology. 291(1): 23–30. 2019. 10.1148/radiol.2019182394. KQ1E7d, KQ2E7d, KQ3E7d30777808
316 Skaane, P, Bandos, AI, . Prospective trial comparing full-field digital mammography (FFDM) versus combined FFDM and tomosynthesis in a population-based screening programme using independent double reading with arbitration. Eur Radiol. 23(8): 2061–71. 2013. 10.1007/s00330-013-2820-3. KQ1E7d, KQ2E7d, KQ3E7d23553585
317 Skaane, P, Bandos, AI, . Two-view digital breast tomosynthesis screening with synthetically reconstructed projection images: comparison with digital breast tomosynthesis with full-field digital mammographic images. Radiology. 271(3): 655–63. 2014. 10.1148/radiol.13131391. KQ1E7d, KQ2E7d, KQ3E7d24484063
318 Skaane, P, Sebuodegard, S, . Performance of breast cancer screening using digital breast tomosynthesis: results from the prospective population-based Oslo Tomosynthesis Screening Trial. Breast Cancer Res Treat. 169(3): 489–496. 2018. 10.1007/s10549-018-4705-2. KQ1E7d, KQ2E7d, KQ3E7d29429017
319 Solbjor, M, Forsmo, S, . Psychosocial consequences among women with false-positive results after mammography screening in Norway. Scand J Prim Health Care. 36(4): 380–389. 2018. 10.1080/02813432.2018.1523985. KQ1E3, KQ2E3, KQ3E330296861
320 Song, SE, Cho, N, . Undiagnosed Breast Cancer: Features at Supplemental Screening US. Radiology. 277(2): 372–80. 2015. 10.1148/radiol.2015142960. KQ1E3, KQ2E3, KQ3E326069925
321 Spayne, MC, Gard, CC, . Reproducibility of BI-RADS breast density measures among community radiologists: a prospective cohort study. Breast J. 18(4): 326–33. 2012. 10.1111/j.1524-4741.2012.01250.x. KQ1E4, KQ2E4, KQ3E422607064
322 Sprague, BL, Chen, S, . Cumulative 6-Year Risk of Screen-Detected Ductal Carcinoma In Situ by Screening Frequency. JAMA Netw Open. 6(2): e230166. 2023. 10.1001/JAMAnetworkopen.2023.0166. KQ1E7h, KQ2E7h, KQ3E7h36808238
323 Sprague, BL, Coley, RY, . Assessment of Radiologist Performance in Breast Cancer Screening Using Digital Breast Tomosynthesis vs Digital Mammography. JAMA Network Open. 3(3): e201759. 2020. 10.1001/JAMAnetworkopen.2020.1759. KQ1E4, KQ2E4, KQ3E332227180
324 Starikov, A, Drotman, M, . 2D mammography, digital breast tomosynthesis, and ultrasound: which should be used for the different breast densities in breast cancer screening? Clin Imaging. 40(1): 68–71. 2016. 10.1016/j.clinimag.2015.10.001. KQ1E4, KQ2E5, KQ3E7j26549432
325 Stepanek, T, Constantinou, N, . Changes in the Utilization of the BI-RADS Category 3 Assessment in Recalled Patients Before and After the Implementation of Screening Digital Breast Tomosynthesis. Acad Radiol. 26(11): 1515–1525. 2019. 10.1016/j.acra.2018.12.020. KQ1E7c, KQ2E7c, KQ3E7c30665715
326 Strobel, K, Schrading, S, . Assessment of BI-RADS category 4 lesions detected with screening mammography and screening US: utility of MR imaging. Radiology. 274(2): 343–51. 2015. 10.1148/radiol.14140645. KQ1E7d, KQ2E7d, KQ3E7d25271857
327 Sumkin, JH, Ganott, MA, . Recall Rate Reduction with Tomosynthesis During Baseline Screening Examinations: An Assessment From a Prospective Trial. Acad Radiol. 22(12): 1477–82. 2015. 10.1016/j.acra.2015.08.015. KQ1E7d, KQ2E7d, KQ3E7d26391857
328 Svahn, TM, Chakraborty, DP, . Breast tomosynthesis and digital mammography: a comparison of diagnostic accuracy. Br J Radiol. 85(1019): e1074–82. 2012. 10.1259/bjr/53282892. KQ1E7d, KQ2E7d, KQ3E7d22674710
329 Tabár, L, Faberberg, G, . What is the optimum interval between mammographic screening examinations? An analysis based on the latest results of the Swedish two-county breast cancer screening trial. Br J Cancer. 55(5): 547–51. 1987. 10.1038/bjc.1987.112. KQ1E3, KQ2E3, KQ3E33606947
330 Tabar, L, Fagerberg, G, . Efficacy of breast cancer screening by age. New results from the Swedish Two-County Trial. Cancer. 75(10): 2507–17. 1995. 10.1002/1097-0142(19950515)75:10<2507::aid-cncr2820751017>3.0.co;2-h. KQ1E3, KQ2E3, KQ3E37736395
331 Tabar, L, Vitak, B, . Swedish two-county trial: impact of mammographic screening on breast cancer mortality during 3 decades. Radiology. 260(3): 658–663. 2011. 10.1148/radiol.11110469. KQ1E2b, KQ2E2b, KQ3E2b21712474
332 Tagliafico, A, Astengo, D, . One-to-one comparison between digital spot compression view and digital breast tomosynthesis. Eur Radiol. 22(3): 539–44. 2012. 10.1007/s00330-011-2305-1. KQ1E1b, KQ2E1b, KQ3E1b21987214
333 Tagliafico, AS, Calabrese, M, . Adjunct Screening With Tomosynthesis or Ultrasound in Women With Mammography-Negative Dense Breasts: Interim Report of a Prospective Comparative Trial. J Clin Oncol. 34(16): 1882–1888. 2016. 10.1016/j.ejca.2018.08.029. KQ1E7d, KQ2E7d, KQ3E7d26962097
334 Tagliafico, AS, Mariscotti, G, . A prospective comparative trial of adjunct screening with tomosynthesis or ultrasound in women with mammography-negative dense breasts (ASTOUND-2). Eur J Cancer. 104: 39–46. 2018. 10.1016/j.ejca.2018.08.029. KQ1E7d, KQ2E7d, KQ3E7d30316869
335 Taha Ali, TamerF, Magid, AsmaaMA, . Potential impact of tomosynthesis on the detection and diagnosis of breast lesions. The Egyptian Journal of Radiology and Nuclear Medicine. 47(1): 351–361. 2016. 10.1016/j.ejrnm.2015.10.006. KQ1E7d, KQ2E7d, KQ3E7d
336 Teertstra, HJ, Loo, CE, . Breast tomosynthesis in clinical practice: initial results. Eur Radiol. 20(1): 16–24. 2010. 10.1007/s00330-009-1523-2. KQ1E1b, KQ2E1b, KQ3E1b19657655
337 Teoh, KC, Manan, HA, . Comparison of Mean Glandular Dose between Full-Field Digital Mammography and Digital Breast Tomosynthesis. Healthcare. 9(12): 19. 2021. 10.3390/healthcare9121758. KQ1E4, KQ2E4, KQ3E7j
338 Thibault, F, Dromain, C, . Digital breast tomosynthesis versus mammography and breast ultrasound: a multireader performance study. Eur Radiol. 23(9): 2441–9. 2013. 10.1007/s00330-013-2863-5. KQ1E1b, KQ2E1b, KQ3E1b23673573
339 Thomassin-Naggara, I, Perrot, N, . Added value of one-view breast tomosynthesis combined with digital mammography according to reader experience. Eur J Radiol. 84(2): 235–41. 2015. 10.1016/j.ejrad.2014.10.022. KQ1E7d, KQ2E7d, KQ3E7d25467641
340 Timmermans, L, Bleyen, L, . Screen-detected versus interval cancers: Effect of imaging modality and breast density in the Flemish Breast Cancer Screening Programme. Eur Radiol. 27(9): 3810–3819. 2017. 10.1007/s00330-017-4757-4. KQ1E2b, KQ2E2b, KQ3E2b28289944
341 Tosteson, AN, Fryback, DG, . Consequences of false-positive screening mammograms. JAMA Intern Med. 174(6): 954–61. 2014. 10.1001/JAMAinternmed.2014.981. KQ1E4, KQ2E4, KQ3E324756610
342 Tsuruda, KM, Larsen, M, . Cumulative risk of a false-positive screening result: A retrospective cohort study using empirical data from 10 biennial screening rounds in BreastScreen Norway. Cancer. 128(7): 1373–1380. 2022. 10.1002/cncr.34078. KQ1E3, KQ2E3, KQ3E334931707
343 Uematsu, T. Sensitivity and specificity of screening mammography without clinical breast examination among Japanese women aged 40-49 years: analysis of data from the J-START results. Breast Cancer. 29(5): 928–931. 2022. 10.1007/s12282-022-01353-1. KQ1E4, KQ2E4, KQ3E435507294
344 Upneja, A, Long, JB, . Comparative Effectiveness of Digital Breast Tomosynthesis and Mammography in Older Women. J Gen Intern Med. 1–7. 2021. 10.1007/s11606-021-07132-6. KQ1E5, KQ2E5, KQ3E7j
345 Valencia, EM, Pruthi, S. Practice-Changing Opportunity to Reduce Disparities in Screening Mammography-Implementation of Risk Assessment in Primary Care. JAMA Net Open. 4(9): e2124535. 2021. 10.1001/jamanetworkopen.2021.24535. KQ1E7a, KQ2E7a, KQ3E7a
346 Van Dyck, Walter, Gassull, Daniel, . Unlocking the value of personalised healthcare in Europe—breast cancer stratification. Health Policy and Technology. 1(2): 63–68. 2012. 10.1016/j.hlpt.2012.04.006. KQ1E7h, KQ2E7h, KQ3E7h
347 van Schoor, G, Moss, SM, . Increasingly strong reduction in breast cancer mortality due to screening. Br J Cancer. 104(6): 910–4. 2011. 10.1038/bjc.2011.44. KQ1E2b, KQ2E2b, KQ3E2b21343930
348 Van, Ravesteyn Nt, Heijnsdijk, Eam, . Prediction of higher mortality reduction for the UK Breast Screening Frequency Trial: a model-based approach on screening intervals. Br J Cancer. 105(7): 1082–1088. 2011. 10.1038/bjc.2011.300. KQ1E7h, KQ2E7h, KQ3E7h21863031
349 Venturini, E, Losio, C, . Tailored breast cancer screening program with microdose mammography, US, and MR Imaging: short-term results of a pilot study in 40-49-year-old women. Radiology. 268(2): 347–55. 2013. 10.1148/radiol.13122278. KQ1E3, KQ2E3, KQ3E323579052
350 Wai, ES, D’Yachkova, Y, . Comparison of 1- and 2-year screening intervals for women undergoing screening mammography. Br J Cancer. 92(5): 961–6. 2005. 10.1038/sj.bjc.6602393. KQ1E7c, KQ2E7c, KQ3E7c15714210
351 Waldherr, C, Cerny, P, . Value of one-view breast tomosynthesis versus two-view mammography in diagnostic workup of women with clinical signs and symptoms and in women recalled from screening. AJR Am J Roentgenol. 200(1): 226–31. 2013. 10.2214/ajr.11.8202. KQ1E1b, KQ2E1b, KQ3E1b23255766
352 Weedon-Fekjaer, H, Romundstad, PR, . Modern mammography screening and breast cancer mortality: population study. BMJ. 348: g3701. 2014. 10.1136/BMJ.g3701. KQ1E7h, KQ2E7h, KQ3E7h24951459
353 Weigert, J, Steenbergen, S. The connecticut experiment: the role of ultrasound in the screening of women with dense breasts. Breast J. 18(6): 517–22. 2012. 10.1111/tbj.12003. KQ1E7, KQ2E7, KQ3E723009208
354 Weigert, J, Steenbergen, S. The connecticut experiments second year: ultrasound in the screening of women with dense breasts. Breast Journal. 21(2): 175–80. 2015. 10.1111/tbj.12386. KQ1E3, KQ2E3, KQ3E325683369
355 Welch, HG, Prorok, PC, . Breast-Cancer Tumor Size, Overdiagnosis, and Mammography Screening Effectiveness. N Engl J Med. 375(15): 1438–1447. 2016. 10.1056/nejmoa1600249. KQ1E2b, KQ2E2b, KQ3E2b27732805
356 Whelehan, P, Evans, A, . The effect of mammography pain on repeat participation in breast cancer screening: a systematic review. Breast. 22(4): 389–94. 2013. 10.1016/j.breast.2013.03.003. KQ1E7a, KQ2E7a, KQ3E7a23541681
357 Whitman, GJ, Scoggins, ME. Screening Breast Ultrasound Following Tomosynthesis. Acad Radiol. 29(3): 348–349. 2022. 10.1016/j.acra.2021.12.003. KQ1E7a, KQ2E7a, KQ3E7a34991942
358 Wilczek, B, Wilczek, HE, . Adding 3D automated breast ultrasound to mammography screening in women with heterogeneously and extremely dense breasts: Report from a hospital-based, high-volume, single-center breast cancer screening program. Eur J Radiol. 85(9): 1554–63. 2016. 10.1016/j.ejrad.2016.06.004. KQ1E1b, KQ2E1b, KQ3E1b27501888
359 Winch, CJ, Sherman, KA, . Toward the breast screening balance sheet: cumulative risk of false positives for annual versus biennial mammograms commencing at age 40 or 50. Breast Cancer Res Treat. 149(1): 211–21. 2015. 10.1007/s10549-014-3226-x. KQ1E4, KQ2E11, KQ3E1125476499
360 Winter, AM, Kazmi, S, . Comparison of interval breast cancers with 2D digital mammography versus 3D digital breast tomosynthesis in a large community-based practice. Breast Journal. 26(10): 1953–1959. 2020. 10.1111/tbj.14047. KQ1E7c, KQ2E7c, KQ3E7c33064341
361 Wu, Y, Alagoz, O, . Pursuing optimal thresholds to recommend breast biopsy by quantifying the value of tomosynthesis. Proc SPIE Int Soc Opt Eng. 9037: 90370u. 2014. 10.1117/12.2042905. KQ1E7d, KQ2E7d, KQ3E7d
362 Wu, YY, Yen, MF, . Individually tailored screening of breast cancer with genes, tumour phenotypes, clinical attributes, and conventional risk factors. Br J Cancer. 108(11): 2241–9. 2013. 10.1038/bjc.2013.202. KQ1E7h, KQ2E7h, KQ3E7h23674086
363 Yaffe, MJ, Mainprize, JG. Risk of radiation-induced breast cancer from mammographic screening. Radiology. 258(1): 98–105. 2011. 10.1148/radiol.10100655. KQ1E7h, KQ2E7h, KQ3E7h21081671
364 Yankaskas, BC, Taplin, SH, . Association between mammography timing and measures of screening performance in the United States. Radiology. 234(2): 363–73. 2005. 10.1148/radiol.2342040048. KQ1E4, KQ2E4, KQ3E7j15670994
365 Yen, AM, Duffy, SW, . Long-term incidence of breast cancer by trial arm in one county of the Swedish Two-County Trial of mammographic screening. Cancer. 118(23): 5728–32. 2012. 10.1002/cncr.27580. KQ1E3, KQ2E3, KQ3E322605639
366 Yen, AM, Tsau, HS, . Population-Based Breast Cancer Screening With Risk-Based and Universal Mammography Screening Compared With Clinical Breast Examination: A Propensity Score Analysis of 1429890 Taiwanese Women. JAMA Oncol. 2(7): 915–21. 2016. 10.1001/JAMAoncol.2016.0447. KQ1E7c, KQ2E7c, KQ3E7c27030951
367 Yen, MF, Tabár, L, . Quantifying the potential problem of overdiagnosis of ductal carcinoma in situ in breast cancer screening. Eur J Cancer. 39(12): 1746–54. 2003. 10.1016/s0959-8049(03)00260-0. KQ1E7h, KQ2E7h, KQ3E7h12888370
368 Yi, A, Jang, MJ, . Addition of Screening Breast US to Digital Mammography and Digital Breast Tomosynthesis for Breast Cancer Screening in Women at Average Risk. Radiology. 298(3): 568–575. 2021. 10.1148/radiol.2021203134. KQ1E7d, KQ2E7d, KQ3E7d33434108
369 Youk, JH, Kim, EK, . Performance of hand-held whole-breast ultrasound based on BI-RADS in women with mammographically negative dense breast. Eur Radiol. 21(4): 667–75. 2011. 10.1007/s00330-010-1955-8. KQ1E1, KQ2E1, KQ3E120853108
370 Zackrisson, S, Andersson, I, . Rate of over-diagnosis of breast cancer 15 years after end of Malmö mammographic screening trial: follow-up study. BMJ. 332(7543): 689–92. 2006. 10.1136/BMJ.38764.572569.7C. KQ1E3, KQ2E3, KQ3E316517548
371 Zahl, PH, Mæhlen, J. Overdiagnosis of breast cancer after 14 years of mammography screening. Tidsskr Nor Laegeforen. 132(4): 414–7. 2012. 10.4045/tidsskr.11.0195. KQ1E2b, KQ2E2b, KQ3E2b22353833
372 Zahl, PH. Overdiagnosis of breast cancer in Denmark. Br J Cancer. 90(8): 1686; author reply 1687. 2004. 10.1038/sj.bjc.6601738. KQ1E7a, KQ2E7a, KQ3E7a15083204
373 Zervoudis, S, Iatrakis, G, . Tomosynthesis improves breast cancer detection: our experience. Eur J Gynaecol Oncol. 35(6): 666–9. 2014. KQ1E7d, KQ2E7d, KQ3E7d25556272
374 Zuckerman, SP, Conant, EF, . Implementation of Synthesized Two-dimensional Mammography in a Population-based Digital Breast Tomosynthesis Screening Program. Radiology. 281(3): 730–736. 2016. 10.1148/radiol.2016160366. KQ1E7c, KQ2E7c, KQ3E7c27467468
375 Zuckerman, SP, Sprague, BL, . Multicenter Evaluation of Breast Cancer Screening with Digital Breast Tomosynthesis in Combination with Synthetic versus Digital Mammography. Radiology. 297(3): 545–553. 2020. 10.1148/radiol.2020200240. KQ1E7c, KQ2E7c, KQ3E7c33048032