# Appendix C Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

1. The frequency of breast cancer screening: results from the UKCCCR Randomised Trial. United Kingdom Co-ordinating Committee on Cancer Research. Eur J Cancer. 2002;38(11):1458–64. 10.1016/s0959-8049(01)00397-5 12110490
2. Armaroli P, Frigerio A, Correale L, . A randomised controlled trial of Digital Breast Tomosynthesis versus Digital Mammography as primary screening tests: screening results over subsequent episodes of the Proteus Donna study. Int J Cancer. 2022. 10.1002/ijc.34161
3. Conant EF, Beaber EF, Sprague BL, . Breast cancer screening using tomosynthesis in combination with digital mammography compared to digital mammography alone: a cohort study within the PROSPR consortium. Breast Cancer Research & Treatment. 2016;156(1):109–16. 10.1007/s10549-016-3695-1 26931450
4. Ganguli I, Keating NL, Thakore N, . Downstream Mammary and Extramammary Cascade Services and Spending Following Screening Breast Magnetic Resonance Imaging vs Mammography Among Commercially Insured Women. JAMA Netw Open. 2022;5(4):e227234. 10.1001/jamanetworkopen.2022.7234 35416989
5. Garcia-Albeniz X, Hernan MA, Logan RW, . Continuation of Annual Screening Mammography and Breast Cancer Mortality in Women Older Than 70 Years. Annals of Internal Medicine. 2020;172(6):381–9. 10.7326/M18-1199 32092767
6. Heindel W, Weigel S, Gerß J, . Digital breast tomosynthesis plus synthesised mammography versus digital screening mammography for the detection of invasive breast cancer (TOSYMA): a multicentre, open-label, randomised, controlled, superiority trial. Lancet Oncol. 2022. 10.1016/s1470-2045(22)00194-2
7. Ho TH, Bissell MCS, Kerlikowske K, . Cumulative Probability of False-Positive Results After 10 Years of Screening With Digital Breast Tomosynthesis vs Digital Mammography. JAMA Netw Open. 2022;5(3):e222440. 10.1001/jamanetworkopen.2022.2440 35333365
8. Hofvind S, Moshina N, Holen AS, . Interval and Subsequent Round Breast Cancer in a Randomized Controlled Trial Comparing Digital Breast Tomosynthesis and Digital Mammography Screening. Radiology. 2021;300(1):66–76. 10.1148/radiol.2021203936 33973840
  a. Aase HS, Danielsen AS, Hoff SR, . Mammographic features and screening outcome in a randomized controlled trial comparing digital breast tomosynthesis and digital mammography. Eur J Radiol. 2021;141:109753. 10.1016/j.ejrad.2021.109753 34053786
  b. Aase HS, Holen AS, Pedersen K, . A randomized controlled trial of digital breast tomosynthesis versus digital mammography in population-based screening in Bergen: interim analysis of performance indicators from the To-Be trial. Eur Radiol. 2019;29(3):1175–86. 10.1007/s00330-018-5690-x 30159620
  c. Moshina N, Aase HS, Danielsen AS, . Comparing Screening Outcomes for Digital Breast Tomosynthesis and Digital Mammography by Automated Breast Density in a Randomized Controlled Trial: Results from the To-Be Trial. Radiology. 2020;297(3):522–31. 10.1148/radiol.2020201150 32930649
  d. Moger TA, Swanson JO, Holen AS, . Cost differences between digital tomosynthesis and standard digital mammography in a breast cancer screening programme: results from the To-Be trial in Norway. Eur J Health Econ. 2019;20(8):1261–9. 10.1007/s10198-019-01094-7 31399773
  e. Hofvind S, Holen AS, Aase HS, . Two-view digital breast tomosynthesis versus digital mammography in a population-based breast cancer screening programme (To-Be): a randomised, controlled trial. Lancet Oncology. 2019;20(6):795–805. 10.1016/S1470-2045(19)30161-5 31078459
  f. Waade G, Holen Å, Sebuødegård S, . Breast compression parameters among women screened with standard digital mammography and digital breast tomosynthesis in a randomized controlled trial. Acta Radiologica. 2020; 61(3). https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01980122/full
9. Hovda T, Holen AS, Lang K, . Interval and Consecutive Round Breast Cancer after Digital Breast Tomosynthesis and Synthetic 2D Mammography versus Standard 2D Digital Mammography in BreastScreen Norway. Radiology. 2020;294(2):256–64. 10.1148/radiol.2019191337 31821118
  a. Hofvind S, Hovda T, Holen AS, . Digital Breast Tomosynthesis and Synthetic 2D Mammography versus Digital Mammography: Evaluation in a Population-based Screening Program. Radiology. 2018;287(3):787–94. 10.1148/radiol.2018171361 29494322
10. Johnson K, Lang K, Ikeda DM, . Interval Breast Cancer Rates and Tumor Characteristics in the Prospective Population-based Malmo Breast Tomosynthesis Screening Trial. Radiology. 2021;299(3):559–67. 10.1148/radiol.2021204106 33825509
  a. Zackrisson S, Lang K, Rosso A, . One-view breast tomosynthesis versus two-view mammography in the Malmo Breast Tomosynthesis Screening Trial (MBTST): a prospective, population-based, diagnostic accuracy study. Lancet Oncology. 2018;19(11):1493–503. 10.1016/S1470-2045(18)30521-7 30322817
  b. Lang K, Nergarden M, Andersson I, . False positives in breast cancer screening with one-view breast tomosynthesis: An analysis of findings leading to recall, work-up and biopsy rates in the Malmo Breast Tomosynthesis Screening Trial. Eur Radiol. 2016;26(11):3899–907.26943342
  c. Lang K, Andersson I, Rosso A, . Performance of one-view breast tomosynthesis as a stand-alone breast cancer screening modality: results from the Malmo Breast Tomosynthesis Screening Trial, a population-based study. Eur Radiol. 2016;26(1):184–90. 10.1007/s00330-015-3803-3 25929946
  d. Johnson K, Zackrisson S, Rosso A, . Tumor Characteristics and Molecular Subtypes in Breast Cancer Screening with Digital Breast Tomosynthesis: the Malmö Breast Tomosynthesis Screening Trial. Radiology. 2019; 293(2): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-02083775/full
  e. Rosso A, Lang K, Petersson IF, . Factors affecting recall rate and false positive fraction in breast cancer screening with breast tomosynthesis - A statistical approach. Breast. 2015;24(5):680–6. 10.1016/j.breast.2015.08.007 26365133
11. Kerlikowske K, Su Y-R, Sprague BL, . Association of Screening With Digital Breast Tomosynthesis vs Digital Mammography With Risk of Interval Invasive and Advanced Breast Cancer. JAMA. 2022;327(22):2220–30. 10.1001/jama.2022.7672 35699706
12. Lee JM, Arao RF, Sprague BL, . Performance of Screening Ultrasonography as an Adjunct to Screening Mammography in Women Across the Spectrum of Breast Cancer Risk. JAMA internal medicine. 2019;179(5):658–67. 10.1001/jamainternmed.2018.8372 30882843
13. McGuinness JE, Ueng W, Trivedi MS, . Factors Associated with False Positive Results on Screening Mammography in a Population of Predominantly Hispanic Women. Cancer Epidemiology, Biomarkers & Prevention. 2018;27(4):446–53. 10.1158/1055-9965.EPI-17-0009
14. Miglioretti DL, Zhu W, Kerlikowske K, . Breast Tumor Prognostic Characteristics and Biennial vs Annual Mammography, Age, and Menopausal Status. JAMA Oncology. 2015;1(8):1069–77. 10.1001/jamaoncol.2015.3084 26501844
  a. Dittus K, Geller B, Weaver DL, . Impact of mammography screening interval on breast cancer diagnosis by menopausal status and BMI. J Gen Intern Med. 2013;28(11):1454–62. 10.1007/s11606-013-2507-0 23760741
  b. Goel A, Littenberg B, Burack RC. The association between the pre-diagnosis mammography screening interval and advanced breast cancer. Breast Cancer Res Treat. 2007;102(3):339–45. 10.1007/s10549-006-9334-5 16927175
  c. Hubbard RA, Kerlikowske K, Flowers CI, . Cumulative probability of false-positive recall or biopsy recommendation after 10 years of screening mammography: a cohort study. Ann Intern Med. 2011;155(8):481–92. 10.7326/0003-4819-155-8-201110180-00004 22007042
  d. Kerlikowske K, Zhu W, Hubbard RA, . Outcomes of screening mammography by frequency, breast density, and postmenopausal hormone therapy. JAMA internal medicine. 2013;173(9):807–16. 10.1001/jamainternmed.2013.307 23552817
  e. White E, Miglioretti DL, Yankaskas BC, . Biennial versus annual mammography and the risk of late-stage breast cancer. Journal of the National Cancer Institute. 2004;96(24):1832–9. 10.1093/jnci/djh337 15601639
  f. Nelson HD, O’Meara ES, Kerlikowske K, . Factors Associated With Rates of False-Positive and False-Negative Results From Digital Mammography Screening: An Analysis of Registry Data. Annals of Internal Medicine. 2016;164(4):226–35. 10.7326/M15-0971 26756902
  g. Braithwaite D, Zhu W, Hubbard RA, . Screening outcomes in older US women undergoing multiple mammograms in community practice: does interval, age, or comorbidity score affect tumor characteristics or false positive rates? Journal of the National Cancer Institute. 2013;105(5):334–41. 10.1093/jnci/djs645 23385442
15. Ohuchi N, Suzuki A, Sobue T, . Sensitivity and specificity of mammography and adjunctive ultrasonography to screen for breast cancer in the Japan Strategic Anti-cancer Randomized Trial (J-START): a randomised controlled trial. Lancet. 2016;387(10016):341–8. 10.1016/S0140-6736(15)00774-6 26547101
  a. Harada-Shoji N, Suzuki A, Ishida T, . Evaluation of Adjunctive Ultrasonography for Breast Cancer Detection Among Women Aged 40-49 Years With Varying Breast Density Undergoing Screening Mammography: A Secondary Analysis of a Randomized Clinical Trial. JAMA netw. 2021;4(8):e2121505. 10.1001/jamanetworkopen.2021.21505
  b. Ishida T, Suzuki A, Kawai M, . A randomized controlled trial to verify the efficacy of the use of ultrasonography in breast cancer screening aged 40-49 (J-START): 76 196 women registered. Jpn J Clin Oncol. 2014;44(2):134–40. 10.1093/jjco/hyt199 24407835
16. Parvinen I, Chiu S, Pylkkänen L, . Effects of annual vs triennial mammography interval on breast cancer incidence and mortality in ages 40-49 in Finland. Br J Cancer. 2011;105(9):1388–91. 10.1038/bjc.2011.372 21934688
  a. Klemi PJ, Toikkanen S, Räsänen O, . Mammography screening interval and the frequency of interval cancers in a population-based screening. Br J Cancer. 1997;75(5):762–6. 10.1038/bjc.1997.135 9043038
17. Pattacini P, Nitrosi A, Giorgi Rossi P, . A Randomized Trial Comparing Breast Cancer Incidence and Interval Cancers after Tomosynthesis Plus Mammography versus Mammography Alone. Radiology. 2022:211132. 10.1148/radiol.211132
  a. Pattacini P, Nitrosi A, Giorgi Rossi P, . Digital Mammography versus Digital Mammography Plus Tomosynthesis for Breast Cancer Screening: The Reggio Emilia Tomosynthesis Randomized Trial. Radiology. 2018;288(2):375–85. 10.1148/radiol.2018172119 29869961
18. Richman IB, Long JB, Hoag JR, . Comparative Effectiveness of Digital Breast Tomosynthesis for Breast Cancer Screening among Women 40-64 Years Old. Journal of the National Cancer Institute. 2021;03:03. 10.1093/jnci/djab063
19. Sprague B, Coley RY, Lowry K, . Digital breast tomosynthesis versus digital mammography screening performance on successive screening rounds from the Breast Cancer Surveillance Consortium. Radiology 2023;307(5):e223142. 10.1148/radiol.223142 37249433
20. Veenhuizen SGA, de Lange SV, Bakker MF, . Supplemental Breast MRI for Women with Extremely Dense Breasts: Results of the Second Screening Round of the DENSE Trial. Radiology. 2021;299(2):278–86. 10.1148/radiol.2021203633 33724062
  a. Bakker MF, de Lange SV, Pijnappel RM, . Supplemental MRI Screening for Women with Extremely Dense Breast Tissue. New England Journal of Medicine. 2019;381(22):2091–102. 10.1056/NEJMoa1903986 31774954
  b. de Lange SV, Bakker MF, Monninkhof EM, . Reasons for (non)participation in supplemental population-based MRI breast screening for women with extremely dense breasts. Clinical Radiology. 2018;73(8):759.e1–.e9. 10.1016/j.crad.2018.04.002