# Appendix B Detailed Methods

## Literature Search Strategies for Primary Literature

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword
- kf = keyword (author attributed keyword)

MEDLINE

Database: Ovid MEDLINE(R) ALL <1946 to September 08, 2021>

Search Strategy:

--------------------------------------------------------------------------------

1. exp Mammography/ or mammogra$.ti,ab,kf. (42796)
2. (digital breast tomosynthesis or (breast and dbt)).ti,ab,kf. (1024)
3. exp Breast Neoplasms/dg, di or *Breast/dg or *Breast Diseases/dg (61902)
4. ((breast adj2 (adenocarcinoma$ or cancer$ or carcinoma$ or neoplasm$ or tumo?r$ or malignan$ or metasta$)) or (dense adj2 breast$)).ti,kf. (232922)
5. 1 or 2 or 3 or 4 (276872)
6. mass screening/ or “Early Detection of Cancer”/ (132362)
7. (screen$ or detect$).ti. (577900)
8. ((routine or detect$ or cancer or ultrasound or multimodal or program$) adj3 (mammogra$ or screen$)).ti,ab. (109023)
9. or/6-8 (680574)
10. 5 and 9 (32197)
11. “Delivery of Health Care”/mt, og, sn (31361)
12. (strateg$ or modalit$ or pattern$).ti,ab,kf. (2759513)
13. Time factors/ (1214828)
14. (interval$ or mean time or frequency or frequent or biannual$ or biennual$ or annual$).ti,ab,kf. (2239088)
15. Age factors/ (465601)
16. (initiation or initiated).ti,ab,kf. (410612)
17. Precision Medicine/ (21498)
18. Personali$.ti,ab,kf. (147594)
19. ((supplemental or supplemented) adj2 (imaging or screening)).ti,ab,kf. (472)
20. ((follow$ or after or plus or prior or versus) adj2 (mammogram$ or dbt or tomosynthesis)).ti,ab,kf. (880)
21. Survival rate/ (183317)
22. Morbidity/ (31781)
23. Life tables/ (6511)
24. Mortality/ (47448)
25. (morbidity or mortality or impairment or impaired).ti,ab,kf. (1615191)
26. Risk factors/ (885488)
27. Risk reduction behavior/ (13682)
28. Incidence/ (281166)
29. Disease progression/ (177438)
30. (Incidence or incident or progression or detection rate$ or recall rate$).ti,ab,kf. or (risk or risks).ti. (1910562)
31. False Positive Reactions/ (28344)
32. (False positive or false negative).ti,ab,kf. (68831)
33. ((incorrect$ or false$ or wrong$ or bias$ or mistake$ or error$ or erroneous$) adj3 (result$ or finding$ or outcome$ or test$ or diagnos$)).ti,ab,kf. (90383)
34. medical overuse/ or unnecessary procedures/ (7907)
35. (overdiagnos$ or over-diagnos$ or misdiagnos$).ti,ab,kf. (42993)
36. (overtreat$ or over treat$).ti,ab,kf. (7976)
37. Anxiety/ (90741)
38. (anxiety or anxious).ti,ab,kf. (225786)
39. (pain or painful).ti,ab,kf. (715605)
40. (embarrassment or psychological or distress or stigma or fatalism or fatalistic).ti,ab,kf. (374937)
41. (harm or harms or harmful or harmed).ti,ab. (132817)
42. (adverse effects or mortality).fs. (2337681)
43. death/ (18406)
44. (death or deaths).ti,ab. (888163)
45. (adverse adj (effect$ or event$ or outcome$ or reaction$)).ti,ab. (402597)
46. complication$.ti,ab. (983995)
47. side effect$.ti,ab. (266086)
48. safety.ti,ab. (568105)
49. (radiation or exposure).ti,ab,kf. (1232997)
50. Long Term Adverse Effects/ (704)
51. “Quality of Life”/ (220401)
52. (“quality of life” or well-being).ti,ab,kf. (391275)
53. or/11-52 (12563328)
54. 10 and 53 (21014)
55. limit 54 to (english language and yr=“2014 -Current”) (7617)

Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL) via Wiley

Date Run: 09/09/2021 18:40:11

ID Search Hits

#1 mammogra*:ti,ab,kw 2606
#2 (“digital breast tomosynthesis” or (breast and dbt)):ti,ab,kw 52
#3 (breast NEAR/2 (adenocarcinoma* or cancer* or carcinoma* or neoplasm* or tumo?r* OR malignan* OR metasta*)):ti,kw or (dense NEAR/2 breast*):ti,kw 35760
#4 #1 OR #2 OR #3 36543
#5 (screen* or detect*):ti,kw 30087
#6 ((routine or detect* or cancer or ultrasound or multimodal or program*) NEAR/3 (mammogra* or screen*)):ti,ab,kw 9764
#7 #5 or #6 32468
#8 #4 AND #7 with Cochrane Library publication date from Jan 2014 to present, in Trials 1698
#9 #8 AND (clinicaltrials or trialsearch):so 300
#10 #8 AND conference:pt 443
#11 #8 NOT (#9 OR #10) 955
#12 #4 AND #7 with Cochrane Library publication date from Jan 2014 to present, in Cochrane Reviews 4

Appendix B Figure 1 Literature Flow Diagram

Appendix B Figure 1 is the literature flow diagram showing the number of studies reviewed and excluded during abstract and full-text review, as well as the rationale for studies excluded during full-text review.

Appendix B Table 1 Inclusion and Exclusion Criteria

Category | Include | Exclude
Population^*^ | Adult females | History of breast cancer or high-risk breast lesions (DCIS, LCIS, ADH, ALH); Clinically significant genetic markers or syndromes associated with high risk (e.g., BRCA1 or BRCA2 gene mutations, Li-Fraumeni syndrome, Cowden syndrome, hereditary diffuse gastric cancer, or other familial breast cancer syndromes); Previous large doses of chest radiation (≥20 Gy) before age 30 years
Interventions | Any mammography screening modality (i.e., film or digital mammography, digital breast tomosynthesis [3D mammography]); Screening strategy (e.g., screening interval, age to start or stop screening, personalized screening based on risk and other characteristics); Any mammography screening modality plus supplemental screening (e.g., ultrasound, MRI); Any mammography screening modality plus supplemental screening for a defined population (e.g., negative mammography, dense breasts, age group) | Breast imaging or clinical examinations conducted for diagnosis or surveillance; Screening strategies that do not include mammography
Comparisons | Standard population-based screening with film or digital mammography | Breast imaging or clinical examinations conducted for diagnosis or surveillance; Screening that does not include mammography
Outcomes | KQ 1:; - Breast cancer morbidity (e.g., adverse effects of treatment, physical/functional impairment); - Quality of life or subjective well-being; - Breast cancer mortality; - All-cause mortality; KQ 2:; - Detection and stage distribution of screen-detected invasive breast cancer; - Detection of advanced cancer and stage distribution of any invasive breast cancer at time of screening and across followup, including interval cancers; - Cancer subtypes will be defined by receptor status (e.g., ER/PR, HER2) since these are associated with prognosis; - Advanced cancer definitions are not standardized, and available outcomes will likely vary across studies (e.g., metastatic breast cancer, different stage and tumor size cutpoints)^†^; KQ 3:; - False-positive and false-negative findings at screening and biopsy; - Recall rate (need for further evaluation); - Overdiagnosis and overtreatment; - Psychological harms (e.g., anxiety, depression); - Quality of life and subjective well-being; - Radiation exposure
Timing | KQs 1, 2: Followup from at least two rounds of screening, duration of followup; KQ 3:; - Per round of screening; - Over multiple rounds of screening; - Lifetime
Setting | Settings and populations of women applicable to U.S. primary care settings; Studies conducted in countries categorized as “Very High” on the Human Development Index (as defined by the United Nations Development Programme)
Study Design | KQs 1, 2:; - Individual participant data meta-analyses; - Randomized, controlled trials; controlled clinical trials; - Prospective cohort studies with contemporaneous comparison groups selected using unbiased criteria (e.g., screening modality used does not vary based on risk factor or marker); KQ 3: Above, plus population-based nested case-control studies and cross-sectional studies from included trials or large population-based studies | Narrative reviews, case reports, case series, editorials; Observational studies using paired designs (i.e., within-person comparisons)
Language | English-language abstracts and articles (includes English-language abstracts of non–English-language papers)

* Most breast cancer cases occur in cisgender women with breast tissue that developed during puberty when rising endogenous estrogen hormone stimulated the proliferation of duct and lobule tissue. Throughout the report we incorporate gender-inclusive language (people, individuals, persons with breasts) when referring to the screening population to recognize that not all people at risk of breast cancer and eligible for screening are women. Transgender men and nonbinary or gender nonconforming people who have breasts are also important to consider when talking about screening for breast cancer, especially since they face unique preventive health care access barriers. In addition to using gender-inclusive terminology throughout the review, we at times refer to women as the study population, especially when citing existing studies, recommendations, registries, and data sources that did not collect nuanced data on gender. The included population for this review does not include studies of screening for transgender women, nonbinary individuals, and others who have developed breast tissue following gender-affirming medical treatment with exogenous estrogen. This population should receive specialty care that can attend to their specific clinical history (length, type of hormone use, etc.), and would rely on different, not yet available evidence for assessing breast cancer risk and screening outcomes.

† Where possible we will report outcomes for cancers diagnosed at American Joint Committee on Cancer (AJCC) stage IIA or higher ( Kerlikowske K, Bissell MCS, Sprague BL, . Advanced Breast Cancer Definitions by Staging System Examined in the Breast Cancer Surveillance Consortium. Journal of the National Cancer Institute. 2021;113(7):909–16 33169794 ).

Abbreviations: ADH=atypical ductal hyperplasia; ALH=atypical lobular hyperplasia; BI-RADS=Breast Imaging-Reporting and Data System; BRCA=breast cancer gene; DCIS=ductal carcinoma in situ; ER/PR=estrogen receptor/progesterone receptor; LCIS=lobular carcinoma in situ; HER2=human epidermal growth factor receptor 2; MRI=magnetic resonance imaging.

Appendix B Table 2 Quality Assessment Criteria^*^

Study Design | Adapted Quality Criteria
Randomized clinical trials, adapted from U.S. Preventive Services Task Force Manual^112^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Adapted Risk of Bias Assessment (ROBINS-I)^290^ | Bias due to confounding; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias in classifying interventions; - Intervention groups are clearly defined; - Information used to define intervention groups was recorded at the start of the intervention; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias due to deviations from intended interventions; - No deviations from intended intervention; - Important co-interventions are balanced across intervention groups; - Analysis adjusts for deviations from intended intervention that could have affected outcomes; Bias from missing data; - Outcome data are available for all, or nearly all, participants; - Proportion of participants and reasons for missing data are similar across groups; - Appropriate statistical methods used to account for missing data or there was evidence that results were robust to the presence data; Bias in measurement of outcomes; - Blinding of participants; - Blinding of outcome assessors; - Methods of outcome assessment are comparable across intervention groups; - No systematic errors in measurement of the outcome related to intervention received; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported

* All randomized clinical trials and nonrandomized studies of intervention were classified as good, fair, or poor.^112,290^ Good quality studies generally meet all quality criteria. Fair quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.