# Appendix A Foundational Trial Evidence From 2016 USPSTF Review

## Screening Effectiveness

Nine fair-quality RCTs comparing mammography screening with nonscreening provided outcomes that addressed several KQs in the 2016 review. Trials enrolling over 600,000 women were conducted in the United States,^282^ Canada,^283^ United Kingdom,^284^ and Sweden.^285–287^ Across all trials, the mean or median screening intervention time ranged from 3.5 to 14.6 years, case accrual time from 7.0 to 17.4 years, and followup time from 11.2 to 21.9 years. To account for clinical heterogeneity and obtain clinically meaningful estimates, the analyses were stratified by age group (39 to 49 years, 50 to 59 years, 60 to 69 years, 70 to 74 years, or ≥75 years). Meta-analyses of breast cancer mortality outcomes using the longest followup data available indicated:

- For women ages 39 to 49 years, the combined RR for breast cancer mortality was 0.92 (95% CI, 0.75 to 1.02; 9 trials); absolute breast cancer mortality reduction was 2.9 (95% CI, −0.6 to 8.9) deaths prevented per 10,000 women over 10 years. None of the trials indicated statistically significantly reduced breast cancer mortality with screening, including the U.K. Age trial, the largest (N = 160,921) and most recent RCT designed specifically to determine the effectiveness of screening women in their 40s. Results of the U.K. Age trial included in the meta-analysis reflected 17.5 years of followup.^284^ A subsequent publication in 2020 indicated a similar lack of breast cancer mortality reduction after 22.8 years of followup (RR, 0.88 [95% CI, 0.74 to 1.03]).^77^
- For ages 50 to 59 years, the combined RR for breast cancer mortality was 0.86 (95% CI, 0.68 to 0.97; 7 trials); absolute breast cancer mortality reduction was 7.7 (95% CI, 1.6 to 17.2) deaths prevented per 10,000 women over 10 years.
- For ages 60 to 69 years, the combined RR for breast cancer mortality was 0.67 (95% CI, 0.54 to 0.83; 5 trials); absolute breast cancer mortality reduction was 21.3 (CI, 10.7 to 31.7) deaths prevented per 10,000 women over 10 years.
- Combining results across women ages 50 to 69 years indicated a RR of 0.78 (95% CI, 0.68 to 0.90; I^2^=41.0%; p=0.118).
- For ages 70 to 74 years, the combined RR for breast cancer mortality was 0.80 (CI, 0.51 to 1.28; 3 trials); absolute breast cancer mortality reduction was 12.5 (CI, −17.2 to 32.1). However, these estimates were limited by low numbers of events from only three trials that had smaller sample sizes of women in this age group.
- All-cause mortality was not reduced with screening for any age group.
- Mortality results by risk factors other than age or by screening intervals were not provided.

The screening trials reported several measures of intermediate breast cancer outcomes; however, most comparisons between screening and control groups provided results for relatively early stages of disease, rather than advanced stages. Meta-analyses of outcomes included:

- Combining estimates based on definitions corresponding to stage II disease or higher (stage II+, size ≥20 mm, 1+ positive lymph node) indicated no significant reductions in advanced disease for women ages 39 to 49 or 50 years and older.
- When thresholds were defined by the most severe disease categories available from the trials (stage III + IV disease, size ≥50 mm, 4+ positive lymph nodes), meta-analysis indicated no reductions for ages 39 to 49 years (RR, 0.98 [95% CI, 0.74 to 1.37]; 4 trials) but reduced risk of advanced cancer in the screening group for age 50 years and older (RR, 0.62 [95% CI, 0.46 to 0.83]; 3 trials).
- No RCTs evaluated the incidence of advanced breast cancer outcomes and treatment based on risk factors or screening intervals.

Observational studies of population-based mammography screening reported a wide range of reductions in breast cancer death. Most studies were conducted in Europe or the United Kingdom and included women ages 50 to 69 years. In general, observational studies reported greater breast cancer mortality reduction (25% to 31% among women invited to screening) than RCTs (19% to 22% using intention-to-treat analysis) for women ages 50 to 69 years. Two observational studies of women in their 40s invited to or participating in screening indicated 26 to 44 percent reduction in breast cancer mortality. Observational studies also reported mixed and varied results regarding detection of earlier versus later stage breast cancer with screening and were considered inconclusive. Similarly, studies of screening and treatment morbidity were inconclusive.

Studies comparing different screening modalities (digital mammography, tomosynthesis, ultrasound, or MRI) for women not at high risk for breast cancer did not report breast cancer specific or all-cause mortality outcomes. In studies comparing tomosynthesis and digital mammography versus mammography alone, detection rates were higher with tomosynthesis, but there were no differences in tumor size, stage, or node status.

## Screening Harms

Harms of screening summarized in the 2016 evidence review included false-positive and false-negative results, additional imaging, and biopsy; overdiagnosis; anxiety, distress, and other psychological responses; pain and discomfort; and radiation exposure.

Rates of false-positive and false-negative results, additional imaging, and biopsy were determined from a primary analysis of data from the BCSC specifically for the USPSTF that included regularly screened women in the United States using digital mammography based on results from a single screening round:^157^

- False-positive mammography rates were highest among women ages 40 to 49 years (121.2 per 1,000 women [95% CI, 105.6 to 138.7]) and declined with age. False-negative rates were low across all age groups (ages 40 to 49 years; 1.0 per 1,000 women [95% CI, 0.9 to 1.2]).
- Rates of recommendations for additional diagnostic imaging were highest among women ages 40 to 49 years (124.9 per 1,000 women [95% CI, 109.3 to 142.3]) and decreased with age, while rates of recommendations for biopsy did not differ between age groups (ages 40 to 49 years; 16.4 per 1,000 women [95% CI, 13.2 to 20.3]).
- Rates of invasive breast cancer were lowest among women ages 40 to 49 years (2.2 per 1,000 women [95% CI, 1.8 to 2.6]) and increased across age groups (P<0.001). For every case of invasive breast cancer detected by mammography screening in women ages 40 to 49 years, 464 women had screening mammography, 58 were recommended for additional diagnostic imaging, and 10 were recommended for biopsies. These estimates declined with age for all three outcomes, indicating lower number needed to screen to obtain harms for older women.
- False-positive and negative rates and recommendations for additional imaging and biopsy were generally higher, and measures of numbers needed to screen to obtain harms lower, for women with risk factors, although these varied slightly across age groups (first-degree relatives with breast cancer; heterogeneous breast density; previous benign biopsy; White or Hispanic race; premenopausal; low BMI).
- Rates of false-positive results, false-negative results, and recommendations for additional imaging did not differ in comparisons of time since the last mammography screening (9 to 18 months versus 19 to 30 months).

A published study of BCSC data that provided results of screening over a 10-year period indicated that when screening began at age 40 years, cumulative rates of false-positive mammography and benign biopsy results were higher for annual than biennial screening (mammography, 61% versus 42%; biopsy, 7% versus 5%).^145^ A second analysis of BCSC data reported that 10-year cumulative rates of false-positive mammography results and biopsy were highest among women with a family history of breast cancer, heterogeneously dense or extremely dense breasts, and combination hormone therapy use.^173^

In the few studies comparing screening modalities, four of five observational studies demonstrated statistically significantly lower rates of recall for tomosynthesis and mammography compared with mammography alone. A U.S. study comparing tomosynthesis and mammography with mammography alone reported a reduction of 16 recalls per 1,000 women and an increase in cancer detection of 1.2 cases per 1,000 women, but also an increase of 1.3 biopsies per 1,000 women. Another U.S. study reported a 38 percent reduction in recall rates when tomosynthesis was added to digital mammography versus mammography alone.

In an extensive literature described in the 2016 evidence review,^288^ estimates of overdiagnosis ranged from nonexistent to nearly 50 percent of diagnosed breast cancer cases. Methods for estimating overdiagnosis varied in many ways, particularly by the type of comparison groups, assumptions about lead time, and the denominator used to calculate rates. In general, most adjusted estimates of overdiagnosis based on trials ranged from 11 to 22 percent, while estimates based on observational studies ranged from 1 to 10 percent. Estimates from statistical models ranged from 0.4 to 50 percent.

No studies directly measured the association between radiation exposure from mammography screening and the incidence of breast cancer and death for film, digital, or tomosynthesis. Models calculate the number of deaths due to radiation-induced cancer using estimates for digital mammography is between 2 per 100,000 in women ages 50 to 59 years screened biennially and up to 11 per 100,000 in women ages 40 to 59 years screened annually.^289^

Appendix A Table 1 Summary of Mortality Reductions From Mammography Screening Compared With No Screening, by Age (Data From Nelson, 2016)

Age | Breast Cancer Mortality Reduction: Relative Risk (95% CI) | Deaths Prevented With Screening 10,000 Women Over 10 Years (95% CI)
39-49 years | 0.92 (0.75 to 1.02) | 2.9 (−0.6 to 8.9)
50-59 years | 0.86 (0.68 to 0.97) | 7.7 (1.6 to 17.2)
60-69 years | 0.67 (0.54 to 0.83) | 21.3 (10.7 to 31.7)
70-74 years | 0.80 (0.51 to 1.28) | 12.5 (−17.2 to 32.1)
50-69 years | 0.78 (0.68 to 0.90) | 12.5 (5.9 to 19.5)

Abbreviation: CI=confidence interval

Appendix A Table 2 Summary of Results: Estimated Benefits of Screening (Data From Nelson, 2016)

Age, years | Reduction in breast cancer deaths from RCTs; RR (95% CI)^*^ | Breast cancer deaths prevented per 10,000 over 10 years (95% CI)^*^ | Reduction in breast cancer deaths from observational studies; RR (95% CI) | Reduction in all-cause deaths from RCTs; RR (95% CI)^*^ | Reduction in advanced breast cancer from RCTs; RR (95% CI) | Reduction in treatment morbidity from RCTs; RR (95% CI)^†^
40-49 | 0.88 (0.73 to 1.003); 0.84 (0.70 to 1.002) | 4 (0 to 9) | 0.74 (0.66 to 0.83); 0.56 (0.45 to 0.67)^‡^ | 0.99 (0.94 to 1.06) | 0.98 (0.74 to 1.37) | Screening results in more mastectomies 1.20 (1.11 to 1.30) and radiation 1.32 (1.16 to 1.50); the majority of cases from screening are DCIS and early stage.
50-59 | 0.86 (0.68 to 0.97); 0.86 (0.69 to 1.007) | 5 to 8 (0 to 17) | | 1.02 (0.94 to 1.10) | | Screening results in more mastectomies 1.20 (1.11 to 1.30) and radiation 1.32 (1.16 to 1.50); the majority of cases from screening are DCIS and early stage.
60-69 | 0.67 (0.54 to 0.83); 0.67 (0.55 to 0.91) | 12 to 21 (3 to 32) | | 0.97 (0.90 to 1.04) | | Screening results in more mastectomies 1.20 (1.11 to 1.30) and radiation 1.32 (1.16 to 1.50); the majority of cases from screening are DCIS and early stage.
70-74 | 0.80 (0.51 to 1.28); 0.90 (0.46 to 1.78) | 12 to 13 (0 to 32) | | 0.98 (0.86 to 1.14) | | Screening results in more mastectomies 1.20 (1.11 to 1.30) and radiation 1.32 (1.16 to 1.50); the majority of cases from screening are DCIS and early stage.
50-69 | 0.78 (0.68 to 0.90); 0.81 (0.69 to 0.95) | 6 to 13 (1 to 20) | 0.75 (0.69 to 0.81)^§^; 0.69 (0.57 to 0.83)^║^ | | 0.62 (0.46 to 0.83)

* From meta-analyses of screening trials using two different methods of case accrual; long case accrual results are provided first, then short case accrual results.

† Based on trials of screening included in the meta-analysis.

‡ Based on a study in Sweden, and a study in Canada (standardized mortality ratio), respectively.

§ Based on seven incidence-based mortality studies.

║ Based on eight case-control studies.

Abbreviations: CI=confidence interval; DCIS=ductal carcinoma in situ; RCT=randomized, controlled trial; RR=relative risk.

Appendix A Table 3 Summary of Results: Estimated Harms of Screening (Data From Nelson, 2016)

Age, years | FP mammography^*^ | Additional imaging recommended^*^ | Biopsy recommended^*^ | 10-yr FP mammography rates (annual; biennial) | 10-yr FP biopsy rates (annual; biennial) | Over-diagnosis estimates from RCTs% (95% CI)^†^ | Over-diagnosis estimates from screening programs^‡^ | Radiation exposure
40-49 | 121.2 | 124.9 | 16.4 | 61%; 42% | 7%; 5% | 10.7 (9.3 to 12.2); 19.0 (15.2 to 22.7) | 0 to 54% unadjusted; 1 to 10% adjusted | Annual screening 40-55 years, biennial to 74 years: 86 cases, 11 deaths^§^
50-59 | 93.2 | 98.5 | 15.9 | 61%; 42% | 9%; 6% | 10.7 (9.3 to 12.2); 19.0 (15.2 to 22.7) | 0 to 54% unadjusted; 1 to 10% adjusted | Annual screening 40-55 years, biennial to 74 years: 86 cases, 11 deaths^§^
60-69 | 80.8 | 88.7 | 16.5 | | | 10.7 (9.3 to 12.2); 19.0 (15.2 to 22.7) | 0 to 54% unadjusted; 1 to 10% adjusted | Annual screening 40-55 years, biennial to 74 years: 86 cases, 11 deaths^§^
70-74 | 69.6 | 79.0 | 17.5 | | | 10.7 (9.3 to 12.2); 19.0 (15.2 to 22.7) | 0 to 54% unadjusted; 1 to 10% adjusted | Annual screening 40-55 years, biennial to 74 years: 86 cases, 11 deaths^§^

* Number per 1,000 screened per screening round.

† From meta-analysis of screening trials using two different methods of case accrual; long case accrual results are provided first, then short case accrual results.

‡ From EUROSCREEN review based on 13 studies overall and six studies adjusted for breast cancer risk and lead time.

§ From a model of digital mammography.

Abbreviations: CI=confidence interval; FP=false positive.