# References

1 Viswanathan M, Treiman KA, Kish-Doto J, Folic acid supplementation: an evidence review for the US Preventive Services Task Force. Evidence Synthesis No. 145. AHRQ publication 14-05214-EF-1. Rockville, MD: Agency for Healthcare Research and Quality. 2017.
2 Bibbins-Domingo K, Grossman DC, Curry SJ, Folic acid supplementation for the prevention of neural tube defects: US Preventive Services Task Force recommendation statement. JAMA 2017 Jan 10;317(2):183–9. doi: 10.1001/jama.2016.19438. PMID: 28097362.28097362
3 U.S. Preventive Services Task Force. Procedure Manual Section 4. Evidence review development. Rockville, MD: U.S. Preventive Services Task Force. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-section-4-evidence-review-development. Accessed 12 July 2023.
4 Williams J, Mai CT, Mulinare J, Updated estimates of neural tube defects prevented by mandatory folic Acid fortification - United States, 1995–2011. MMWR Morb Mortal Wkly Rep. 2015 Jan 16;64(1):1–5. PMID: 25590678.25590678
5 Viswanathan M, Treiman KA, Kish-Doto J, Folic acid supplementation for the prevention of neural tube defects: an updated evidence report and systematic review for the US Preventive Services Task Force. JAMA Neurol. 2017 Jan 10;317(2):190–203. doi: 10.1001/jama.2016.19193. PMID: 28097361.28097361
6 Zaganjor I, Sekkarie A, Tsang BL, Describing the prevalence of neural tube defects worldwide: a systematic literature review. PLoS One. 2016;11(4):e0151586. doi: 10.1371/journal.pone.0151586. PMID: 27064786.27064786
7 Institute of Medicine (US) Standing Committee on the Scientific Evaluation of Dietary Reference Intakes and its Panel on Folate. Standing committee on the scientific evaluation of dietary reference intakes and its panel on folate, other b vitamins, and choline. dietary reference intakes for thiamin, riboflavin, niacin, vitamin b6, folate, vitamin b12, pantothenic acid, biotin, and choline. Washington, DC: National Academies Press; 1998.
8 Copp AJ, Stanier P, Greene ND. Neural tube defects: recent advances, unsolved questions, and controversies. Lancet Neurol. 2013 Aug;12(8):799–810. doi: 10.1016/S1474-4422(13)70110-8. PMID: 23790957.23790957
9 Mai CT, Isenburg JL, Canfield MA, National population-based estimates for major birth defects, 2010–2014. Birth Defects Res. 2019 Nov 1;111(18):1420–35. doi: 10.1002/bdr2.1589. PMID: 31580536.31580536
10 Johnson CY, Honein MA, Dana Flanders W, Pregnancy termination following prenatal diagnosis of anencephaly or spina bifida: a systematic review of the literature. Birth Defects Res A Clin Mol Teratol. 2012 Nov;94(11):857–63. doi: 10.1002/bdra.23086. PMID: 23097374.23097374
11 Centers for Disease Control and Prevention. Spina bifida and anencephaly before and after folic acid mandate--United States, 1995–1996 and 1999–2000. MMWR Morb Mortal Wkly Rep. 2004 May 7;53(17):362–5. PMID: 15129193.15129193
12 Markovic I, Bosnjakovic P, Milenkovic Z. Occipital encephalocele: cause, incidence, neuroimaging and surgical management. Curr Pediatr Rev. 2020;16(3):200–5. doi: 10.2174/1573396315666191018161535. PMID: 31656152.31656152
13 Centers for Disease Control and Prevention (CDC). Spina bifida. Atlanta, GA: Centers for Disease Control and Prevention (CDC); 2021. https://www.cdc.gov/ncbddd/birthdefects/surveillancemanual/quick-reference-handbook/spinaBifida.html#:~:text=Spina%20bifida%20is%20an%20NTD,can%20be%2 0open%20or%20closed. Accessed 12 July 2023.
14 Centers for Disease Control and Prevention (CDC). Anencephaly. Atlanta, GA: Centers for Disease Control and Prevention (CDC); 2021. https://www.cdc.gov/ncbddd/birthdefects/surveillancemanual/quick-referencehandbook/anencephaly.html. Accessed 12 July 2023.
15 Centers for Disease Control and Prevention (CDC). Encephalocele. Atlanta, GA: Centers for Disease Control and Prevention (CDC); 2021. https://www.cdc.gov/ncbddd/birthdefects/surveillancemanual/quick-reference-handbook/encephalocele.html. Accessed 12 July 2023.
16 Adzick NS, Thom EA, Spong CY, A randomized trial of prenatal versus postnatal repair of myelomeningocele. N Engl J Med. 2011;364(11):993–1004. doi: 10.1056/NEJMoa1014379. PMID: 21306277.21306277
17 Grosse SD, Berry RJ, Mick Tilford J, Retrospective assessment of cost savings from prevention: folic acid fortification and spina bifida in the U.S. Am J Prev Med. 2016 May;50(5 Suppl 1):S74–S80. doi: 10.1016/j.amepre.2015.10.012. PMID: 26790341.26790341
18 Radcliff E, Cassell CH, Tanner JP, Hospital use, associated costs, and payer status for infants born with spina bifida. Birth Defects Res A Clin Mol Teratol. 2012 Dec;94(12):1044–53. doi: 10.1002/bdra.23084. PMID: 23115108.23115108
19 Murray CB, Holmbeck GN, Ros AM, A longitudinal examination of health-related quality of life in children and adolescents with spina bifida. J Pediatr Psychol. 2015 May;40(4):419–30. doi: 10.1093/jpepsy/jsu098. PMID: 25434043.25434043
20 Greene ND, Copp AJ. Neural tube defects. Annu Rev Neurosci. 2014;37:221–42. doi: 10.1146/annurev-neuro-062012-170354. PMID: 25032496.25032496
21 Copp AJ, Greene ND. Genetics and development of neural tube defects. J Pathol. 2010 Jan;220(2):217–30. doi: 10.1002/path.2643. PMID: 19918803.19918803
22 Prevention of neural tube defects: results of the Medical Research Council Vitamin Study. MRC Vitamin Study Research Group. Lancet. 1991 Jul 20;338(8760):131–7. PMID: 1677062.1677062
23 Beaudin AE, Stover PJ. Insights into metabolic mechanisms underlying folate-responsive neural tube defects: a minireview. Birth Defects Res A Clin Mol Teratol. 2009 Apr;85(4):274–84. doi: 10.1002/bdra.20553. PMID: 19180567.19180567
24 Shane B, Pangilinan F, Mills JL, The 677C→T variant of MTHFR is the major genetic modifier of biomarkers of folate status in a young, healthy Irish population. Am J Clin Nutr. 2018 2018/12//;108(6):1334–41. doi: 10.1093/ajcn/nqy209. PMID: 30339177.30339177
25 Li J, Feng D, He S, Association of MTHFR 677C > T gene polymorphism with neonatal defects: a meta-analysis of 81444 subjects. J Obstet Gynaecol. 2022 Aug;42(6):1811–22. doi: 10.1080/01443615.2022.2039908. PMID: 35282788.35282788
26 Tsang BL, Devine OJ, Cordero AM, Assessing the association between the methylenetetrahydrofolate reductase (MTHFR) 677C>T polymorphism and blood folate concentrations: a systematic review and meta-analysis of trials and observational studies. Am J Clin Nutr. 2015 Jun;101(6):1286–94. doi: 10.3945/ajcn.114.099994. PMID: 25788000.25788000
27 de Franchis R, Botto LD, Sebastio G, Spina bifida and folate-related genes: a study of gene-gene interactions. Genet Med. 2002 May-Jun;4(3):126–30. doi: 10.1097/00125817-200205000-00005. PMID: 12180146.12180146
28 Crider KS, Zhu JH, Hao L, MTHFR 677C->T genotype is associated with folate and homocysteine concentrations in a large, population-based, double-blind trial of folic acid supplementation. Am J Clin Nutr. 2011 Jun;93(6):1365–72. doi: 10.3945/ajcn.110.004671. PMID: 21508090.21508090
29 Crider KS, Devine O, Hao L, Population red blood cell folate concentrations for prevention of neural tube defects: bayesian model. BMJ. 2014;349:g4554. doi: 10.1136/bmj.g4554. PMID: 25073783.25073783
30 Garne E, Loane M, Dolk H, Spectrum of congenital anomalies in pregnancies with pregestational diabetes. Birth Defects Res A Clin Mol Teratol. 2012 Mar;94(3):134–40. doi: 10.1002/bdra.22886. PMID: 22371321.22371321
31 Anderson JL, Waller DK, Canfield MA, Maternal obesity, gestational diabetes, and central nervous system birth defects. Epidemiology. 2005;16(1):87–92.15613950
32 Racusin D, Stevens B, Campbell G, Obesity and the risk and detection of fetal malformations. Semin Perinatol. 2012 Jun;36(3):213–21. doi: 10.1053/j.semperi.2012.05.001. PMID: 22713503.22713503
33 Hernandez-Diaz S, Werler MM, Walker AM, Neural tube defects in relation to use of folic acid antagonists during pregnancy. Am J Epidemiol. 2001 May 15;153(10):961–8. PMID: 11384952.11384952
34 Dreier JW, Andersen AM, Berg-BeckhoffG. Systematic review and meta-analyses: fever in pregnancy and health impacts in the offspring. Pediatrics. 2014 Mar;133(3):e674–88. doi: 10.1542/peds.2013-3205. PMID: 24567014.24567014
35 Agopian AJ, Tinker SC, Lupo PJ, Proportion of neural tube defects attributable to known risk factors. Birth Defects Res A Clin Mol Teratol. 2013 Jan;97(1):42–6. PMID: 23427344.23427344
36 Lupo PJ, Canfield MA, Chapa C, Diabetes and obesity-related genes and the risk of neural tube defects in the national birth defects prevention study. Am J Epidemiol. 2012 15 December;176(12):1101–9.23132673
37 Wasserman CR, Shaw GM, Selvin S, Socioeconomic status, neighborhood social conditions, and neural tube defects. Am J Public Health. 1998 Nov;88(11):1674–80. doi: 10.2105/ajph.88.11.1674. PMID: 9807535.9807535
38 Grewal J, Carmichael SL, Song J, Neural tube defects: an analysis of neighbourhood- and individual-level socio-economic characteristics. Paediatr Perinat Epidemiol. 2009 Mar;23(2):116–24. doi: 10.1111/j.1365-3016.2008.00992.x. PMID: 19159398.19159398
39 Marchetta CM, Hamner HC. Blood folate concentrations among women of childbearing age by race/ethnicity and acculturation, NHANES 2001–2010. Matern Child Nutr. 2016 Jan;12(1):39–50. doi: 10.1111/mcn.12134. PMID: 24934272.24934272
40 Feuchtbaum LB, Currier RJ, Riggle S, Neural tube defect prevalence in California (1990–1994): eliciting patterns by type of defect and maternal race/ethnicity. Genet Test. 1999;3(3):265–72. doi: 10.1089/109065799316572. PMID: 10495925.10495925
41 Ray JG, Vermeulen MJ, Meier C, Maternal ethnicity and risk of neural tube defects: a population-based study. CMAJ. 2004 Aug 17;171(4):343–5. doi: 10.1503/cmaj.1040254. PMID: 15313993.15313993
42 Williams LJ, Rasmussen SA, Flores A, Decline in the prevalence of spina bifida and anencephaly by race/ethnicity: 1995–2002. Pediatrics. 2005 Sep;116(3):580–6. doi: 10.1542/peds.2005-0592. PMID: 16140696.16140696
43 Centers for Disease Control and Prevention. Racial/ethnic differences in the birth prevalence of spina bifida - United States, 1995–2005. MMWR Morb Mortal Wkly Rep. 2009 Jan 9;57(53):1409–13. PMID: 19129744.19129744
44 Tinker SC, Devine O, Mai C, Estimate of the potential impact of folic acid fortification of corn masa flour on the prevention of neural tube defects. Birth Defects Res A Clin Mol Teratol. 2013 Oct;97(10):649–57. doi: 10.1002/bdra.23158. PMID: 24142499.24142499
45 Wang A, Rose CE, Qi YP, Impact of voluntary folic acid fortification of corn masa flour on RBC folate concentrations in the U.S. (NHANES 2011–2018). Nutrients. 2021 Apr 16;13(4). doi: 10.3390/nu13041325. PMID: 33923768.33923768
46 Field MS, Stover PJ. Safety of folic acid. Ann N Y Acad Sci. 2018 Feb;1414(1):59–71. doi: 10.1111/nyas.13499. PMID: 29155442.29155442
47 Crider KS, Qi YP, Devine O, Modeling the impact of folic acid fortification and supplementation on red blood cell folate concentrations and predicted neural tube defect risk in the United States: have we reached optimal prevention? Am J Clin Nutr. 2018 Jun 1;107(6):1027–34. doi: 10.1093/ajcn/nqy065. PMID: 29767673.29767673
48 Qi YP, Do AN, Hamner HC, The prevalence of low serum vitamin B-12 status in the absence of anemia or macrocytosis did not increase among older U.S. adults after mandatory folic acid fortification. J Nutr. 2014 Feb;144(2):170–6. doi: 10.3945/jn.113.183095. PMID: 24306216.24306216
49 Wiens D, DeSoto MC. Is high folic acid intake a risk factor for autism?-A review. Brain Sci. 2017 Nov 10;7(11):149. doi: 10.3390/brainsci7110149. PMID: 29125540.29125540
50 European Food Safety Authority (EFSA). EFSA meeting summary report. Uppsala, Sweden: European Food Safety Authority (EFSA),; 2009. Accessed 12 April 2022.
51 Imbard A, Benoist JF, Blom HJ. Neural tube defects, folic acid and methylation. Int J Environ Res Public Health. 2013 Sep 17;10(9):4352–89. doi: 10.3390/ijerph10094352. PMID: 24048206.24048206
52 Oregon State University. Folate. Corvallis, OR: Linus Pauling Institute, Oregon State University; 2021. https://lpi.oregonstate.edu/mic/vitamins/folate. Accessed 12 July 2023.
53 Wilson RD, Genetics C, Wilson RD, Pre-conception folic acid and multivitamin supplementation for the primary and secondary prevention of neural tube defects and other folic acid-sensitive congenital anomalies. J Obstet Gynaecol Can. 2015 Jun;37(6):534–52. doi: 10.1016/s1701-2163(15)30230-9. PMID: 26334606.26334606
54 National Institutes of Health. Folate. Fact sheet for health professionals. Washington, DC: National Institutes of Health; 2021. https://ods.od.nih.gov/factsheets/FolateHealthProfessional/ Accessed 12 July 2023.
55 Centers for Disease Control and Prevention (CDC). MTHFR gene, folic acid, and preventing neural tube defects. Atlanta, GA: Centers for Disease Control and Prevention (CDC); 2020. https://www.cdc.gov/ncbddd/folicacid/mthfr-gene-and-folicacid.html#bread-pasta-cooked. Accessed 12 July 2023.
56 Stover PJ. Physiology of folate and vitamin B12 in health and disease. Nutr Rev. 2004 Jun;62(6 Pt 2):S3–12; discussion S3. doi: 10.1111/j.1753-4887.2004.tb00070.x. PMID: 15298442.15298442
57 Chen MY, Rose CE, Qi YP, Defining the plasma folate concentration associated with the red blood cell folate concentration threshold for optimal neural tube defects prevention: a population-based, randomized trial of folic acid supplementation. Am J Clin Nutr. 2019 May 1;109(5):1452–61. doi: 10.1093/ajcn/nqz027. PMID: 31005964.31005964
58 World Health Organization. Guideline: optimal serum and red blood cell folate concentrations in women of reproductive age for prevention of neural tube defects. World Health Organization. Geneva. 2015.
59 Bailey RL, Dodd KW, Gahche JJ, Total folate and folic acid intake from foods and dietary supplements in the United States: 2003–2006. Am J Clin Nutr. 2010 Jan;91(1):231–7. doi: 10.3945/ajcn.2009.28427. PMID: 19923379.19923379
60 Rosenberg KD, Gelow JM, Sandoval AP. Pregnancy intendedness and the use of periconceptional folic acid. Pediatrics. 2003 May;111(5 Pt 2):1142–5. PMID: 12728127.12728127
61 Wong EC, Rose CE, Flores AL, Trends in multivitamin use among women of reproductive age: United States, 2006–2016. J Womens Health (Larchmt). 2019 Jan;28(1):37–45. doi: 10.1089/jwh.2018.7075. PMID: 30620242.30620242
62 Mukhtar A, Kramer MR, Oakley GP Jr., Race and ethnicity and preconception folic acid supplement use among pregnant women in Georgia, PRAMS 2009 to 2011. Birth Defects Res. 2017 Jan 20;109(1):38–48. doi: 10.1002/bdra.23597. PMID: 27905191.27905191
63 Orozco AM, Yeung LF, Guo J, Characteristics of U.S. adults with usual daily folic acid intake above the tolerable upper intake level: National Health and Nutrition Examination Survey, 2003–2010. Nutrients. 2016 Apr 1;8(4):195. doi: 10.3390/nu8040195. PMID: 27043623.27043623
64 Centers for Disease Control and Prevention. From the Centers for Disease Control and Prevention. Recommendations for use of folic acid to reduce number of spina bifida cases and other neural tube defects. JAMA. 1993 Mar 10;269(10):1233, 6–8. PMID: 8437292.8437292
65 American College of Obstetricians and Gynecologists. Prepregnancy counseling. Number 762. Washington, DC: American College of Obstetricians and Gynecologists; 2019. https://www.acog.org/clinical/clinical-guidance/committee-opinion/articles/2019/01/prepregnancy-counseling. Accessed 12 July 2023.
66 American Academy of Pediatrics. Committee on Genetics. Folic acid for the prevention of neural tube defects. Pediatrics. 1999 Aug;104(2 Pt 1):325–7. PMID: 10429019.10429019
67 Zolotor AJ, Carlough MC. Update on prenatal care. Am Fam Physician. 2014 Feb 1;89(3):199–208. PMID: 24506122.24506122
68 Institute of Medicine (US) Standing Committee on the Scientific Evaluation of Dietary Reference Intakes and its Panel on Folate, Other B Vitamins, and Choline. Dietary reference intakes for thiamin, riboflavin, niacin, vitamin B6, folate, vitamin B12, pantothenic acid, biotin, and choline. Washington, DC: National Academies Press; 1998.
69 National Institute for Health and Care Excellence. NICE public health guidance: PH11 maternal and child nutrition. London: NICE; 2008.
70 National Institute for Health and Care Excellence (NICE). Maternal and child nutrition: folic acid, recommendation 2. London: National Institute for Health and Care Excellence; n.d. https://www.nice.org.uk/guidance/ph11/chapter/4-recommendations#folic-acid-2. Accessed 12 July 2023.
71 U.S. Preventive Services Task Force. Folic Acid Supplementation for the Prevention of Neural Tube Defects: Recommendation Statement. Am Fam Physician. 2017 May 15;95(10):Online. PMID: 28671401.28671401
72 Yang Q, Cogswell ME, Hamner HC, Folic acid source, usual intake, and folate and vitamin B-12 status in US adults: National Health and Nutrition Examination Survey (NHANES) 2003–2006. Am J Clin Nutr. 2010 Jan;91(1):64–72. doi: 10.3945/ajcn.2009.28401. PMID: 19828716.19828716
73 Finer LB, Zolna MR. Declines in unintended pregnancy in the United States, 2008–2011. N Engl J Med. 2016 Mar 3;374(9):843–52. doi: 10.1056/NEJMsa1506575. PMID: 26962904.26962904
74 U.S. Preventive Services Task Force. Folic acid for the prevention of neural tube defects: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009 May 5;150(9):626–31. doi: 10.7326/0003-4819-150-9-200905050-00009. PMID: 19414842.19414842
75 Czeizel AE, Dudas I. Prevention of the first occurrence of neural-tube defects by periconceptional vitamin supplementation. N Engl J Med. 1992 Dec 24;327(26):1832–5. doi: 10.1056/nejm199212243272602. PMID: 1307234.1307234
76 Czeizel AE. Prevention of congenital abnormalities by periconceptional multivitamin supplementation. BMJ. 1993 Jun 19;306(6893):1645–8. PMID: 8324432.8324432
77 Czeizel AE, Metneki J, Dudas I. The higher rate of multiple births after periconceptional multivitamin supplementation: an analysis of causes. Acta Genet Med Gemellol (Roma). 1994;43(3–4):175–84. PMID: 8588492.8588492
78 Czeizel AE, Dudas I, Metneki J. Pregnancy outcomes in a randomised controlled trial of periconceptional multivitamin supplementation. Final report. Arch Gynecol Obstet. 1994;255(3):131–9. PMID: 7979565.7979565
79 Czeizel AE. Controlled studies of multivitamin supplementation on pregnancy outcomes. Ann N Y Acad Sci. 1993 Mar 15;678:266–75. PMID: 8257482.8257482
80 Czeizel AE. Reduction of urinary tract and cardiovascular defects by periconceptional multivitamin supplementation. Am J Med Genet. 1996 Mar 15;62(2):179–83. doi: 10.1002/(sici)1096-8628(19960315)62:2<179::aid-ajmg12>3.0.co;2-1. PMID: 8882400.8882400
81 Czeizel AE. Periconceptional folic acid containing multivitamin supplementation. Eur J Obstet Gynecol Reprod Biol. 1998 Jun;78(2):151–61. PMID: 9622312.9622312
82 Czeizel AE, Dobo M, Vargha P. Hungarian cohort-controlled trial of periconceptional multivitamin supplementation shows a reduction in certain congenital abnormalities. Birth Defects Res A Clin Mol Teratol. 2004 Nov;70(11):853–61. doi: 10.1002/bdra.20086. PMID: 15523663.15523663
83 Milunsky A, Jick H, Jick SS, Multivitamin/folic acid supplementation in early pregnancy reduces the prevalence of neural tube defects. JAMA. 1989 Nov 24;262(20):2847–52. PMID: 2478730.2478730
84 Moore LL, Bradlee ML, Singer MR, Folate intake and the risk of neural tube defects: an estimation of dose-response. Epidemiology. 2003 Mar;14(2):200–5. doi: 10.1097/01.ede.0000040253.12446.b2. PMID: 12606886.12606886
85 Werler MM, Shapiro S, Mitchell AA. Periconceptional folic acid exposure and risk of occurrent neural tube defects. Jama. 1993 Mar 10;269(10):1257–61. PMID: 8437302.8437302
86 Shaw GM, Schaffer D, Velie EM, Periconceptional vitamin use, dietary folate, and the occurrence of neural tube defects. Epidemiology. 1995 May;6(3):219–26. PMID: 7619926.7619926
87 Mills JL, Rhoads GG, Simpson JL, The absence of a relation between the periconceptional use of vitamins and neural-tube defects. National Institute of Child Health and Human Development Neural Tube Defects Study Group. N Engl J Med. 1989 Aug 17;321(7):430–5. doi: 10.1056/nejm198908173210704. PMID: 2761577.2761577
88 Suarez L, Hendricks KA, Cooper SP, Neural tube defects among Mexican Americans living on the US-Mexico border: effects of folic acid and dietary folate. Am J Epidemiol. 2000 Dec 1;152(11):1017–23. PMID: 11117610.11117610
89 Ahrens K, Yazdy MM, Mitchell AA, Folic acid intake and spina bifida in the era of dietary folic acid fortification. Epidemiology. 2011 Sep;22(5):731–7. doi: 10.1097/EDE.0b013e3182227887. PMID: 21659881.21659881
90 Mosley BS, Cleves MA, Siega-Riz AM, Neural tube defects and maternal folate intake among pregnancies conceived after folic acid fortification in the United States. Am J Epidemiol. 2009 Jan 1;169(1):9–17. doi: 10.1093/aje/kwn331. PMID: 18953063.18953063
91 United Nations Development Programme (UNDP). Human development report 2020: the next frontier human development and the Anthropocene. 0969-4501 New York, NY. 2020.
92 Gildestad T, Øyen N, Klungsøyr K, Maternal use of folic acid supplements and infant risk of neural tube defects in Norway 1999–2013. Scand J Public Health. 2016 Aug;44(6):619–26. doi: 10.1177/1403494816649494. PMID: 27206771.27206771
93 Gildestad T, Bjørge T, Haaland Ø A, Maternal use of folic acid and multivitamin supplements and infant risk of birth defects in Norway, 1999–2013. Br J Nutr. 2020 Aug 14;124(3):316–29. doi: 10.1017/s0007114520001178. PMID: 32238218.32238218
94 Nishigori H, Obara T, Nishigori T, Preconception folic acid supplementation use and the occurrence of neural tube defects in Japan: A nationwide birth cohort study of the Japan Environment and Children's Study. Congenit Anom (Kyoto). 2019 Jul;59(4):110–7. doi: 10.1111/cga.12293. PMID: 29900595.29900595
95 Petersen JM, Parker SE, Benedum CM, Periconceptional folic acid and risk for neural tube defects among higher risk pregnancies. Birth Defects Res. 2019 Nov 15;111(19):1501–12. doi: 10.1002/bdr2.1579. PMID: 31433116.31433116
96 Bortolus R, Filippini F, Cipriani S, Efficacy of 4.0 mg versus 0.4 mg folic acid supplementation on the reproductive outcomes: a randomized controlled trial. Nutrients. 2021;13(12). doi: 10.3390/nu13124422. PMID: CN-02347908.
97 Mortensen JH, Øyen N, Fomina T, Supplemental folic acid in pregnancy and maternal cancer risk. Cancer Epidemiol. 2015 Dec;39(6):805–11. doi: 10.1016/j.canep.2015.10.009. PMID: 26569032.26569032
98 Strom M, Granstrom C, Lyall K, Research Letter: Folic acid supplementation and intake of folate in pregnancy in relation to offspring risk of autism spectrum disorder. Psychol Med. 2018 Apr;48(6):1048–54. doi: 10.1017/S0033291717002410. PMID: 28946926.28946926
99 Virk J, Liew Z, Olsen J, Preconceptional and prenatal supplementary folic acid and multivitamin intake and autism spectrum disorders. Autism. 2016 Aug;20(6):710–8. doi: 10.1177/1362361315604076. PMID: 26408631.26408631
100 Suren P, Roth C, Bresnahan M, Association between maternal use of folic acid supplements and risk of autism spectrum disorders in children. JAMA. 2013 Feb 13;309(6):570–7. doi: 10.1001/jama.2012.155925. PMID: 23403681.23403681
101 DeVilbiss EA, Magnusson C, Gardner RM, Antenatal nutritional supplementation and autism spectrum disorders in the Stockholm youth cohort: population based cohort study. BMJ. 2017 Oct 4;359:j4273. doi: 10.1136/bmj.j4273. PMID: 28978695.28978695
102 Nilsen RM, Suren P, Gunnes N, Analysis of self-selection bias in a population-based cohort study of autism spectrum disorders. Paediatr Perinat Epidemiol. 2013 Nov;27(6):553–63. doi: 10.1111/ppe.12077. PMID: 23919580.23919580
103 Levine SZ, Kodesh A, Viktorin A, Association of maternal use of folic acid and multivitamin supplements in the periods before and during pregnancy with the risk of autism spectrum disorder in offspring. JAMA Psychiatry. 2018 Feb 1;75(2):176–84. doi: 10.1001/jamapsychiatry.2017.4050. PMID: 29299606.29299606
104 Sharman Moser S, Davidovitch M, Rotem RS, High dose folic acid during pregnancy and the risk of autism; the birth order bias: a nested case-control study. Reprod Toxicol. 2019 Oct;89:173–7. doi: 10.1016/j.reprotox.2019.07.083. PMID: 31376478.31376478
105 Slone Epidemiology Center. Pregnancy health interview study (birth defects study). Boston, MA Slone Epidemiology Center; (n.d.). https://www.bu.edu/slone/research/studies/phis/. Accessed 12 July 2023.
106 Moseson H, Zazanis N, Goldberg E, The imperative for transgender and gender nonbinary inclusion: beyond women's health. Obstet Gynecol. 2020 May;135(5):1059–68. doi: 10.1097/AOG.0000000000003816. PMID: 32282602.32282602
107 Community Preventive Services Task Force. Pregnancy health: community-wide campaigns to promote the use of folic acid supplements Community Preventive Services Task Force; May 10. 2019. https://www.thecommunityguide.org/sites/default/files/assets/Pregnancy-Health-Folic-Acid-Community-Wide-Campaigns.pdf
108 Gaskins AJ, Chavarro JE. Diet and fertility: a review. Am J Obstet Gynecol. 2018 Apr;218(4):379–89. doi: 10.1016/j.ajog.2017.08.010. PMID: 28844822.28844822
109 Berry RJ, Li Z, Erickson JD, Prevention of neural-tube defects with folic acid in China. China-U.S. Collaborative Project for Neural Tube Defect Prevention. N Engl J Med. 1999 Nov 11;341(20):1485–90. doi: 10.1056/NEJM199911113412001. PMID: 10559448.10559448
110 Wolff T, Witkop CT, Miller T, Folic acid supplementation for the prevention of neural tube defects: an update of the evidence for the U.S. preventive services task force. Annals of internal medicine. 2009;150(9):632‐9. PMID: CN-01779140.19414843
111 Wolff T, Witkop CT, Miller T, Folic Acid Supplementation for the Prevention of Neural Tube Defects: An Update of the Evidence for the U.S. Preventive Services Task Force. Rockville (MD); 2009.
112 Vollset SE, Gjessing HK, Tandberg A, Folate supplementation and twin pregnancies. Epidemiology. 2005 Mar;16(2):201–5. PMID: 15703534.15703534
113 Yang L, Jiang L, Bi M, High dose of maternal folic acid supplementation is associated to infant asthma. Food Chem Toxicol. 2015 Jan;75:88–93. doi: 10.1016/j.fct.2014.11.006. PMID: 25449200.25449200
114 Wang T, Zhang HP, Zhang X, Is Folate Status a Risk Factor for Asthma or Other Allergic Diseases? Allergy Asthma Immunol Res. 2015 Nov;7(6):538–46. doi: 10.4168/aair.2015.7.6.538. PMID: 26333700.26333700
115 Crider KS, Cordero AM, Qi YP, Prenatal folic acid and risk of asthma in children: a systematic review and meta-analysis. Am J Clin Nutr. 2013 Nov;98(5):1272–81. doi: 10.3945/ajcn.113.065623. PMID: 24004895.24004895
116 Bekkers MB, Elstgeest LE, Scholtens S, Maternal use of folic acid supplements during pregnancy, and childhood respiratory health and atopy. Eur Respir J. 2012 Jun;39(6):1468–74. doi: 10.1183/09031936.00094511. PMID: 22034647.22034647
117 Dunstan JA, West C, McCarthy S, The relationship between maternal folate status in pregnancy, cord blood folate levels, and allergic outcomes in early childhood. Allergy. 2012 Jan;67(1):50–7. doi: 10.1111/j.1398-9995.2011.02714.x. PMID: 21923665.21923665
118 Granell R, Heron J, Lewis S, The association between mother and child MTHFR C677T polymorphisms, dietary folate intake and childhood atopy in a population-based, longitudinal birth cohort. Clin Exp Allergy. 2008 Feb;38(2):320–8. doi: 10.1111/j.1365-2222.2007.02902.x. PMID: 18070159.18070159
119 Haberg SE, London SJ, Stigum H, Folic acid supplements in pregnancy and early childhood respiratory health. Arch Dis Child. 2009 Mar;94(3):180–4. doi: 10.1136/adc.2008.142448. PMID: 19052032.19052032
120 Kiefte-de Jong JC, Timmermans S, Jaddoe VW, High circulating folate and vitamin B-12 concentrations in women during pregnancy are associated with increased prevalence of atopic dermatitis in their offspring. J Nutr. 2012 Apr;142(4):731–8. doi: 10.3945/jn.111.154948. PMID: 22399526.22399526
121 Magdelijns FJ, Mommers M, Penders J, Folic acid use in pregnancy and the development of atopy, asthma, and lung function in childhood. Pediatrics. 2011 Jul;128(1):e135–44. doi: 10.1542/peds.2010-1690. PMID: 21690114.21690114
122 Martinussen MP, Risnes KR, Jacobsen GW, Folic acid supplementation in early pregnancy and asthma in children aged 6 years. Am J Obstet Gynecol. 2012 Jan;206(1):72.e1-7. doi: 10.1016/j.ajog.2011.07.033. PMID: 21982024.21982024
123 Whitrow MJ, Moore VM, Rumbold AR, Effect of supplemental folic acid in pregnancy on childhood asthma: a prospective birth cohort study. Am J Epidemiol. 2009 Dec 15;170(12):1486–93. doi: 10.1093/aje/kwp315. PMID: 19880541.19880541
124 Institute of Medicine (US) Panel on Micronutrients. Dietary reference intakes for vitamin A, vitamin K, arsenic, boron, chromium, copper, iodine, iron, manganese, molybdenum, nickel, silicon, vanadium, and zinc. Washington, DC: The National Academies Press; 2001.
125 O'Keefe CA, Bailey LB, Thomas EA, Controlled dietary folate affects folate status in nonpregnant women. J Nutr. 1995 Oct;125(10):2717–25. doi: 10.1093/jn/125.10.2717. PMID: 7562109.7562109
126 Herbert V. Experimental nutritional folate deficiency in man. Trans Assoc Am Physicians. 1962;75:307–20. PMID: 13953904.13953904
127 Eichner ER, Pierce HI, Hillman RS. Folate balance in dietary-induced megaloblastic anemia. N Engl J Med. 1971 Apr 29;284(17):933–8. doi: 10.1056/NEJM197104292841702. PMID: 5551802.5551802
128 Hoffbrand AV, Newcombe FA, Mollin DL. Method of assay of red cell folate activity and the value of the assay as a test for folate deficiency. J Clin Pathol. 1966 Jan;19(1):17–28. doi: 10.1136/jcp.19.1.17. PMID: 5904976.5904976
129 Varadi S, Abbott D, Elwis A. Correlation of peripheral white cell and bone marrow changes with folate levels in pregnancy and their clinical significance. J Clin Pathol. 1966 Jan;19(1):33–6. doi: 10.1136/jcp.19.1.33. PMID: 5904979.5904979
130 European Food Safety Authority (EFSA). Scientific opinion on dietary reference values for folate. Parma, Italy; 2015. https://efsa.onlinelibrary.wiley.com/doi/pdf/10.2903/j.efsa.2014.3893. Accessed 12 July 2023.
131 de Benoist B. Conclusions of a WHO Technical Consultation on folate and vitamin B12 deficiencies. Food Nutr Bull. 2008 Jun;29(2 Suppl):S238–44. doi: 10.1177/15648265080292S129. PMID: 18709899.18709899
132 Viswanathan M, Treiman KA, Doto JK, Folic acid supplementation: an evidence review for the U.S. Preventive Services Task Force. Agency for Healthcare Research and Quality. Report No.: 14-05214-EF-1. Rockville, MD. 2017. https://www.ncbi.nlm.nih.gov/books/NBK410113/
133 Abe M. Effects of folic acid supplement intake during pregnancy on food allergy onset in female children. Allergy: European Journal of Allergy and Clinical Immunology. 2019;74:562–3. doi: 10.1111/all.13961.
134 Alfonso VH, Bandoli G, von Ehrenstein O, Early folic acid supplement initiation and risk of adverse early childhood respiratory health: a population-based study. Matern Child Health J. 2018 Jan;22(1):111–9. doi: 10.1007/s10995-017-2360-6. PMID: 28887720.28887720
135 Bjørk M, Riedel B, Spigset O, Association of folic acid supplementation during pregnancy with the risk of autistic traits in children exposed to antiepileptic drugs in utero. JAMA Neurol. 2018 Feb 1;75(2):160–8. doi: 10.1001/jamaneurol.2017.3897. PMID: 29279889.29279889
136 den Dekker HT, Jaddoe VW V, Reiss IK, Maternal folic acid use during pregnancy, methylenetetrahydrofolate reductase gene polymorphism, and child's lung function and asthma. Clin Exp Allergy. 2018 Feb;48(2):175–85. doi: 10.1111/cea.13056. PMID: 29117460.29117460
137 Hoang TT, Lei Y, Mitchell LE, Maternal lactase polymorphism (rs4988235) is associated with neural tube defects in offspring in the National Birth Defects Prevention Study. J Nutr. 2019 Feb 1;149(2):295–303. doi: 10.1093/jn/nxy246. PMID: 30689919.30689919
138 Jenkins MM, Reefhuis J, Herring AH, Impact of sample collection participation on the validity of estimated measures of association in the National Birth Defects Prevention Study when assessing gene-environment interactions. Genet Epidemiol. 2017 Dec;41(8):834–43. doi: 10.1002/gepi.22088. PMID: 29071735.29071735
139 Kondo A, Morota N, Date H, Awareness of folic acid use increases its consumption, and reduces the risk of spina bifida. Br J Nutr. 2015 Jul 14;114(1):84–90. doi: 10.1017/s0007114515001439. PMID: 25999131.25999131
140 Ozer A, Ozer S, Kanat-Pektas M, How does folic acid supplementation affect serum folate concentrations in pregnant Turkish women? Journal of Clinical and Analytical Medicine. 2016;7(4):538–41. doi: 10.4328/JCAM.4391.
141 Socha-Banasiak A, Kamer B, Pacześ K, Trends in folic acid supplementation during pregnancy - the effect on allergy development in children. Postepy Dermatol Alergol. 2018 Apr;35(2):139–44. doi: 10.5114/pdia.2017.68785. PMID: 29760612.29760612
142 Tsai Z, Huang Y, Huang Y, Maternal folic acid supplementation during pregnancy in relation to childhood rhinitis: a cohort study in Taiwan. Allergy: European Journal of Allergy and Clinical Immunology. 2018;73:679. doi: 10.1111/all.13539.