# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Justin Mills, MD, MPH, AHRQ Medical Officer; Tina Fan, MD, MPH, previous Associate Scientific Director and Tracy Wolff, MD, MPH, Scientific Director, AHRQ, U.S. Preventive Services Task Force (USPSTF) Program; current and former members of the USPSTF; external peer reviewers Nancy Rose, MD, University of Utah; Jorge Chavarro, MD, ScD, Harvard University; and Kimberly Gregory, MD, MPH, Cedars-Sinai Medical Center; federal partner reviewers (Centers for Disease Control and Prevention, National Institutes of Health); RTI International–University of North Carolina EPC staff: Christiane Voisin, MSLS, research librarian; Roberta Wines, MPH, and Carol Woodell, BSPH, current and former EPC Program Managers; Nila Sathe, MA, MLIS, quality assurance; Sharon Barrell, MA, editor; and Teyonna Downing, publications specialist.