# Chapter 4 Discussion

## Summary of Evidence

Since the previous review on this topic, new observational studies were published on the effects of folic acid supplementation on NTDs (3 analyses), maternal cancer (1 analysis), and ASD (7 analyses). This update was limited to summarizing only new evidence and does not incorporate the foundational evidence leading the USPSTF’s current A recommendation for this topic. This recommendation was based on experimental and observational studies conducted in settings without or before food fortification demonstrating a reduction in NTDs and no evidence of harms at usual doses.

Once the benefits of folic acid supplementation were widely known and fortification of the food supply was initiated in some countries, ethical and logistical constraints have precluded the conduct of trials comparing folic acid supplementation with no supplementation. Since then, studies have relied on cohort and case-control designs with greater potential bias than in randomized trials, both from selection bias (e.g., inability to include pregnancy terminations, other unmeasured confounding) and potential misclassification of exposure (from poor or differential recall of exposure). In the prior review, the results from these observational studies inconsistently demonstrated benefit but have not demonstrated any harms. The overall conclusions from this limited update are consistent with those of the prior review in demonstrating some evidence of benefit for NTDs and no evidence of harm (Table 3) for autism and maternal cancer; we found no newly eligible studies on previously reported harms of multiple gestation, childhood respiratory conditions, and maternal adverse events. We found no evidence to suggest that benefits for NTDs varied by timing, duration, and dose of folic acid exposure.

Table 3 Summary of Evidence

Key Question | Foundational Evidence: N of Studies (Study Designs); N of Participants | Rationale and Foundational Evidence | Limitations of the Foundational Evidence | New Evidence: N of Studies (Study Designs); N of Participants | New Evidence Findings | Limitations of New Evidence | Consistency of New Evidence With Foundational Evidence
KQ1a: Effects of folic acid supplements on the risk of NTDs | 12 (1 ROT,^75–81^ 2 cohort studies,^82–84^ 8 case-control studies,^33,^ ^35,^ ^85–90,^ ^110^1 previous review);^110,^ ^111^N>41,802 | Generally consistent evidence within the prefortification (indicating benefit) and postfortification eras (no statistically significant differences), inconsistent over time; One RCT (prefortification): Peto OR for NTD, 0.131 (95% CI, 0.026 to 0.648); p=0.013^75–81^; Two cohort studies (prefortification): aOR for NTD, 0.11 (95% CI, 0.01 to 0.91);^82^ OR, 0.27 (95% CI, 0.11 to 0.63)^83,^ ^84^; Four case-control publications (prefortification): aOR for NTD, 0.7 (95% CI, 0.5 to 0.8);^33^ RR for NTD, 0.6 (95% CI, 0.4 to 0.8);^85^ OR for NTD, 0.65 (95% CI, 0.45 to 0.94);^86^ OR, 1.00 (95% CI, 0.73 to 1.40); p=0.97^87^; One case-control study (spanning pre- and postfortification): aOR for NTD, 1.12 (95% CI, 0.22 to 5.78)^88^; Three case-control studies (postfortification): OR for NTD, 1.11 (95% CI, 0.74 to 1.65) for consistent users;^89^ aOR for NTD (anencephaly+spin a bifida), 0.93 (95% CI, 0.82 to 1.06);^35^ aOR (anencephaly), 1.2 (95% CI, 0.8 to 1.9);^90^ aOR (spina bifida), 1.4 (95% CI, 1.0 to 1.8)^90^ | No new trials can be conducted on this topic. New studies must rely on observational data with inherent risks of case ascertainment bias (in prospective cohort studies) or exposure recall bias (in retrospective studies) | Three studies (2 cohort studies [3 publications publications^92–94^], 1 case-control study^95^); N=990,372 | Norwegian cohort (no mandatory fortification) study reported no statistically significant associations in overall analysis (1999–2013) or the first period (1999–2005) with low compliance with folic acid supplementation recommendations; statistically significant associations from 2006–2013 with higher compliance with folic acid recommendations: before pregnancy only (aRR, 0.54 [95% CI, 0.31 to 0.91]);^92^ during pregnancy only (aRR, 0.62 [95% CI, 0.39 to 0.97]);^93^ and before and during pregnancy (aRR, 0.49 [95% CI, 0.29 to 0.83])^93^; No consistently and statistically significant associations in Japanese cohort of general population (no mandatory fortification) (aOR, 0.62 [95% CI, 0.23 to 1.71])^94^ or U.S. and Canadian case-control study (postfortification study) of participants with prepregnancy diabetes or pregestational obesity for exposures measured as less than daily, daily, <0.4 mg, 0.4 mg to <0.1.0 mg^95^ | Heterogenous populations with different levels of food fortification and diet patterns; method-ological limitations in foundational evidence also apply | New studies have some evidence of benefit for reducing NTDs and do not change conclusions from foundational evidence.
KQ 1b: Differences in effect of folic acid supplements on NTDs by race/ethnicity | Three (3 case-control studies);^86,^ ^89,^ ^90^ N=11,154 | Inconsistent and imprecise findings from fair-quality studies suggesting no differences; No effect in first study;^90^ higher risk in second (aOR for Hispanic women with consistent use compared with nonuse, 2.20 [95% CI, 0.98 to 4.92]);^89^ less protective effect in third (OR for Hispanic women, 0.96 [95% CI, 0.44 to 2.10]) vs. 0.62 [95% CI, 0.35 to 1.10]) for non-Hispanic White womenvs. 0.54 [95% CI, 0.09 to 3.20] for Black women)^86^ | Small numbers in each comparison, differences in direction of estimate of effect effects possibly due to chance | No new evidence | NA | NA | NA
KQ 1c: Differences in effect of folic acid supplements on NTDs by dosage, duration, and timing | Dosage: Four (1 cohort study,^83,^ ^84^ 3 case-control studies^85–87^); N=26,791; Duration: 0; Timing: Five (1 cohort study, ^83,^ ^84^ 4 case-control studies^86,^ ^88–90^); N=26,808 | No indication of dose response in 3 of 4 studies.^83–87^ One study showed lower odds for daily use vs. less than daily use (OR, 0.57 [95% CI, 0.35 to 0.93])^83–87^; Duration: None; Timing: Calculated OR from cohort study for use weeks 1–6 vs. weeks 7 and later: 0.29 [95% CI, 0.14 to 0.60].^83,^ ^84^ Older studies consistently showed no effect of timing;^86,^ ^88^ one new study (postfortification) showed a protective effect of use before pregnancy vs. initiation in the first month of pregnancy on anencephaly but not spina bifida^90^ The other new study did not find a protective effect for spina bifida for consistent periconceptional use vs. initiation in the first month of pregnancy.^89^ | Small numbers in each comparison, effects possibly due to chance, studies used different measures of dose and timing | Dosage: 1 case-control study of women with prepregnancy obesity; N=1,429^95^; Timing: One cohort (2 publications^92,^ ^93^); N=896,674 | Dosage: Statistically significantly reduced association between NTD risk and exposure of 0.4 to <1.0 mg of folic acid supplementation daily (aOR, 0.54 [95% CI, 0.29 to 0.95]) but not for exposures of <0.4 mg (aOR, 1.29 [95% CI, 0.40 to 3.37]) or <0.4 mg or ≥1.0 mg (aOR, 0.84 [95% CI, 0.38 to 1.68]);^95^ differences did not persist in sensitivity analysis; Timing: Consistent benefits regardless of timing in 1 of 3 time periods examined (2006–2013) (aRR before pregnancy only [0.54, 95% CI, 0.31 to 0.91];^92^ during pregnancy only [0.62 [95% CI, 0.39 to 0.97];^93^ and before and during pregnancy [0.49 {95% CI, 0.29 to 0.83}]^93^; consistently no statistically significant differences for the other time periods (1999–2013, 1999–2005) | Small numbers in each comparison, effects possibly due to chance | New studies do not change conclusions regarding dosage or timing
KQ 2a: Harms associated with folic acid supplements: multiple gestation (twinning) | 2 (1 trial,^77^ 1 cohort^112^); N=7,387 | Trial found no statistically significant differences in twin pregnancy rate (RR, 1.4 [95% CI, 0.87 to 2.26]).^77^ Cohort found higher risk of twin birth for folate use (OR, 1.59 [95% CI, 1.41 to 1.78]) was attenuated once potential misclassification was accounted for (OR, 1.04 [95% CI, 0.91 to 1.18])^112^ | Low event rate, wide CIs | No new evidence | NA | NA | NA
KQ 2a: Harms associated with folic acid supplements: childhood asthma, allergy, wheezing | Childhood asthma, wheezing, allergy (3 SRs,^113–115^ 8 observational studies^116–123^); N>14,438 | No effect for a large majority of comparisons and outcomes^113–123^ | Variable measures of outcomes and exposure, all observation studies with risks of bias from case ascertainment and recall | No new evidence | NA | NA | NA
KQ 2a: Harms associated with folic acid supplements: other adverse events in women | 1 RCT; N=4,862^81^ | Increased risk for weight gain, diarrhea, constipation; reduced risk for irregular defecation; no difference for increased appetite, lack of appetite, exanthema, heartburn, and vertigo^81^ | Low event rate, wide confidence intervals | No new evidence | NA | NA | NA
KQ 2a: Harms associated with folic acid supplements: autism | No eligible evidence | NA | NA | Six fair-quality cohort studies^98–103^ and one fair-quality case-control study^104^; N=761,125 | Seven studies set in four countries (Israel, Sweden, Denmark, Norway); varied measures of exposure, comparator, and outcomes; generally no statistically significant associations; three publications of two populations in Israel,^103^ and Norway^100,^ ^102^ respectively, reported some benefits^103^ | No study reported harm but differences in statistically significant associations (benefits vs. no evidence of difference) may stem from differences in measurement of exposure, choice of comparator, and controls for confounding | NA
KQ 2a: Harms associated with folic acid supplements: maternal cancer | No eligible evidence | NA | NA | One cohort study;^97^ N=429,004 | HR for one pregnancy with exposure to folic acid supplementation vs. no exposure in pregnancy: 1.08 [95% CI, 1.00 to 1.18]^97^; HR for two or more pregnancies with exposure to folic acid supplementation vs. no exposure in pregnancy: 1.06 [95% CI, 0.91 to 1.22]^97^ | Potential for unmeasured confounding and recall bias in the classification of the intervention | NA
KQ 2b: Differences in harms associated with folic acid supplements by dosage, timing, and duration: twinning | No eligible evidence | NA | NA | One trial;^96^ N=431 | RR for twin deliveries with exposure to 4 mg folic acid supplementation vs. exposure to 0.4 mg folic acid supplementation; boths groups exposed before conception and through 12 weeks gestation: 0.45; 95% CI, 0.11 to 1.77 | Applicability uncertain to unplanned pregnancies | NA
KQ 2b: Differences in harms associated with folic acid supplements by dosage, timing, and duration: childhood asthma, allergy, wheezing | Dosage: One SR,^115^ one observational study^117^; N=484; Duration: 0; Timing of asthma, wheezing, allergy (2 SRs,^114,^ ^115^ 3 observational studies^116,^ ^118,^ ^119^); N varies by outcome | Dosage: No consistent increase in the risk of childhood asthma, wheeze, or allergies by dosage^115,^ ^117^; Duration: None; Timing: No consistent increase in the risk of childhood asthma, wheeze, or allergies by timing^114–116,^ ^118,^ ^119^ | Variable measures of outcomes and exposure, all observation studies with risks of bias from case ascertainment and recall | No new evidence | NA | NA | NA
KQ 2b: Differences in harms associated with folic acid supplements by dosage, timing, and duration: autism | No eligible evidence | NA | NA | Dose: Three (2 cohort studies,^98,^ ^100^ 1 case-control study),^104^ N=194,281; Timing: Two cohort studies,^99,^ ^100^ N=120,235; Duration: 0, N=NA | Dose: Overlap in CIs with exposure to folic acid supplementation in different doses vs. no or very low exposure to folic acid supplementation in pregnancy, all not statistically significant; Timing: Overlap in CIs with exposure to folic acid supplementation in different time intervals vs. no exposure to folic acid supplementation in pregnancy, all but one estimate not statistically significant; initiation in weeks 5 to 8 associated with benefit (14/16,184 vs. 32/14,721, aOR, 044 [95% CI, 0.23 to 0.83])^100^ | Potential for unmeasured confounding and recall bias in the classification of the intervention | NA

Abbreviations: aOR=adjusted odds ratio; aRR=adjusted relative risk; CI=confidence interval; HR=hazard ratio; KQ=key question; N=number; NA=not applicable; NTD=neural tube defect; OR=odds ratio; RCT=randomized, controlled trial; RR=relative risk; SR=systematic review; U.S.=United States; vs.=versus.

Studies identified in this review measured the impact of folic acid supplementation among women who eventually became pregnant. However, the guidance focuses on “women who are planning or capable of pregnancy.” There are two potential inconsistencies to consider. One is that individuals who are capable of becoming pregnant do not always identify as women; therefore, gendered language is not inclusive of their experience.^106^ Second, the language of the recommendation may be taken to assume that every reproductive-age individual who could theoretically carry a pregnancy should take folic acid supplementation. In all cases, the people involved in the identified studies were “women” who were planning a pregnancy or who had already become pregnant. No studies evaluated the use of folic acid supplementation among all people with a uterus who could theoretically conceive. Because a significant proportion of pregnancies in the United States are unintended, patient-centered counseling by primary care physicians about preconception folic acid supplementation may need to include a discussion on the likelihood of an individual becoming pregnant based on their actual behaviors, including sexual activity, sexual partners, and consistency of contraceptive use. No studies evaluated this type of approach to recommending folic acid supplementation.

## Limitations of the Review

Our scoping decisions serve as limitations to our conclusions. We restricted interventions to folic acid supplementation and did not consider food fortification, counseling to increase dietary intake, or screening for NTDs. We did not systematically examine the benefits of folic acid supplementation on benefits other than averted NTDs. We focused our limited update on the direct association between folic acid supplementation and NTDs, which is the focus of the prior review. A future updated review may need to consider the impact of folic acid supplementation on RBC folate concentrations, which may be a less biased measure of folate exposure than self-report of intake and would reflect adherence. We did not systematically evaluate the effect of folic acid supplementation among high-risk populations such as women with previous pregnancies with NTDs or exposure to antiepileptic drugs. These populations may respond to folic acid supplementation in different ways. We did not evaluate the impact of various clinical and public health strategies to improve the uptake of folic acid recommendations, which has been previously reviewed by the Community Preventive Services Task Force.^107^ We did not evaluate the impact of folic acid supplementation on the risk of early pregnancy loss or preconception outcomes such as ovulation patterns and infertility, although there is growing evidence that folate status and supplementation may have an impact on these outcomes as well.^108^

## Limitations of the Evidence

The state of the science also serves as a limitation to the evidence. Although we searched for evidence on subgroups of interest such as MTHFR status, we found no eligible studies. All new evidence is observational with limited ability to control for confounding, selection bias, recall bias, and attrition. One important limitation was that few studies were able to include pregnancies ending by termination, preimplantation, or early loss, thereby limiting the ability to account for all NTDs in the population. As a result, included studies have inherent uncertainty regarding case ascertainment (for NTDs and harms) and degree of exposure (dose, timing, and duration) to folic acid supplementation. Mandatory food fortification practices vary by geography and time period of investigation and contribute to heterogeneity across studies. Furthermore, failure to account for changes in food fortification practices over time within studies creates the potential for confounding. Heterogeneity in measuring adherence to folic acid supplementation and harms such as autism also limit the potential for causal inference.

## Future Research Needs

Studies suggested that folic acid supplementation of 400 µg resulted in an optimal RBC folate concentration threshold after 3 to 6 months of supplementation across all MTHFR genotypes,^28,^ ^29^ and that folic acid supplementation in populations known to have high rates of MTHFR TT resulted in a reduction in NTDs in that population.^109^ No trials have explored the effect of folic acid supplementation on NTDs by genotype. Future reviews could evaluate the risk of NTDs based on RBC folate concentrations and whether screening for RBC folate concentration preconception could help identify individuals who need modified folic acid supplementation of different doses or formulations before conception. Future reviews could also investigate whether folic acid supplementation affects other preconception and early pregnancy outcomes, including fertility, miscarriage, and early fetal loss. Given that these outcomes may lead to differential rates of NTDs, understanding the impact of folic acid supplementation on these outcomes would add further context to the question of how folic acid supplementation affects NTDs. These questions were outside the scope of this limited update.

## Conclusion

New evidence from observational studies provides continued evidence of benefit of folic acid supplementation for preventing NTDs and no evidence of harms related to autism or maternal cancer and is consistent with the previously reviewed evidence on this topic. The 2017 USPSTF recommendation supporting folic acid supplementation in pregnancy was based on previously reviewed evidence from an RCT and observational studies reporting reduced NTDs with supplementation and no consistent evidence of harms for multiple gestations, maternal adverse effects, or child respiratory illness.