# Chapter 3 Results

We screened 3,191 titles and abstracts and 142 full-text articles to identify 12 unique studies from 13 publications and N=1,244,072 for inclusion in this limited update (Figure 2).^62^ We identified two fair-quality cohort studies^92–94^ and one fair-quality case-control study^95^ reporting on the benefits of folic acid supplementation to reduce the risk of NTDs (KQ 1). One high-quality RCT,^96^ seven fair-quality cohort studies,^97–103^ and one fair-quality case-control study^104^ assessed the harms of folic acid supplementation (KQ 2). Appendix D provides the list of excluded articles that were screened at the full-text stage. Appendix E details methodologic quality assessments for all eligible studies. Appendix F provides detailed study characteristics and results. The results below focus on newly reported outcomes for this limited update.

Figure 2 Flow Diagram of Studies

Abbreviations: ICTRP=International Clinical Trials Registry Platform; WHO=World Health Organization.

Figure 2 is a flow chart that summarizes the search and selection of articles: There were 3,414 references identified by searching PubMed (1,790), the Cochrane Library (396), and EMBASE (1,228). In addition, 689 references were identified by ClinicalTrials.gov (549), WHO ICTRP (134), and hand searches (6). After removal of duplicate citations (478), the titles and abstracts of 3,625 references were screened for potential inclusion. Of these, 152 were deemed appropriate for full-text review to determine eligibility. After full-text review, 130 were excluded: 13 for wrong publication type/not original research, 7 for wrong population, 9 for wrong intervention, 8 for wrong comparator, 63 for wrong outcome, 7 for wrong country, 18 for wrong study design, 2 for wrong language, and 3 that had data that was not abstractable. 13 articles representing 12 studies are included in this report’s qualitative synthesis. 9 articles were excluded for high or unclear risk of bias.

## KQ 1 Folic Acid Supplementation and Risk Reduction for First Occurrence of NTDs

### Summary of Results

Three observational studies, described in four publications, reported on the association between folic acid supplementation and NTDs (N=990,372).^92–95^ Two cohort studies were in populations with no food fortification (Norway^92,^ ^93^ and Japan^94^). The Norwegian cohort study reported results separately by time periods (1999–2005, 2006–2013, and overall [1999–2013]).^92–95^ The authors hypothesized that these periods corresponded to lesser (1999–2005) and greater adherence (2006–2013) to recommendations regarding folic acid supplementation. The study reported a statistically significant reduction in NTDs in women on folic acid supplementation, regardless of timing of intake in the time period hypothesized to correspond to greater adherence (2006 to 2013),^92,^ ^93^ but not in other time periods. The Japanese cohort study reported no statistically significant differences associated with folic acid supplementation.^94^ The third study, a case-control study set in the United States and Canada in the period following food fortification, focused on participants with pregestational diabetes and prepregnancy obesity and represents a higher-risk cohort than the Norwegian and Japanese cohorts.^95^ This study reported no statistically significant associations between daily or less than daily folic acid supplementation compared with no supplementation and NTDs. The same study reported a statistically significant reduction in NTDs in women with prepregnancy obesity taking 0.4 mg to 1 mg folic acid, when compared with women with no supplementation, but this association did not persist in sensitivity analyses that adjusted for planned pregnancy rather than maternal age.^95^ Across all three studies, no other statistically significant benefits were reported overall, or by dose (1 study^95^) or timing (1 study^92,^ ^93^). Populations, interventions, and outcomes are described in the section that follows and in Appendix F Tables 1 through 4.

### Study Characteristics

Three fair-quality studies, described in four publications, reported on the association between folic acid supplementation and the occurrence of NTDs.^92–95^ Of these studies, two were cohort studies, set in Norway^92,^ ^93^ and Japan,^94^ and one was a case-control study drawing from the United States and Canadian Slone Birth Defects Study.^95^ The populations in the included studies were heterogeneous representing different baseline risks for NTDs. Both cohort studies drew from general populations: the Norwegian study drew from the Medical Birth Registry of Norway^92,^ ^93^ and the Japanese study drew from the Japan Environment and Children’s Study (a nationwide prospective birth cohort).^94^ The case-control study from the United States and Canada, however, focused on higher-risk groups (NTD family history, periconceptional antiepileptic drug exposure, pregestational diabetes, and prepregnancy obesity), of which, only the results for participants with pregestational diabetes and prepregnancy obesity are eligible for this review and summarized below.^95^

#### Norwegian Cohort

Two articles, published in 2016^92^ and 2020,^93^ reported on the Norwegian cohort study. The 2016 publication reported on 528,220 persons with 880,568 pregnancies and 896,674 live births and stillborn infants; of these infants, 270 had NTDs, indicating a prevalence of 3.07 per 10,000 pregnancies. The International Classification of Diseases-10 (ICD-10) and the International Classification of Diseases-10-British Pediatric Association were used to code birth defects that were identified by pediatric examination in the maternity or neonatal ward. Information on folic acid supplementation in terminated pregnancies was not available so these were not included in the population for the analysis on impacts of folic acid use. When 551 cases of NTDs among terminated pregnancies were added, prevalence of NTDs increased from 3.07 to 9.32 per 10,000 pregnancies, indicating that a significant number of NTDs were not included in the analysis of the impact of folic acid exposure.^92^

The analysis reported on NTDs among live births and stillborn infants from 1999 to 2013 overall and also stratified results into two separate time periods: 1999 to 2005 and 2006 to 2013. The authors performed this stratified analysis because they found that the overall adjusted relative risk (aRR) was affected by year of birth. Although the authors did not list hypotheses to explain differences by time period, they cited several external events of importance in their interpretation of the findings: the introduction of folic acid recommendations in 1999, inclusion of 0.2 mg folic acid in multivitamin supplements from 2004 onward (before 2004, most multivitamins did not include folic acid), and increased compliance with folic acid recommendations in the second half of the time period analyzed (2006–2013). The 2020 publication used a similar but not identical denominator (894,927 births) and the same overall time frame (1999–2013; data on separate time periods were reported in an appendix).^93^

Both publications drew on standard data collection in the Medical Birth Registry of Norway (MBRN) that recorded self-reported maternal exposure to folic acid at 16 weeks and at delivery and defined exposure as occurring before, during, or before and during pregnancy. The type of exposure was recorded as folic acid only, multivitamins only, and folic acid and/or multivitamins. The authors reported that over-the-counter folic acid preparations in Norway contain 0.4 mg. As noted above, multivitamins included no folic acid before 2004 and 0.2 mg thereafter. No measures of adherence were reported. The exposure categories were compared against no use of either folic acid or multivitamins before or during pregnancy.

In the 2016 publication, the outcome of NTDs included anencephaly, encephalocele, and spina bifida and excluded NTDs that were accompanied by chromosomal abnormalities and/or other genetic syndromes.^92^ The 2020 publication distinguished between total NTDs and isolated NTDs and also excluded chromosomal anomalies, genetic syndromes and microdeletions, and teratogenic syndromes.^93^

Both publications associated with this cohort study adjusted for year of birth, maternal age, marital status, parity, maternal smoking, pregestational diabetes, and maternal epilepsy in their analyses. The high proportion of pregnancy terminations due to NTD (551 cases, 67% of all NTDs) compared with live births with NTDs (229 cases, 28% of all NTDs) and stillbirths with NTDs (41 cases, 5% of all NTDs)^92^ suggests the potential for selection bias. Overall, the study, across the two publications, was rated as fair quality because of the potential for unmeasured confounding, the potential for recall bias leading to bias in the classification of the intervention, and the potential for selection bias.

#### Japanese Cohort

The Japanese cohort comprised 92,269 singleton pregnancies occurring between January 2011 and March 2014.^94^ Pregnancy outcomes included spontaneous abortion, termination of pregnancy, stillbirth, and live birth. The study recorded 74 unique NTDs (spina bifida, anencephaly, and encephalocele), indicating a prevalence of 8.02 per 10,000 pregnancies. NTD diagnoses and birth outcomes were based on medical records that recorded information diagnosed by obstetricians or gynecologists immediately after delivery and during the first month at a regular checkup.

The study provided information regarding patient-reported supplement use for 1 year before pregnancy confirmation and for 12 weeks after pregnancy confirmation.^94^ The study noted that the recommendation intake was 0.4 mg but did not specify the dose from individual participants. The study compared adequate users of folic acid supplements (started before conception) with inadequate users (started after pregnancy recognition or nonuse of folic acid supplements). NTD outcomes included spina bifida, anencephaly, and encephalocele.

The study adjusted for age, smoking habits, body mass index, history or complication of diabetes and gestational diabetes mellitus, valproic acid and other antiepileptic drugs.^94^ The study was rated fair quality because of the potential for confounding, bias from recall of folic acid exposure, and lack of information on how missing data were handled.

#### U.S. and Canadian Case-Control Study

The U.S. and Canadian case-control study identified pregnancies in high-risk groups (diabetes, obesity, NTD family history, periconceptional antiepileptic drug exposure) from tertiary care centers and birth hospitals in Boston, Philadelphia, and Toronto (1976–2005); San Diego (2001–2015), and Nashville (2012–2015); and via birth defect registries in Massachusetts (2003–2015) and parts of New York State (2004–2015); the analyses were restricted to data from 1988 through 2015.^95^ We included subgroups of those participants with prepregnancy diabetes and those with prepregnancy obesity in our analyses; as noted earlier, other groups were ineligible for this review. Participants who reported diagnosis of type 1 or 2 diabetes mellitus before the end of the periconceptional period were included in the pregestational diabetes group. Participants whose reported prepregnancy height and weight yielded a body mass index (BMI) ≥30 kg/m^2^ were included in the prepregnancy obesity group; this group excluded participants with NTD history, antiepileptic drug use, or pregestational diabetes. The study reported 111 cases and 1,243 controls whose mothers had prepregnancy obesity without diabetes and 12 cases and 63 controls whose mothers had pregestational diabetes with or without obesity.

Cases were defined as pregnancies affected by anencephaly, spina bifida, or encephalocele, resulting in live birth, stillbirth, or elective termination >12 weeks of gestation, based on clinical geneticist review. Cases were identified through arrangements with state birth defect registries and participating institutions.^105^ Conjoined twins and infants with amniotic bands, body wall defects, chromosomal anomalies, a known syndrome, or unconfirmed diagnoses were excluded. From 1988 to 1992, controls were pregnancies affected by minor malformations only or by one of several major malformations not known to be associated with folic acid. From 1993 onward, controls were liveborn infants without major structural malformations.

The study ascertained exposure to folic acid supplementation by interview with study participants within 6 months of delivery.^95^ Participants reporting daily exposure to a product containing folic acid 28 days before to 28 days after the first day of the last menstrual period were categorized as daily supplement users. Participants reporting exposure but not daily exposure were categorized as than less than daily. Additionally, based on the information provided by participants, the study authors calculated average daily dose and categorized dose as <0.4 mg, 0.4 mg to <.1.0 mg, or ≥1.0 mg. The analyses compared less than daily folic acid supplementation; daily folic acid supplementation; and <0.4 mg, 0.4 mg to <1.0 mg, or ≥1.0 mg of folic acid with no supplements in the periconceptional period.

The study adjusted for maternal age and study center and also adjusted for planned pregnancy instead of maternal age in sensitivity analyses.^95^ The study was rated fair quality because of the potential for confounding from failure to account for food fortification changes, unmeasured confounding, and bias from recall of folic acid exposure.

### Results of Included Studies

#### KQ 1a To What Extent Does Folic Acid Supplementation Reduce the Risk for NTDs (First Occurrence) in Persons Capable of Getting Pregnant?

Table 1 summarizes key results. The Norwegian cohort study reported statistically significant associations with lower NTD risk in the later 2006 to 2013 time period but not in the overall time period 1999 to 2013 or in the earlier time period 1999 to 2005.^92,^ ^93^ In the 2006 to 2013 period, the study reported a higher level of compliance with folic acid supplementation recommendations than in previous time points and inclusion of folic acid in multivitamin supplements. The use of folic acid and/or multivitamins resulted in a statistically significant lower aRR of NTDs when taken before pregnancy (aRR, 0.54 [95% CI, 0.31 to 0.91]).^92^ NTDs were diagnosed after live or stillbirth by expert examiners. The study also reported statistically significant associations between folic acid or multivitamin supplementation during pregnancy only or both before and during pregnancy. No analyses in the first time period (1999–2005) or in the overall time period (1999–2013) yielded statistically significant associations.

Table 1 Folic Acid Supplementation and Neural Tube Defect Outcomes

Cohort | Supplementation Group | Comparator | Outcome: (N With Event/N Exposed vs. N With Event/N Nonexposed) | Effect on NTD Incidence (95% CI)
Gildestad et al, 2016^92^ Gildestad et al, 2020^93^ (Norwegian cohort)^*^ | Folic acid and/or multivitamins before pregnancy | No use of folic acid or multivitamins before or during pregnancy | Time period 1999–2013: 44/189,217 (0.02%) vs. 141/380,273 (0.04%); Time period 1999–2005: 22/101,977 (0.04%) vs. 95/242,696 (0.04%); Time period 2006–2013: 22/134,515 (0.02%) vs. 46/137,577 (0.03%) | Time period 1999–2013, aRR, 0.76 (0.53 to 1.10); Time period 1999–2005, aRR, 1.02 (0.63 to 1.65); Time period 2006–2013, aRR, 0.54 (0.31 to 0.91)
Nishigori et al, 2019^94^ (Japanese cohort) | Adequate use of folic acid supplements (started before conception) | Inadequate use (started folic acid supplements after pregnancy recognition or nonuse of folic acid supplements) | 4/7,634 (0.05%) vs. 70/84,635 (0.08%) | aOR, 0.62 (0.23 to 1.71)
Petersen et al, 2019^95^ (U.S. and Canadian case-control study) | Daily exposure to a product containing folic acid 28 days before to 28 days after the first day of the last menstrual period | No supplements in the periconceptional period | NA (case-control study) | Prepregnancy obesity,^†^ aORs adjusting for maternal age: 0.65 (95% CI, 0.40 to 1.04); aOR adjusting for planned pregnancy: 0.69 (95% CI, 0.42 to 1.10); Pregestational diabetes, aOR adjusting for maternal age: 0.25 (95% CI, 0.04 to 1.05); aOR adjusting for planned pregnancy: 0.37 (95% CI, 0.06 to 1.65)

* Data presented for use of folic acid supplement or multivitamins containing folic acid before pregnancy only, data limited to folic acid supplements only and for use during pregnancy and combined before and during pregnancy is available in Appendix F Table 2.

† Additional results for various levels of folic acid exposure are in Appendix F Table 2.

Abbreviations: aOR=adjusted odds ratio; aRR=adjusted relative risk; CI=confidence interval; NA=not applicable; N=number; NTD=neural tube defect; U.S.=United States; vs.=versus.

The Japanese cohort study reported no statistically significant associations between adequate use of folic acid supplementation (initiated before conception) when compared with inadequate use (started after pregnancy recognition or nonuse of folic acid supplements).^94^ The study reported an adjusted odds ratio (aOR) of 0.62 (95% CI, 0.23 to 1.71). Analyses by type of NTD (spina bifida, anencephaly, encephalocele) also showed no statistically significant associations. NTDs were diagnosed after live birth or stillbirth by expert examiners.

The U.S. and Canadian case-control study reported no statistically significant associations between most measures of exposure (less than daily; daily; and <0.4 mg, 0.4 mg to <1.0 mg, or ≥1.0 mg of folic acid supplementation) and NTDs.^95^ The authors reported multiple aORs, depending on variables adjusted in the model. For daily supplementation compared with no supplementation, aORs ranged from 0.65 to 0.69 depending on variables included in the model; CIs spanned the null. For women with pregestational diabetes, aORs ranged from 0.25 to 0.37; CIs spanned the null. Nearly all other measures of exposure (less than daily, <0.4 mg, 0.4 mg to <1.0 mg, or ≥1.0 mg of folic acid supplementation) similarly reported no statistically significant associations between folic acid supplementation and NTDs. The only exception was participants with prepregnancy obesity taking supplements of 0.4 mg to 1 mg. Among this group, the OR for NTDs was significantly lower in analyses that adjusted for maternal age and study center (aOR, 0.54 [95% CI, 0.29 to 0.95]) but not in sensitivity analyses that adjusted for planned pregnancy instead of maternal age and study center (aOR, 0.57 [95% CI, 0.30 to 1.02]). The authors did not report adjusting the CIs for multiple comparisons. NTDs in this study were from a birth defects registry that used an active surveillance program with trained personnel evaluating reports of birth defects based on physical exam at the time of delivery. NTDs from pregnancy terminations or early fetal loss were not included. Notably, the study included data in a period of time (1988–2015) spanning the introduction of food fortification in the United States and Canada in 1998 and consequent attenuation of the effect of individual supplementation, but the study did not stratify the analyses accordingly.

#### KQ 1b Does the Effect of Folic Acid Supplementation on NTDs (First Occurrence) Differ by Race and Ethnicity?

Differences in NTD prevalence by race and ethnicity could not be evaluated because no studies reported on these data.

#### KQ 1c Do the Benefits of Folic Acid Supplementation Differ by Dosage, Timing, or Duration of Therapy?

As noted previously, one study in Norway, reported in two publications, presented data on a population cohort relevant to NTD risk and the timing (before only, during only, before and during) of supplementation.^92,^ ^93^ The results were consistent in demonstrating no effect of folic acid supplementation in the overall time period (1999–2013) and the first time period (1999–2005), regardless of the timing of folic acid supplementation (before, during, or before and during pregnancy). In the second time period, the results were consistent in demonstrating benefit of folic acid supplementation regardless of timing (before pregnancy only: aRR, 0.54 [95% CI, 0.31 to 0.91];^92^ before and during pregnancy: aRR, 0.49 [95% CI, 0.29 to 0.83];^93^ during pregnancy only: aRR, 0.62 [95% CI, 0.39 to 0.97]^93^).

One case-control study of participants with prepregnancy obesity reported statistically significantly reduced association between NTD risk and exposure of 0.4 to <1.0 mg of folic acid supplementation daily (aOR, 0.54 [95% CI, 0.29 to 0.95]) but not for exposures of <0.4 mg (aOR, 1.29 [95% CI, 0.40 to 3.37]) or ≥1.0 mg (aOR, 0.84 [95% CI, 0.38 to 1.68]).^95^ As noted previously, the finding of a statistically significant difference for the 0.4 to <1.0 mg did not persist in sensitivity analyses adjusting for planned pregnancy instead of maternal age (aOR, 0.57 [95% CI, 0.30 to 1.02]), in which all exposures, regardless of dose, did not demonstrate a statistically significant association with NTDs. Notably, these subgroups of participants had as few as four to 14 cases; a single statistically significant result may have arisen by chance.

## KQ 2. Harms of Folic Acid Supplementation

### Summary of Results

One trial reported no association between doses of folic acid supplementation (4 mg vs. 0.4 mg) and twin delivery (N=431).^96^

Six cohort studies^98–103^ and one case-control study^104^ examined the association between folic acid supplementation and autism spectrum disorder (ASD) (N=761,125). In addition, one cohort study assessed association between folic acid supplementation and maternal cancer (N=429,004).^97^ No study reported a statistically significant association for either of these two harms.

Two cohort studies reported some statistically significant benefits associated with folic acid supplementation and ASD,^100,^ ^103^ but other analyses in the similar geographic settings^104^ or even the same population^102^ that used different measures of exposure^102,^ ^104^ or comparator^104^ did not report these benefits.

Two cohort studies and one case-control study examined associations between folic acid supplementation and ASD by dose^98,^ ^100,^ ^104^ and found effects with overlapping CIs, suggesting no differences by dose. Two cohort studies assessed associations between folic acid supplementation and ASD by timing.^99,^ ^100^ Neither reported harm, but one reported a statistically significant benefit associated with folic acid supplementation initiation in weeks 5 to 8 of the pregnancy alone.^100^ Populations, interventions, and outcomes are described below in detail and in Appendix F Tables 5 through 11.

### Study Characteristics: Twinning

A single high-quality RCT, conducted in Italy between 2009 and 2014, compared outcomes following randomization of 1,060 women age 18 to 44 years and planning a pregnancy to 4 mg vs. 0.4 mg of folic acid supplementation.^96^ After exclusions for early interruptions (e.g., withdrawal of consent, adverse events, or other reasons) (N=167), loss to followup (N=137), lack of conception at 1 year (N=251), delayed or unclear timing of the start of folic acid supplementation relative to conception (N=44) or assisted reproductive technology conceptions (N=30), 431 natural conceptions were retained for analysis.

### Results of Included Studies: Twinning

#### KQ 2a Are Harms Associated With Folic Acid Supplementation to the Pregnant Person, Fetus, Neonate, or Child?

No studies reported on risk of overall risk of twinning.

#### KQ 2b Do the Harms of Folic Acid Supplementation Differ by Dosage, Timing, or Duration of Therapy?

One trial reported no differences between an exposure of 4 mg vs. 0.4 mg of folic acid on twin deliveries (3/227 [1.3%] vs. 6/204 [2.9%]; RR, 0.45 [95% CI, 0.11 to 1.77]). No studies reported on variation in harms by duration or timing of therapy.

### Study Characteristics: Autism Spectrum Disorder

Six fair-quality cohort studies^98–103^ and one fair-quality case-control study^104^ examined the association between folic acid supplementation and the incidence of ASD. Two of these studies were set in Israel,^103,^ ^104^ one in Sweden,^101^ two in Denmark,^98,^ ^99^ and two in Norway.^100,^ ^102^ Given similarities within countries (and differences across countries) in secular trends in supplementation and typical doses of folic acid in over-the-counter supplements, the analysis below summarizes results by country.

#### Israeli Studies

The two studies set in Israel drew from independent populations of the Maccabi Healthcare Service organization (Sharman Moser et al, 2019,^104^ case-control study from 2000 to 2013, N=21,895 children, including 2,009 with ASD) and the Meuhedet healthcare organization^103^ (retrospective controlled cohort study of births from 2003 to 2007, N=45,300 children, including 572 with ASD).

The Sharman Moser case-control study relied on ASD diagnoses made after a multidisciplinary assessment (pediatric neurology, development, and psychology) and concurrence between the physician and the psychologist that Diagnostic and Statistical Manual of Mental Disorders (DSM) criteria were met.^104^ ASD patients were randomly matched with ASD-free children by birth year (within 2 years), maternal age (within 2 years), sex, residential area, and socioeconomic status. The study measured folic acid exposure from dispensing data in medical records and categorized exposure as low supplemented (0.2 to <0.4 mg/day), typically supplemented (0.4 to <1 mg/day), high supplemented (1 to <3 mg/day), and very high supplemented (>3 mg/day) and compared these results to not supplemented or very low supplemented (median daily dose of <0.2 mg).^104^ In Israel, multivitamins are available through the health system at a lower cost than outside the health system ($9 for 100 tablets of 0.4 mg vs. $12).^104^

In the Levine cohort study, folic acid supplement doses were not specified but were recorded from prescription registers as occurring before or during pregnancy when compared with no exposure in that time interval.^103^ This study followed participants from birth to 15 years. ASD was ascertained by a developmental behavioral pediatrician; authors used 10th revision of the International Statistical Classification of Diseases and Related Health Problems (ICD-I0) codes to define the condition. These diagnoses happened after children with probable ASD were evaluated by an expert panel comprising social workers, a psychologist, and either a trained psychiatrist, developmental behavioral pediatrician, or child neurologist.^103^ This study included all participants with ASD and one-third of all live births.^103^

The Levine cohort study adjusted for birth year, sex, socioeconomic status (high vs. low), a maternal and paternal psychiatric diagnosis at childbirth (present or absent), maternal and paternal age at childbirth, and parity.^103^ The Sharman Moser case-control study matched participants by birth year, maternal age, sex, residential area, and socioeconomic status and adjusted results for maternal age, subfertility, number of physician or obstetrics visits in the 15 months before index date, birth order, and total number of children in the family but not birth order of the child; sensitivity analyses focused on first-order births.^104^ We rated both studies as fair quality because of potential for bias from unmeasured confounding and the potential for bias in measurement of exposure from prescriptions or medical records. Neither study evaluated adherence to the supplements.^103,^ ^104^

#### Swedish Cohort

One cohort study drew from the Stockholm youth cohort, which includes children between 4 and 15 years of age living in Stockholm County, Sweden, for at least 4 years between 2001 and 2011 (N=94,864, including 2,123 with ASD).^101^ Clinicians recorded self-reported supplement use during pregnancy at the first antenatal visit; dose was not reported in the study. The comparison was no use of multivitamins, iron, or folic acid. The outcome of ASD was ascertained following structured diagnostic assessment by specialists and was recorded in medical records using ICD-10 and DSM-IV codes. The analysis adjusted for child characteristics (sex, birth year, and years resided in Stockholm County), socioeconomic indicators (education, family income, and maternal birth country), maternal characteristics (age, BMI, parity, smoking status), medication use during pregnancy (antidepressants or antiepileptics), and maternal neuropsychiatric conditions (anxiety disorders, autism, bipolar disorder, depression, epilepsy, intellectual disability, nonaffective psychotic disorders, and stress disorders). We rated the study as fair quality because of the risk of bias from unmeasured confounding and attrition. The study conducted sensitivity analyses using matched siblings and propensity score-adjusted models.

#### Danish Cohort

Two publications of the same cohort, the Danish National Birth Cohort (DNBC), reported on the association between folic acid exposure and ASD.^98,^ ^99^ The database, comprising more than 100,000 pregnancies, collected data from 1996 to 2002. The study organizers changed the recruitment form midway through the study to allow greater specificity in exposure to supplements. The 2016 DNBC publication by Virk et al. selected 19,042 (total N with ASD, autism, or Asperger’s syndrome were not reported) women with singleton offspring with exposure to folic acid or no exposure to supplements from 2000 to 2002.^99^ A later publication by Strom and colleagues, in 2018, took advantage of ongoing computerization of the early recruitment forms and selected 87,210 participants (1,234 with ASD and 312 with childhood autism) with singleton offspring who were born at 32 weeks or more and weighed 2,500 grams or more.^98^ The exposure was reporting having taken folic acid in at least 2 weeks in the period that began 4 weeks before the last menstrual period and continued 8 weeks after the last menstrual period. Most folic acid supplements available in Norway during this period contained 0.4 mg. Periconception folic acid use was defined as any use of a supplement containing folic acid during one or more of the following periods: −4 to −1 weeks, 1 to 4 weeks, and 5 to 8 weeks. The two publications varied in their reference categories: the Virk (2016) publication defined the reference group of unexposed women as women who indicated no supplement use during the −4- to 8-week period.^99^ The Strom (2018) publication created a reference category of no use for each separate time period of exposure.^98^ The Strom (2018) publication also provided dose information from a mid-pregnancy measure of folic acid use of <0.4 mg and ≥0.4 mg compared with no use. Virk et al mentioned an average of 9.6 years (8.1−11.4 years) followup.^99^

The Virk (2016) study obtained outcome data from the National Hospital Register and included ICD-10-CM codes for autistic disorder, Asperger’s syndrome, pervasive developmental disorder, and ASD (the most inclusive).^99^ The Strom (2018) study identified 1,234 cases of ASD and 312 cases of childhood autism that had been diagnosed with ICD-10 diagnosis codes for childhood autism and entered in at least one of two national registries.^98^ The only category in which the case definition is identical in the two studies was autistic disorder/childhood autism.

We rated both studies as fair quality because of the risk from unmeasured confounding and attrition. The 2016 publication adjusted for maternal age, household socioeconomic status, maternal smoking during pregnancy, maternal alcohol consumption during pregnancy, maternal BMI, maternal mental health history, and socioeconomic status.^99^ The 2018 publication adjusted for the following covariates: maternal age, paternal age, parity, maternal smoking during pregnancy, maternal education, family socioeconomic status, pregnancy intendedness, maternal BMI, and sex of child.^98^

#### Norwegian Cohort

Two publications drew from a pregnancy cohort in Norway consisting of pregnant persons who were recruited in the second trimester. Suren et al selected participants from the Norwegian Mother and Child Cohort Study (MoBa) and its substudy specific to autism, the Autism Birth Cohort study.^100^ Nilsen et al drew from the same source but sought to examine the potential for selection bias, by comparing the MoBa cohort with a nationwide registry, the Medical Birth Registry of Norway (MBRN).^102^ All pregnancies lasting more than 12 weeks in Norway are required to be recorded in the MBRN by law, but only a subset of women volunteered to participate in MoBa. In addition to these differences in data sources and purposes, the publications varied in other respects as well. Suren et al selected 85,176 children (270 with ASD) born between 2002 and 2008;^100^ Nilsen et al selected 89,836 children (234 with ASD) born from the MoBa cohort between 1999 and 2007 and 507,856 children (2,072 with ASD) born in the same period from the MBRN.^102^ The two data sources had an overlap of 234 ASD cases.

The MBRN population was younger, more likely to be single, and more likely to deliver at a larger hospital, more likely to smoke and less likely to use folic acid supplements compared with pregnant persons in the MoBa cohort. Participants in the MoBa cohort were likelier to have healthier lifestyles and higher socioeconomic status than the nationwide population, suggesting a more selective population.

Importantly, the two analyses also differed in their source of data for use of folic acid supplements. Suren et al relied on MoBa supplement data collected at 18 weeks of gestation. Women were asked to record their intake of vitamins and supplements but not asked to specify exact amounts; those who took folic acid as part of a multivitamin supplement may have received less than 0.4 mg. Suren et al further recorded the initiation of exposure from weeks −4 to –1, 1 to 4, 5 to 8, and 9 to 16, using no exposure to vitamins or minerals in weeks −4 to 8 as the referent. The Suren publication also reported on exposure based on self-reported use of supplements in week 22 of pregnancy and recorded folic acid intake as 0.001 to 0.399 mg and 0.4 mg and more. The analysis of folic acid exposure used no folic acid in week 22 as the referent.^100^ Nilsen et al relied on the MBRN data, specifically use was determined by an item on a participant questionnaires at the beginning and the end of the pregnancy about “any use of maternal folic acid supplements before and/or during pregnancy.”^102^

The two publications also varied in outcome measurement. Suren et al reported that cases were identified through a variety of means, but all cases had either been individually assessed using validated tools and diagnosed according to DSM-IV criteria (N=135) or via specialist diagnosis ICD-10-CM in patient registry (N=135) for ASD including autism, Asperger’s, and pervasive developmental disorder.^100^ In the Nilsen publication, authors diagnosed ASD by linkage with a national administrative database with mandatory reporting via ICD-10-CM for autism, atypical autism, Asperger’s, pervasive developmental disorder, and unspecified and other pervasive developmental disorder. The cases in the cohort were validated against DSM-IV criteria and were found to be accurate in 97 percent of cases.^102^

Suren et al reported ORs that were adjusted for year of birth, maternal education, and parity.^100^ Nilsen et al reported adjusting effect estimates for year of birth, maternal and paternal age, marital status, parity, and hospital size.^102^ We rated these studies as fair quality because of the potential for unmeasured confounding; additionally, the measurement of exposure (any use vs. no use) in the Nilsen et al study does not account for dose or adherence.^102^

### Results of Included Studies: Autism Spectrum Disorder

#### KQ 2a Are Harms Associated With Folic Acid Supplementation to the Pregnant Person, Fetus, Neonate, or Child?

Table 2 presents summary results across the included studies.

Table 2 Folic Acid Supplementation and Autism Spectrum Disorder Outcomes

Country | First Author, Year | Supplementation Groups | Comparator | Outcome: (N With Event/N Exposed vs. N With Event/N Nonexposed) | Effect on Autism Incidence (95% CI)
Israel | Levine et al, 2018^103^ | Folic acid supplement exposure before pregnancy | No folic acid supplement exposure before pregnancy | ASD: NR by arm | aRR, 0.56 (95% CI, 0.42 to 0.74)
Israel | Levine et al, 2018^103^ | Folic acid supplement exposure during pregnancy | No folic acid supplement exposure during pregnancy | ASD: NR by arm | aRR, 0.32 (95% CI, 0.26 to 0.41)
Israel | Sharman Moser et al, 2019^104^ | 0.2 <0.4 mg/day | <0.2 mg/day | ASD: NA (case-control study) | aOR, 1.27 (95% CI, 0.98 to 1.65)
Israel | Sharman Moser et al, 2019^104^ | 0.4–<1 mg/day | <0.2 mg/day | ASD: NA (case-control study) | aOR, 1.12 (95% CI, 0.91 to 1.39)
Israel | Sharman Moser et al, 2019^104^ | 1–<3 mg/day | <0.2 mg/day | ASD: NA (case-control study) | aOR, 1.18 (95% CI, 0.89 to 1.56)
Israel | Sharman Moser et al, 2019^104^ | >3 mg/day | <0.2 mg/day | ASD: NA (case-control study) | aOR, 1.08 (95% CI, 0.44 to 2.64)
Sweden | DeVilbiss et al, 2017^101^ | Folic acid supplement use during pregnancy | No use of folic acid, multivitamins, or iron during pregnancy | ASD with intellectual disability: 15/2,789 (0.54%) vs. 430/91,895 (0.47%) | aOR, 1.2 (95% CI, 0.71 to 2.01)
Sweden | DeVilbiss et al, 2017^101^ | Folic acid supplement use during pregnancy | No use of folic acid, multivitamins, or iron during pregnancy | ASD without intellectual disability: 63/2,789 (2.26%) vs. 1,615/91,895 (1.76%) | aOR, 1.29 (95% CI, 0.99 to 1.67)
Sweden | DeVilbiss et al, 2017^101^ | Folic acid supplement use during pregnancy | No use of folic acid, multivitamins, or iron during pregnancy | ASD with or without intellectual disability: 72/2,789 (2.58%) vs. 2045/91,895 (2.23%) | aOR, 1.27 (95% CI, 1.01 to 1.6)
Sweden | DeVilbiss et al, 2017^101^ | Folic acid supplement use during pregnancy | No use of folic acid, multivitamins, or iron during pregnancy | ASD with or without intellectual disability: 72/2,789 (2.58%) vs. 2045/91,895 (2.23%) | aOR (sensitivity analysis: propensity score model): 1.17 (95% CI, 0.89 to 1.51)
Sweden | DeVilbiss et al, 2017^101^ | Folic acid supplement use during pregnancy | No use of folic acid, multivitamins, or iron during pregnancy | ASD with or without intellectual disability: 72/2,789 (2.58%) vs. 2045/91,895 (2.23%) | aOR (sensitivity analysis: sibling controls): 1.48 (95% CI, 0.87 to 2.51)
Denmark | Virk et al, 2016^99^ | Folic acid use weeks −4 to −1 | No folic acid use between weeks −4 to 8 | ASD: NR by arm | aRR, 1.06 (95% CI, 0.83 to 1.36)
Denmark | Virk et al, 2016^99^ | Folic acid use weeks 1 to 4 | No folic acid use between weeks −4 to 8 | ASD: NR by arm | aRR, 0.98 (95% CI, 0.77 to 1.24)
Denmark | Virk et al, 2016^99^ | Folic acid use weeks 5 to 8 | No folic acid use between weeks −4 to 8 | ASD: NR by arm | aRR, 0.99 (95% CI, 0.8 to 1.22)
Denmark | Virk et al, 2016^99^ | Folic acid use weeks −4 to 8 | No folic acid use between weeks −4 to 8 | ASD: NR by arm | aRR, 1.00 (95% CI, 0.82 to 1.22)
Denmark | Strom et al, 2018^98^ | Folic acid use weeks −4 to −1 | No folic acid use between weeks −4 to 8 | ASD: 749/52822 (1.42%) vs. 485/34,388 (1.41%); | aHR: 1.03 (95% CI, 0.92 to 1.16)
Denmark | Strom et al, 2018^98^ | Folic acid use between weeks −4 and 1 | No folic acid use between weeks −4 and 1 | ASD: 414/28295 (1.46%) vs. 820/58,315 (1.41%) | aHR: 1.02 (95% CI, 0.91 to 1.15)
Denmark | Strom et al, 2018^98^ | Folic acid use between weeks 1 and 4 | No folic acid use between weeks 1 and 4 | ASD: 545/38,326 (1.42%) vs. 689/48,884 (1.41%) | aHR: 1.01 (95% CI, 0.9 to 1.13)
Denmark | Strom et al, 2018^98^ | Folic acid use between weeks 5 and 8 | No folic acid use between weeks 5 and 8 | ASD: 732/51559 (1.42%) vs. 502/35,651 (1.41%) | aHR: 1.03 (95% CI, 0.92 to 1.15)
Norway | Suren et al, 2013^100^ | Any folic acid use weeks −4 to 8 | No folic acid use between weeks −4 and 8 | Autistic disorder: 64/61,042 (0.10%) vs. 50/21,134 (0.24%) | aOR, 0.61 (95% CI, 0.41 to 0.90)
Norway | Suren et al, 2013^100^ | Folic acid initiation weeks −4 to −1 | No folic acid use between weeks −4 and 8 | Autistic disorder: 32/28,061 (0.11%) vs. 32/14,721 (0.22%) | aOR, 0.67 (95% CI, 0.4 to 1.14)
Norway | Suren et al, 2013^100^ | Folic acid initiation weeks 1 to 4 | No folic acid use between weeks −4 and 8 | Autistic disorder: 18/16,797 (0.11%) vs. 32/14,721 (0.22%) | aOR, 0.58 (95% CI, 0.32 to 1.05)
Norway | Suren et al, 2013^100^ | Folic acid initiation weeks 5 to 8 | No folic acid use between weeks −4 and 8 | Autistic disorder: 14/16,184 (0.09%) vs. 32/14,721 (0.22%) | aOR, 0.44 (95% CI, 0.23 to 0.83)
Norway | Suren et al, 2013^100^ | Folic acid initiation weeks 9 to 16 | No folic acid use between weeks −4 and 8 | Autistic disorder: 18/9395 (0.19%) vs. 32/14,721 (0.22%) | aOR, 0.87 (95% CI, 0.49 to 1.57)
Norway | Nilsen et al, 2013^102^ | Prenatal folic acid use | No prenatal folic acid use | ASD: NR by arm | aOR, 0.86 (95% CI, 0.78 to 0.95) (MBRN population)
Norway | Nilsen et al, 2013^102^ | Prenatal folic acid use | No prenatal folic acid use | ASD: NR by arm | aOR, 0.85 (95% CI, 0.65 to 1.11) (MoBa cohort)

Abbreviations: aHR=adjusted hazard ratio; aOR=adjusted odds ratio; aRR=adjusted relative risk; ASD=autism spectrum disorder; CI=confidence interval; MBRN=Medical Birth Registry of Norway; MoBa=Mother and Child Cohort Study; NA=not applicable; N=number; NR=not reported; vs.=versus.

Both studies set in Israel reported no harms. The Levine cohort reported benefits: exposure to folic acid supplements either before (aRR, 0.56 [95% CI, 0.42 to 0.74]) or during pregnancy (aRR, 0.32 [95% CI, 0.26 to 0.41]) was associated with a lower risk of ASD compared with no exposure.^103^ By contrast, the Sharman Moser case-control study found ORs ranging from 1.01 to 1.15 for the four levels of folic acid exposure with no statistically significant associations and no dose response observed.^104^ Differences in the definition of exposure and comparator may explain these differences: the Sharman Moser cohort study stratified exposure by dose and compared it with no or low exposure,^104^ whereas the Levine cohort study did not stratify exposure and compared exposure with no exposure.^103^

The Swedish cohort study found no statistically significant associations between folic acid exposure and ASD with (aOR, 1.20 [95% CI, 0.71 to 2.01]) or without (aOR, 1.29 [95% CI, 0.99 to 1.67]) intellectual disability.^101^ However, the association between folic acid supplementation and these outcomes put together, for ASD with or without intellectual disability, was statistically significant (aOR, 1.27 [95% CI, 1.01 to 1.30]). Sensitivity analyses of a matched cohort of siblings (aOR, 1.48 [95% CI, 0.87 to 2.51]) and propensity score models (aOR, 1.17 [95% CI, 0.89 to 1.51]) both resulted in nonsignificant effects, suggesting a lack of evidence of association.

Two analyses with some overlap in time and participants from Denmark reported consistent results.^98,^ ^99^ The 2016 analysis found no statistically significant associations between folic acid exposure between pregnancy weeks −4 to 8 and ASD, autism, Asperger’s syndrome, or pervasive developmental disorder not otherwise specified. Reported aRRs ranged from 0.85 to 1.18 (see Appendix F Table 6 for more details).^99^ The 2018 analysis,^98^ using a larger and overlapping dataset but that restricted the outcomes to only ASD or childhood autism, also found no statistically significant associations between exposure to folic acid supplements between pregnancy weeks −4 to 8 and these outcomes; adjusted hazard ratio (HR) ranged from 1.06 to 1.09 (see Appendix F Table 6 for more details).^98^ The studies reported no associations between dose or time intervals of exposure and autism.

Two analyses (Suren et al^100^ and Nilsen et al^102^) conducted among participants in Norway, with some overlap in populations, but differences in measurement of exposure and outcomes, found no harms. The Suren et al analysis reported that prepregnancy and early pregnancy exposure to folic acid supplementation resulted in lower odds of autism (aOR 0.61 [95% CI, 0.41 to 0.90]) but no statistically significant associations for Asperger’s syndrome (aOR 0.65 [95% CI, 0.36 to 1.16]) or pervasive developmental disorder (aOR, 1.04 [95% CI, 0.66 to 1.63]). Notably, sample sizes for all these analyses were small, leaving open the potential for chance findings

The Nilsen et al analysis sought to understand bias in outcome measurement using two data sources and looked at ASD only and found an aOR of 0.86 (95% CI, 0.78 to 0.95) for the MBRN population and 0.85 (95% CI, 0.65 to 1.11) for the MoBa cohort.^102^ Nilsen and coauthors attributed differences between the population and the cohort to lack of precise data in the MBRN on timing, dose, and frequency of folic acid supplement use compared with the MoBa.

#### KQ 2b Do the Harms of Folic Acid Supplementation Differ by Dosage, Timing, or Duration of Therapy?

Three studies, set in Israel (Sharman Moser^104^), Denmark (Strom et al^98^), and Norway (Suren et al^100^), reported on dosage. Two studies used similar exposure and comparator variables: the Danish^98^ and Norwegian^100^ studies reported aORs or HRs ranging from 0.89 to 1.06 for folic acid doses (<0.4 mg and ≥0.4 mg vs. no use) in mid-pregnancy and autism, with overlapping CIs, suggesting no differences by dose. The Sharman Moser case-control study reported no statistically significant associations across the various exposure categories defined in this study compared with no or very low exposure with aORs ranging from 1.01 to 1.15.^104^

Two studies, set in Denmark (Virk et al,^99^) and Norway (Suren et al^100^), used similar categories for timing of folic acid exposure and similar comparators. Both found aRR or HR ranging from 0.44 to 1.39 for various exposures when compared with no exposure. The Norwegian study focused on initiation in the specified time period, whereas the Danish study focused on use of supplements within the time period. With the exception of initiation in weeks 5 to 8 in the Norwegian study (14/16,184 vs. 32/14,721, aOR, 044 [95% CI, 0.23 to 0.83]), no statistically significant associations were identified.

No studies reported on associations between duration of exposure and autism.

### Study Characteristics: Maternal Cancer

#### Norway Cohort

A single fair-quality cohort study, drawing from multiple population registries in Norway between 1999 and 2010, examined the association between exposure to folic acid supplementation during pregnancy and incidence of maternal cancer (3,781 cases) among 429,004 persons over an average of 7 years (range 0.04 to 12 years).^97^ Information on folic acid exposure came from the MBRN notification form. This information was used to characterize folic acid exposure as no use, before and/or during one pregnancy, and before and/or during two or more pregnancies.

The outcome was defined as the first incidence of any cancer diagnosis; additionally cancers were presented by type. Breast cancer was the single most commonly reported cancer (30% of all cancers). Other relatively frequently occurring cancer types included melanoma (13%), cervical and uterine cancer (12%), central nervous system cancers (9%), and other cancers (9%). Other reported cancers included colorectal, lung and trachea, non-melanoma skin, ovarian, thyroid, other endocrine, Hodgkin’s lymphoma, non-Hodgkin’s lymphoma, and leukemia. The analyses adjusted for maternal age, maternal age at first childbirth, maternal year of birth, parity, marital status, education, occupation, multivitamin use, and smoking. We rated the study as fair quality because of the potential for unmeasured confounding and potential for bias in the classification of the intervention from recall bias and lack of information on dose and adherence.

### Results of Included Studies: Maternal Cancer

#### KQ 2a Are Harms Associated With Folic Acid Supplementation to the Pregnant Person, Fetus, Neonate, or Child?

The one study we identified adjusted for maternal age, age at first childbirth, year of birth, parity, marital status, education, occupation, and smoking status; it found no statistically significant differences in the risk of developing any cancer after use of folic acid in one (HR, 1.08 [95% CI, 1.00 to 1.18]) or two or more pregnancies (HR, 1.06 [95% CI, 0.91 to 1.22]), when compared with women with no exposure to folic acid in pregnancy.^97^ However, the study did not report the total timing of folic acid exposure in months and years as this amount of time could vary between individuals who take longer or shorter to conceive. The study also did not report statistically significant associations for any individual cancer type, for example, breast cancer (HR, 0.96 to 1.10, with CIs widely spanning the null). The range of HRs for other cancers spanned from 0.26 to 2.41 with wide CIs that included the null. Sixteen percent of the sample was missing information on smoking. The authors performed multiple imputation for smoking status and reported that they found no substantial changes in the risk estimates.

#### KQ 2b Do the Harms of Folic Acid Supplementation Differ by Dosage, Timing, or Duration of Therapy?

No studies reported on variation in harms by dosage, duration, or timing of therapy.