# Chapter 2 Methods

## Key Questions and Analytic Framework

Using USPSTF methods, the investigators, USPSTF members, and AHRQ Medical Officers developed the scope, Key Questions (KQs), and analytic framework (Figure 1) that guided our literature search and limited review. Specifically, our KQs are:

Figure 1 Analytic Framework

Abbreviations: KQ=key question; NTD=neural tube defect.

This figure depicts the analytic framework that outlines the key questions addressed and the evidence covered in this report, including populations, interventions, and outcomes. On the left, the population of interest is specified as persons capable of pregnancy. Moving from left to right, the figure illustrates the overarching question: To what extent does folic acid supplementation reduce the risk for neural tube defects (first occurrence) in persons capable of getting pregnant (key question 1)? The figure depicts the pathway from folic acid supplementation to neural tube defects operating through folate levels in the body. Folic acid supplementation may result in harms (key question 2).

1a To what extent does folic acid supplementation reduce the risk for NTDs (first occurrence) in persons capable of getting pregnant?
1b Does the effect of folic acid supplementation on NTDs (first occurrence) differ by race/ethnicity?
1c Do the benefits of folic acid supplementation differ by dosage, timing, or duration of therapy?
2a Are harms associated with folic acid supplementation to the pregnant person, fetus, neonate, or child?
2b Do the harms of folic acid supplementation differ by dosage, timing, or duration of therapy?

## Search Strategies

We searched PubMed/MEDLINE®, the Cochrane Library, and Embase for English-language articles published from July 1, 2015, through July 2, 2021. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, interventions, outcomes, and study designs. Appendix B describes the complete search strategies. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov and the World Health Organization’s International Clinical Trials Registry Platform. To supplement electronic searches, we reviewed the reference lists of pertinent review articles meeting our inclusion criteria and added all previously unidentified relevant articles. We also manually reviewed all literature suggested by peer reviewers to incorporate them into the final review as needed. We conducted active surveillance through article alerts and targeted searches of journals to identify major studies published through February 10, 2023, to identify studies that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation.

## Study Selection

We selected studies on the basis of inclusion and exclusion criteria developed for each KQ based on the populations, interventions, comparators, outcomes, timing, settings, and study designs briefly described further in this section (detailed description in Appendix C). We imported all citations identified through searches and other sources into EndNote X9.2 (Thomson Reuters, New York, NY). Two investigators independently reviewed titles and abstracts. We dually and independently reviewed the full-text articles of abstracts marked for potential inclusion by either reviewer. We resolved disagreements by discussion and consensus; if necessary, we sought adjudication of conflicts from other experienced team members.

We included studies that focused on the use of folic acid supplementation for the prevention of NTD-affected pregnancies in persons capable of getting pregnant. We did not include studies focusing solely on persons on antiseizure medications, persons with a history of NTDs, or persons not capable of getting pregnant (e.g., persons of biological male sex, prepubertal persons, postmenopausal persons, sterilized persons, or persons with medical conditions rendering them sterile) as these scenarios would be outside of the realm of primary care preventive care recommendations. Studies with mixed samples that included higher-risk persons requiring specialist care were eligible as long as the study also included lower-risk persons. In such studies with mixed samples, when stratified analyses of lower-risk participants were available, we limited our review to these analyses.

We included studies that examined the use of folic acid supplementation. We also included studies that examined supplementation with micronutrients (e.g., multivitamin, iron) in combination with folic acid for the prevention of NTDs.

We included studies that compared interventions with placebo, no treatment, or dietary supplementation only when compared with folic acid supplementation; supplementation with multivitamins not containing folic acid when compared with multivitamin supplementation containing folic acid; or iron supplements not containing folic acid when compared with iron supplementation with folic acid) and food fortification alone when compared with folic acid supplementation with food fortification. For KQs 1c and 2b on dose, we included studies that compared interventions with varying doses of folic acid or micronutrient plus folic acid supplementation. For KQ 1a, we included studies that reported on the benefits of folic acid supplementation initiated before the index pregnancy or in the first trimester of the index pregnancy (to ensure that studies focused on exposure during the critical period for neural tube closure) to prevent NTDs. For KQs 1b, 1c, 2a, and 2b, we included studies that reported on the benefits or harms of folic acid supplementation initiated before the index pregnancy and during the first, second, and third trimesters of pregnancy. Harms such as colorectal cancer or other reported types of cancer, inability to diagnose vitamin B6 or B12 adequately (masking of vitamin B6 or B12 deficiency), autism, asthma or allergies were specified as eligible; additionally, other outcomes that studies described as clinical harms were eligible.

We included studies conducted in the United States or in countries considered very highly developed based on the Human Development Index as defined by the United Nations Development Programme in 2020.^91^ For KQs 1a, 1b, and 1c, we included randomized, controlled trials (RCTs), controlled trials, cohort studies, and case-control studies. For KQs 2a and 2b, we included RCTs, controlled trials, cohort studies, case-control studies, and registry data.

## Quality Assessment and Data Extraction

Two reviewers independently assessed the methodological quality of all studies that met the inclusion criteria as good, fair, or poor using predefined criteria. Disagreements were resolved by discussion and consensus. Studies with “fatal flaws” were rated as having high risk of bias (i.e., poor quality). Specific considerations for this topic include the risk of misclassification bias from retrospective recall of dose and timing of exposure; the risk of selection bias from not identifying all cases of the outcome including fetal deaths and pregnancy terminations; and the risk of confounding from not appropriately accounting for relevant factors such as family history of an outcome (e.g., NTD, asthma, autism) or maternal obesity and diabetes (for NTD outcomes only). Other fatal flaws that resulted in poor-quality ratings included high and differential attrition.

For each included study, we abstracted pertinent details about study design, setting, methodology, participant and intervention characteristics, and outcomes. A second team member reviewed all data abstractions for completeness and accuracy.

## Data Synthesis and Analysis

This report is a limited systematic review to provide an update of the evidence published since the USPSTF last considered this topic in 2017. The results of newly identified publications are narratively described. Results of studies included in previous evidence reviews are not included in the report. We qualitatively synthesized findings for each KQ by summarizing the characteristics and results of included studies in a narrative format, with accompanying summary tables. A summary table comparing the conclusions of this review with the conclusions of the previous review is provided in Chapter 4.

## Expert Review and Public Comment

USPSTF and AHRQ Medical Officers reviewed a draft research plan for this review. The draft research plan was also available for public comment from July 22, 2021, through August 18, 2021. Clarifications to search terms and inclusion and exclusion criteria were made as appropriate. A draft version of this report has been reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and has been revised based on comments, as appropriate. A draft of this report was posted for public comment. In response to public comment, citations were added to support some statements, and the document was edited for clarity.

## USPSTF and AHRQ Involvement

AHRQ funded this review under a contract to support the USPSTF. The authors of this review worked with USPSTF liaisons throughout the review process to develop and refine the scope of work, analytic framework, and KQs. AHRQ staff provided project oversight, including reviewing the draft report and assisting in the coordination of an external review of the draft report.