# Appendix F Evidence Tables

Appendix F Table 1 Study Characteristics of Included Studies on the Effect of Folic Acid Supplementation on Neural Tube Defects

Appendix F Table 2 Results of Included Studies on the Effect of Folic Acid Supplementation on Neural Tube Defects

Appendix F Table 3 Variations in Effect of Folic Acid Supplementation on Neural Tube Defects by Dosage

Appendix F Table 4 Variations in Effect of Folic Acid Supplementation on Neural Tube Defects by Timing

Appendix F Table 5 Variations in Effect of Folic Acid Supplementation on Twin Deliveries by Dose

Appendix F Table 6 Harms of Folic Acid Supplementation: Study Characteristics of Included Autism Spectrum Disorder Studies

Appendix F Table 7 Results of Included Studies on Association Between Folic Acid Supplementation and Autism Spectrum Disorders

Appendix F Table 8 Harms of Folic Acid Supplementation: Study Characteristics of Included Cancer Studies

Appendix F Table 9 Results of Included Studies on Association Between Folic Acid Supplementation and Cancer

Appendix F Table 10 Variation in Harms of Folic Acid Supplementation by Dose

Appendix F Table 11 Variation in Harms of Folic Acid Supplementation by Timing