# Appendix E Quality Assessments

Appendix E Table 1 Quality Assessments for All Included Studies

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup at least 80%; reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, for RCTs intention to treat analysis is used.
Fair: Studies will be graded “fair” if any or all of the following problems occur
without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention to treat analysis is done for RCTs.
Poor: Studies will be graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. For RCTs intention to treat analysis is lacking

Appendix E Table 2 Individual Study Quality Assessment Based on the ROBINS-I Tool, Part 1

Author Year | Is there potential for confounding of the effect of intervention in this study | Was the analysis based on splitting participants’ followup time according to intervention received? | Were intervention discontinuations or switches likely to be related to factors that are prognostic for the outcome? | Did the authors use an appropriate analysis method that controlled for all the important confounding domains? | Were confounding domains that were controlled for measured validly and reliably by the variables available in this study? | Did the authors control for any post-intervention variables that could have been affected by the intervention? | Did the authors use an appropriate analysis method that adjusted for all the important confounding domains and for time varying confounding? | Were confounding domains that were adjusted for measured validly and reliably by the variables available in this study? | Overall Bias due to Confounding | Justification/Comments
Abe et al, 2019^133^ | Yes | No information | No information | No information | No information | No information | No information | No information | Uncertain because no information | Adjusted for birth order, egg intake, breastfeeding, and caesarean; unable to adjust for everything and not sure if other other variables were controlled
Alfonso et al, 2018^134^ | Yes | No | NA | Probably yes | Probably yes | Probably no | NA | NA | Some concerns | Potential for unmeasured confounding. Adjusted for mother’s race/ethnicity (non-Hispanic White, Hispanic White, African American/Black, Asian/Other) and nativity (U.S. born, foreign born), mother’s age at pregnancy (<20, 20–24, 25–29, 30+), mother’s education at the time of pregnancy (≤11, 12, ≥13 years), use of preconception vitamins (yes, no), initiation of prenatal care (first trimester, after first trimester/never), alcohol use during pregnancy (yes, no), home environmental tobacco smoke during pregnancy; yes,no), prepregnancy BMI (<24.9, ≥25.0 kg/m), marital status (married/cohabitating, single/divorced/separated), primary source of payment for prenatal care (private health insurance, other/none), parity (only child, ≥1 sibling), and birth outcome (preterm, term birth). Maternal history of atopy (including eczema, asthma, and hay fever), duration of exclusive breastfeeding (<3 months, ≥3 months), child attendance to daycare or preschool (yes, no), infection during pregnancy (yes, no), and housing characteristics (mold or pests in the home in the past year)
Bjork et al, 2018^135^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding: maternal age, parental socioeconomic status (single mother, low educational attainment [9 y], low household income [€42 404/y or 399 999 kr/y; $49 336/y]), parity (prior pregnancies in past 21 gestational weeks), smoking (any), alcohol use (number of units per month from conception to week 19, depression
Dekker et al, 2017^136^ | Yes | No | NA | Probably yes | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding. Models were adjusted for maternal age and BMI at intake, parity, history of asthma or atopy, educational level, smoking or alcohol use during pregnancy, child’s gestational age at birth, birthweight, and ethnicity
DeVilbiss et al, 2017^101^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding: child characteristics (sex, birth year, and years resided in Stockholm County), socioeconomic indicators (education, family income, and maternal birth country), maternal characteristics (age, BMI, parity, smoking status), medication use during pregnancy (antidepressants or antiepileptics), and maternal neuropsychiatric conditions (anxiety disorders, autism, bipolar disorder, depression, epilepsy, intellectual disability, nonaffective psychotic disorders, and stress disorders)
Gildestad et al, 2016^92^ | Yes | No | NA | Probably no | NA | No | NA | NA | Some concerns | Potential for residual confounding, Adjusted for year of birth, maternal age, marital status, parity, maternal smoking, pregestational diabetes, maternal epilepsy
Gildestad et al, 2020^93^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Potential for residual confounding, did not control for history of NTDs
Hoang et al, 2019^137^ | Yes | No | NA | No | NA | No | NA | NA | High | No adjustment for confounding
Jenkins et al, 2017^138^ | Yes | No | NA | No | NA | No | NA | NA | High | No adjustment for confounding for analyses overall (the results were stratified and adjusted for sample collection status)
Kondo et al, 2015^139^ | Yes | No | NA | Probably no | NA | No | NA | NA | High | Potential for residual confounding, did not control for epilepsy or diabetes because “had nothing to do with an increase in maternal supplement use” but the reasoning behind the asssertion is not clear. Adjusted only for year and place of birth
Levine et al, 2018^103^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding (birth year, sex, SES (high vs. low), a maternal and paternal psychiatric diagnosis at childbirth (present or absent), maternal and paternal age at childbirth, and parity)
Mortensen et al, 2015^97^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding: adjusted for maternal age (<20, 20–24, 25–29, 30–34, 35–39, ≥40 years) at first childbirth in the study period 1999–2010), maternal year of birth (1949–59, 1960–69, 1970–79, 1980–89, 1990–96), parity (1, 2, 3, ≥4), marital status (unmarried, married/registered partner/cohabitant, divorced/widowed), education (compulsory [1st–7th class level], intermediate [8th–12th class level], tertiary [14th–20th class level]), occupation (armed forces/unspecified, legislators, senior officials/managers, professionals, technicians/associate professionals, clerks, service workers/shop workers/market sales workers, agricultural/forestry/fishery workers, craft/related trades workers, plant/machine operators, assemblers/elementary occupations), and smoking (never, intermittent, 10 cigarettes daily, >10 cigarettes daily, daily smoking–unknown number of cigarettes). For total cancer and breast cancer the model was also adjusted for maternal age at first childbirth (<20, 20–24, 25–29, 30–34, 35–39, ≥40 years) prior to start of followup.
Nilsen et al, 2013^102^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding: maternal age (<25, 25–29, 30–34, ≥35 years), parity (0, 1, ≥2 previous deliveries), hospital size (<500, 500–1,499, 1,500–2,999, ≥3,000 births per year), smoking. Marital status, paternal age, and year of birth and sex were poorly associated with covariates and so excluded from the analysis.
Nishigori et al, 2019^94^ | Yes | No | NA | Probably no | Yes | No | NA | NA | Some concerns | Potential for residual confounding, did not control for history of NTDs, adjusted for age, smoking habits, BMI, history or complication of diabetes and gestational diabetes mellitus, valproic acid and other antiepileptic drugs
Ozer et al, 2016^140^ | Yes | No | NA | No | NA | No | NA | NA | High | No adjustment for confounding
Petersen et al, 2019^95^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Potential for residual confounding and failure to account for time period (which includes pre- and postfortification), adjusted for age and study center, planned pregnancy
Sharman Moser et al, 2019^104^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding: age of mother at birth of child, number of family physician and obstetric visits in the 15 months before index date, subfertility, and number of children in family, birth order
Socha-Banasiak et al, 2018^141^ | Yes | No | NA | No | NA | No | NA | NA | High | No adjustment for confounding
Strom et al, 2018^98^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding: maternal age, paternal age, parity, maternal smoking during pregnancy, maternal education, family socioeconomic status, whether the pregnancy was planned, maternal prepregnancy BMI and sex of the child
Suren et al, 2013^100^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding: maternal age, paternal age, parity, maternal smoking during pregnancy, maternal education, family socioeconomic status, whether the pregnancy was planned, maternal prepregnancy BMI and sex of the child
Tsai et al, 2018^142^ | Yes | No information | No information | No information | No information | No information | No information | No information | Uncertain because no information | Adjusted for sex, age, number of older siblings, breastfeeding duration, maternal smoking during pregnancy, maternal allergy, maternal education level, maternal age, and socioeconomic status
Virk et al, 2016^99^ | Yes | No | NA | Probably no | Probably yes | Probably no | NA | NA | Some concerns | Partially adjusted for confounding: maternal age (≤24, 25–29, 30–34, ≥35 years); household socioeconomic status (higher grade professionals, middle-grade professionals, skilled work, unskilled work, student, unemployed >1year, unclassified); maternal smoking (never, ≤9 cigarettes/day, >9 cigarettes/day); and alcohol consumption during pregnancy (never, 0–1 glasses per week, 2–4 glasses per week, >4 glasses per week)

Abbreviations: BMI=body mass index; NA=not applicable; NTD=neural tube defects; ROBINS-I=Risk Of Bias In Non-randomized Studies of Interventions; SES=socioeconomic status; vs-versus.

Appendix E Table 3 Individual Study Quality Assessment Based on the ROBINS-I Tool, Part 2

Author Year | Was selection of participants into the study (or into the analysis) based on participant characteristics observed after the start of intervention? | Were the postintervention variables that influenced selection likely to be associated with intervention? | Were the postintervention variables that influenced selection likely to be influenced by the outcome or a cause of the outcome? | Do start of followup and start of intervention coincide for most participants? | Were adjustment techniques used that are likely to correct for the presence of selection biases? | Overall Bias in Selection of Participants into the Study | Justification/Comments
Abe et al, 2019^133^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Alfonso et al, 2018^134^ | Probably no | NA | NA | Yes | NA | Low | NA
Bjork et al, 2018^135^ | Probably no | NA | NA | Yes | NA | Low | NA
Dekker et al, 2017^136^ | Probably no | NA | NA | Yes | NA | Low | NA
DeVilbiss et al, 2017^101^ | Probably no | NA | NA | Yes | NA | Low | NA
Gildestad et al, 2016^92^ | Probably yes | Probably yes | Probably yes | Yes | NA | Some concerns | The study included only live births and stillbirths and excluded pregnancy terminations due to fetal anomaly. The study reported NTDs by birth outcome. The high proportion of terminations with NTDs (67%) compared with live births with NTDs (28%) and stillbirths with NTDs (5%) suggests the potential for selection bias.
Gildestad et al, 2020^93^ | Probably no | NA | NA | Yes | NA | Low | NA
Hoang et al, 2019^137^ | Yes | Yes | Yes | no | no | High | Case control of infants with and without NTDs, did not account for pregnancy losses
Jenkins et al, 2017^138^ | Yes | Yes | Yes | no | no | High | Case control of infants with and without NTDs, did not account for pregnancy losses
Kondo et al, 2015^139^ | Yes | Yes | Yes | Yes | no | High | Study included live births only, did not account for pregnancy losses. Additionally, the sample frame for controls was changed (time and region) during the study and it is not clear if there were regional or temporal practice differences.
Levine et al, 2018 ^103^ | Probably no | NA | NA | Yes | NA | Low | NA
Mortensen et al, 2015^97^ | Probably no | NA | NA | Yes | NA | Low | NA
Nilsen et al, 2013^102^ | Probably no | NA | NA | Yes | NA | Low | NA
Nishigori et al, 2019^94^ | Probably no | NA | NA | Yes | NA | Low | NA
Ozer et al, 2016^140^ | Yes | Yes | Yes | No | No | High | Case control of infants with and without NTDs, did not account for pregnancy losses
Petersen et al, 2019^95^ | Probably no | NA | NA | Yes | NA | Low | NA
Sharman Moser et al, 2019^104^ | Probably no | NA | NA | Yes | NA | Low | NA
Socha-Banasiak et al, 2018^141^ | Probably no | NA | NA | Yes | NA | Low | NA
Strom et al, 2018^98^ | Probably no | NA | NA | Yes | NA | Low | NA
Suren et al, 2013^100^ | Probably no | NA | NA | Yes | NA | Low | NA
Tsai et al, 2018^142^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Virk et al, 2016^99^ | Probably no | NA | NA | Yes | NA | Low | NA

Abbreviations: NA=not applicable; NTDs=neural tube defects; ROBINS-I=Risk Of Bias In Non-randomized Studies of Interventions.

Appendix E Table 4 Individual Study Quality Assessment Based on the ROBINS-I Tool, Part 3

Author Year | Were intervention groups clearly defined? | Was the information used to define intervention groups recorded at the start of the intervention? | Could classification of intervention status have been affected by knowledge of the outcome or risk of the outcome? | Overall Bias in Classification of Intervention | Justification/Comments
Abe et al, 2019^133^ | No information | No information | No information | Uncertain because no information | Intake based on recall
Alfonso et al, 201 ^134^ | Probably no | No | Probably yes | Some concerns | Meaured at 3–6 months postpartum; some potential for recall bias but low likelihood of awareness of outcome influencing recall of exposure differentially; no information on dose, adherence, timing
Bjork et al, 2018^135^ | Probably yes | No | No | Low | NA
Dekker et al, 2017^136^ | Probably no | No | No | Some concerns | Meaured at 18 weeks of gestation, some potential for recall bias but no reason to expect differential recall bias before outcome; actual intake (dose/adherence) unclear based on measurement
DeVilbiss et al, 2017^101^ | Probably no | No | Probably no | Some concerns | Cohort based on registration at 9 to 12 weeks gestation, dose/adherence and timing unclear
Gildestad et al, 2016^92^ | No | No | Probably no | Some concerns | Although measurement of exposure was not prospective, it was based on a registry of data collected at 12 weeks gestation, so it is unlikely to have a recall bias issue; the dose is implicit in the source, but adherence/level of exposure is unknown
Gildestad et al, 2020^93^ | No | No | Probably no | Some concerns | Although measurement of exposure was not prospective, it was based on a registry of data collected at 12 weeks gestation, so it is unlikely to have a recall bias issue; the dose is implicit in the source, but adherence/level of exposure is unknown
Hoang et al, 2019^137^ | Probably no | Probably no | Probably yes | Some concerns | Participants reported on any use of folic acid 3 months before pregnancy through the first month. Although the exposure period was correct, the measurement did not control for level of exposure and the information was obtained by recall, leading to the potential for biased recall and misclassification
Jenkins et al, 2017^138^ | No | Probably no | Probably yes | High | Potential for recall bias because participants were asked to recall exposure from 6 to 24 months after delivery, unclear if the folic acid recall pertained to the period of NTD occurrence, dose and level of adherence unclear
Kondo et al, 2015^139^ | No | Probably no | Probably yes | Some concerns | Potential for recall bias because participants were asked to recall exposure from 6 to 12 years ago, unclear that the folic acid recall pertained to the period of NTD occurrence, dose and level of adherence unclear
Levine et al, 2018^103^ | Probably no | Yes | No | Some concerns | Based on prescriptions so actual intake unclear, but appears to assume that each dispensation was 1 pill, accounts for type of dispenstation (folic acid or multivitamin) and timing
Mortensen et al, 2015^97^ | Probably no | No | Probably no | Some concerns | Cohort based on compulsory notiifcation at week 16, dose/adherence unclear, timing is measured as before/after pregnancy
Nilsen et al, 2013^102^ | Probably no | No | Probably no | Some concerns | Cohort based on compulsory notifcation at week 18, dose/adherence unclear, timing includes questions about preconceptional exposure, also asked about brands, amounts, and period of exposure. However, midway through recruitment, the method of data collection changed because 14% of the information was not computerized.Authors note that the new version included a table where the women ticked off which weeks (from gestation week −4 to 14) they had taken the supplement and asked her to write the average number of units taken per week. Then the task of making the data from the first version of the recruitment form electronically available was taken up, which implied interpretation and coding of electronical text variables. For a smaller proportion of pregnancies, for which the first version of the recruitment form had not been computerized, the original questionnaires had to be manually processed. Although this 2.3% of population was missing data on exposure and was excluded from the sample, but there is no mention of sensitivity analyses of missing data
Nishigori et al, 2019^94^ | Probably no | Probably no | Probably yes | Some concerns | Some potential for recall bias (folic acid supplements, valproic acid, and other antiepileptic drugs used were investigated for 1 year before pregnancy confirmation and for an additional 12 weeks after pregnancy confirmation), timing recorded, dose and adherence unclear
Ozer et al, 2016^140^ | No information | No information | No information | Uncertain because no information | Authors noted that patients were identified and grouped retrospectively according to the receipt of periconceptional folate supplementation so the accuracy of classification of the intervention is unclear
Petersen et al, 2019^95^ | Probably yes | Probably no | Probably yes | Some concerns | Potential for recall bias, partially addressed level of exposure by asking about daily vs. less than daily supplements, categorized by dose, asked about timing
Sharman Moser et al, 2019^104^ | Probably no | Yes | No | Some concerns | Based on prescriptions so actual intake unclear, dose is listed, timing and adherence unclear, also did not include over-the-counter medications
Socha-Banasiak et al, 2018^141^ | Probably no | No | No | Some concerns | Meaured at 2 to 72 months of child’s age, potential for recall bias, timing measured as before or in each trimester of pregnancy, dose calculated from package, adherence unclear
Strom et al, 2018^98^ | Probably no | No | Probably no | Some concerns | Folic acid supplement at −4, −1, 1–4, and 5–8 and −4–8 weeks; recall at 6–10 weeks pregnant; brand name and period taken
Suren et al, 2013^100^ | Probably no | No | Probably no | Some concerns | Cohort based on compulsory notiifcation at week 18, dose/adherence unclear, timing is measured within 4-week intervals from before the start of the pregnancy
Tsai et al, 2018^142^ | No information | No information | No information | Uncertain because no information | NA
Virk et al, 2016^99^ | Probably no | No | Probably no | Some concerns | Cohort based on registration around 12 weeks gestation, asked about timing and use each week, adherence unclear

Abbreviations: NA= not applicable; NTDs=neural tube defects; ROBINS-I=Risk Of Bias In Non-randomized Studies of Interventions; vs.=versus.

Appendix E Table 5 Individual Study Quality Assessment Based on the ROBINS-I Tool, Part 4

Author Year | Were there deviations from the intended intervention beyond what would be expected in usual practice? | Were these deviations from intended intervention unbalanced between groups and likely to have affected the outcome? | Overall Bias due to Deviation From Intended Intervention
Abe et al, 2019^133^ | No information | No information | Uncertain because no information
Alfonso et al, 2018^134^ | No information | NA | Uncertain because no information
Bjork et al, 2018^135^ | No information | NA | Uncertain because no information
Dekker et al, 2017^136^ | No information | NA | Uncertain because no information
DeVilbiss et al, 2017^101^ | No information | NA | Uncertain because no information
Gildestad et al, 2016^92^ | No information | NA | Uncertain because no information
Gildestad et al, 2020^93^ | No information | NA | Uncertain because no information
Hoang et al, 2019^137^ | No information | NA | Uncertain because no information
Jenkins et al, 2017^138^ | No information | NA | Uncertain because no information
Kondo et al, 2015^139^ | No information | NA | Uncertain because no information
Levine et al, 2018^103^ | No information | NA | Uncertain because no information
Mortensen et al, 2015^97^ | No information | NA | Uncertain because no information
Nilsen et al, 2013^102^ | No information | NA | Uncertain because no information
Nishigori et al, 2019^94^ | No information | NA | Uncertain because no information
Ozer et al, 2016^140^ | No information | NA | Uncertain because no information
Petersen et al, 2019^95^ | No information | NA | Uncertain because no information
Sharman Moser et al, 2019^104^ | No information | NA | Uncertain because no information
Socha-Banasiak et al, 2018^141^ | No information | NA | Uncertain because no information
Strom et al, 2018^98^ | No information | NA | Uncertain because no information
Suren et al, 2013^100^ | No information | NA | Uncertain because no information
Tsai et al, 2018^142^ | No information | No information | Uncertain because no information
Virk et al, 2016^99^ | No information | NA | Uncertain because no information

Abbreviations: NA=not applicable; ROBINS-I=Risk Of Bias In Non-randomized Studies of Interventions.

Appendix E Table 6 Individual Study Quality Assessment Based on the ROBINS-I Tool, Part 5

Author Year | Were outcome data available for all, or nearly all, participants? | Were participants excluded due to missing data on intervention status? | Were participants excluded due to missing data on other variables needed for the analysis? | Are the proportion of participants and reasons for missing data similar across interventions? | Is there evidence that results were robust to the presence of missing data? | Overall Bias due to Missing Data | Justification/Comments
Abe et al, 2019^133^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Alfonso et al, 2018^134^ | No | No information | No information | No information | No information | High | About 50% response rate to outcomes survey. At baseline, folic acid initation in the first trimester was 85%; at followup, it was 87%. Race, ethnicity, age, and education influenced censoring, and after adjustment, folic acid initation was not associated with censoring. Authors conducted inverse probability censoring weights in sensitivity analyses, with results that were consistent with the main analysis.
Bjork et al, 2018^135^ | No | No information | No information | No information | No information | High | No information on differential attition; overall retention at 18 months was 67% and at 36 months was 54%
Dekker et al, 2017^136^ | No | Yes | Yes | No information | Probably no | High | 25% of sample was missing and sensitivity analyses suggested differences between those who dropped out and those who were retained, leading to the potential for bias from missing data; 19.9% of the sample was excluded for missing folic acid supplementation exposure and 16.7% was missing current asthma outcomes; neither was imputed
DeVilbiss et al, 2017^101^ | No | No information | No information | Probably no | No information | Some concerns | 6% of the eligible sample was missing from the medical birth register, no sensitivity analyses done
Gildestad et al, 2016^92^ | Probably yes | No information | No information | NA | NA | Low | NA
Gildestad et al, 2020^93^ | Probably yes | No information | No information | NA | NA | Low | NA
Hoang et al, 2019^137^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Jenkins et al, 2017^138^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Kondo et al, 2015^139^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Levine et al, 2018^103^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Mortensen et al, 2015^97^ | Probably yes | No | Yes | No information | No information | Some concerns | 16% of the sample was missing information on smoking, multiple imputation was performed and showed no substantial changes in the risk estimates. Data were also missing on maternal age at first birth, education, occupation, marital status
Nilsen et al, 2013^102^ | No | No information | No information | Probably no | No information | Some concerns | 2.3% of the eligible sample was missing exposure data, and no sensitivity analyses were provided.
Nishigori et al, 2019^94^ | No | No information | No information | No information | No information | Some concerns | Excluded 2,885 people for lack of information on exposure and 1,322 for lack of information on outcomes, but no information provided on differential exclusion and no sensitivity analysis
Ozer et al, 2016^140^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Petersen et al, 2019^95^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Sharman Moser et al, 2019^104^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Socha-Banasiak et al, 2018^141^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Strom et al, 2018^98^ | Probably yes | Probably yes | No information | No information | No information | Some concerns | 87,210 mother-child pairs out of 92,676 included. Approximately 2,000 missing supplement data Education missing for 28%.
Suren et al, 2013^100^ | No | No information | No information | Probably no | No information | Some concerns | Approximately 80% of sample had available data; differential attrition on screening questionnaires
Tsai et al, 2018^142^ | No information | No information | No information | No information | No information | Uncertain because no information | NA
Virk et al, 2016^99^ | No | No information | No information | Probably no | No information | Some concerns | 20% of the eligible sample was missing from the eligible population because of a change in the recruitment forms, no sensitivity analyses done. Authors noted that women who were excluded due to missing reported weeks of supplement use were similar to those who reported weeks of use

Abbreviations: NA=not applicable; ROBINS-I=Risk Of Bias In Non-randomized Studies of Interventions.

Appendix E Table 7 Individual Study Quality Assessment Based on the ROBINS-I Tool, Part 6

Author Year | Could the outcome measure have been influenced by knowledge of the intervention received? | Were outcome assessors aware of the intervention received by study participants? | Were the methods of outcome assessment comparable across intervention groups? | Were any systematic errors in measurement of the outcome related to intervention received? | Overall Bias in Measurement of Outcomes | Justification/Comments
Abe et al, 2019^133^ | No information | No information | No information | No information | Uncertain because no information | NA
Alfonso et al, 2018^134^ | Probably no | No information | Probably yes | Probably no | Low | NA
Bjork et al, 2018^135^ | Probably no | No information | Probably yes | Probably no | Low | NA
Dekker et al, 2017^136^ | Probably no | No information | Probably yes | Probably no | Low | NA
DeVilbiss et al, 2017^101^ | Probably no | No information | Probably yes | Probably no | Low | NA
Gildestad et al, 2016^92^ | Probably no | No information | Probably yes | Probably no | Low | NA
Gildestad et al, 2020^93^ | Probably no | No information | Probably yes | Probably no | Low | NA
Hoang et al, 2019^137^ | Probably no | No information | Probably yes | Probably no | Low | NA
Jenkins et al, 2017^138^ | Probably no | No information | No | Probably yes | Some concerns | No information about control infants and whether their charts were reviewed to determine if they could have had a congenital anomaly. Only the charts of the cases were reviewed. This would have been unlikely to be missed given they were using registries, and most of the time, these birth defects would need to be reported, but methods are dissimilar.
Kondo et al, 2015^139^ | Probably no | No information | Probably yes | Probably no | Low | NA
Levine et al, 2018^103^ | Probably no | No information | Probably yes | Probably no | Low | NA
Mortensen et al, 2015^97^ | No | No information | Yes | Probably no | Low | NA
Nilsen et al, 2013^102^ | Probably no | No information | Probably yes | Probably no | Low | NA
Nishigori et al, 2019^94^ | Probably no | No information | Probably yes | Probably no | Low | NA
Ozer et al, 2016^140^ | Probably no | No information | Probably yes | Probably no | Low | NA
Petersen et al, 2019^95^ | Probably no | No information | Probably yes | Probably no | Low | NA
Sharman Moser et al, 2019^104^ | Probably no | No information | Probably yes | Probably no | Low | NA
Socha-Banasiak et al, 2018 ^141^ | Probably no | No information | Probably yes | Probably no | Low | NA
Strom et al, 2018^98^ | No | No information | Yes | Probably no | Low | NA
Suren et al, 2013^100^ | Probably no | No information | Probably yes | Probably no | Low | NA
Tsai et al, 2018^142^ | No information | No information | No information | No information | Uncertain because no information | NA
Virk et al, 2016^99^ | Probably no | No information | Probably yes | Probably no | Low | NA

Abbreviations: NA= not applicable; ROBINS-I=Risk Of Bias In Non-randomized Studies of Interventions.

Appendix E Table 8 Individual Study Quality Assessment Based on the ROBINS-I Tool, Part 7

Author Year | Is the reported effect estimate likely to be selected, on the basis of the results, from multiple outcome measurements within the outcome domain? | Is the reported effect estimate likely to be selected, on the basis of the results, from multiple analyses of the intervention outcome relationship? | Is the reported effect estimate likely to be selected, on the basis of the results, from different subgroups? | Overall Bias in Selection of the Reported Result
Abe et al, 2019^133^ | No information | No information | No information | Uncertain because no information
Alfonso et al, 2018^134^ | No information | No information | No information | Uncertain because no information
Bjork et al, 201 ^135^ | No information | No information | No information | Uncertain because no information
Dekker et al, 2017^136^ | No information | No information | No information | Uncertain because no information
DeVilbiss et al, 2017^101^ | No information | No information | No information | Uncertain because no information
Gildestad et al, 2016^92^ | No information | No information | No information | Uncertain because no information
Gildestad et al, 2020^93^ | No information | No information | No information | Uncertain because no information
Hoang et al, 2019^137^ | No information | No information | No information | Uncertain because no information
Jenkins et al, 2017^138^ | No information | No information | No information | Uncertain because no information
Kondo et al, 2015^139^ | No information | No information | No information | Uncertain because no information
Levine et al, 2018^103^ | No information | No information | No information | Uncertain because no information
Mortensen et al, 2015^97^ | No information | No information | No information | Uncertain because no information
Nilsen et al, 2013^102^ | No information | No information | No information | Uncertain because no information
Nishigori et al, 2019^94^ | No information | No information | No information | Uncertain because no information
Ozer et al, 2016^140^ | No information | No information | No information | Uncertain because no information
Petersen et al, 2019^95^ | No information | No information | No information | Uncertain because no information
Sharman Moser et al, 2019^104^ | No information | No information | No information | Uncertain because no information
Socha-Banasiak et al, 2018^141^ | No information | No information | No information | Uncertain because no information
Strom et al, 2018^98^ | No information | No information | No information | Uncertain because no information
Suren et al, 2013^100^ | No information | No information | No information | Uncertain because no information
Tsai et al, 2018^142^ | No information | No information | No information | Uncertain because no information
Virk et al, 2016^99^ | No information | No information | No information | Uncertain because no information

Abbreviations: ROBINS-I=Risk Of Bias In Non-randomized Studies of Interventions.

Appendix E Table 9 Individual Study Quality Assessment Based on the ROBINS-I Tool Overall Risk of Bias, Part 8

Author, Year | Overall Rating Justification/Comments | Overall Rating Justification/Comments | Does rating of study vary by outcome?
Abe et al, 2019^133^ | Uncertain because no information | Abstract only, so very limited information; adjusted for some outcomes but unable to adjust for everything and unsure what other variables were controlled for; intervention status based on recall, no information on how missing data were handled; no information on how reported results were selected; no information on measure of outcomes | No
Alfonso et al, 2018^134^ | High | Potential for bias from unmeasured confounding, potential for bias from attrition | No
Bjork et al, 2018^135^ | High | Potential for bias from unmeasured confounding, potential for bias from attrition | No
Dekker et al, 2017^136^ | High | Potential for bias from attrition, residual confounding, and recall | No
DeVilbiss et al, 2017^101^ | Some concerns | Potential for bias from unmeasured confounding, potential for bias from attrition | No
Gildestad et al, 2016^92^ | Some concerns | Potential for bias from unmeasured confounding, potential for recall bias, potential for selection bias | No
Gildestad et al, 2020^93^ | Some concerns | Potential for bias from unmeasured confounding, potential for recall bias | No
Hoang et al, 2019^137^ | High | No adjustment for potential confounding, risk of selection bias because pregnancy losses were not included | No
Jenkins et al, 2017^138^ | High | Risk of bias from confounding, selection, and recall | No
Kondo et al, 2015^139^ | High | Potential for bias from selection, potential for recall bias | No
Levine et al, 2018^103^ | Some concerns | Potential for bias from unmeasured confounding, potential for bias in measurement of exposure from prescriptions | No
Mortensen et al, 2015^97^ | Some concerns | Potential for bias from unmeasured confounding | No
Nilsen et al, 2013^102^ | Some concerns | Potential for bias from unmeasured confounding, potential for bias from attrition and measurement of exposure | No
Nishigori et al, 2019^94^ | Some concerns | Potential for confounding, intervention status based on recall, no information on how missing data were handled | No
Ozer et al, 2016^140^ | High | Risk of bias from confounding and selection | No
Petersen et al, 2019^95^ | Some concerns | Potential for bias from unmeasured confounding and confounding from changes in food fortification, potential for recall bias | No
Sharman Moser et al, 2019^104^ | Some concerns | Potential for bias from unmeasured confounding, potential for bias in measurement of exposure from prescriptions | Yes
Socha-Banasiak et al, 2018^141^ | High | Potential for bias from confounding | No
Strom et al, 2018^98^ | Some concerns | Confounding, missing data | No
Suren et al, 2013^100^ | Some concerns | Potential for bias from unmeasured confounding, potential for bias from attrition | No
Tsai et al, 2018^142^ | Uncertain because no information | Abstract only, so very limited information; adjusted for some outcomes but unable to adjust for everything; very little information on intervention, no information on how missing data were handled, no information on how results were selected | No
Virk et al, 2016^99^ | Some concerns | Potential for bias from unmeasured confounding, potential for bias from attrition | No

Abbreviations: ROBINS-I=Risk Of Bias In Non-randomized Studies of Interventions.

Appendix E Table 10 Individual Study Quality Assessment Based on Cochrane RoB 2.0

Author, Year | Domain 1 RoB | Domain 2 RoB | Domain 3 RoB | Domain 4 RoB | Domain 5 RoB | Overall RoB | Justification/Comments
Bortolus et al, 2021 ^96^ | Low | Low | Low | Low | Low | Low | An appropriate analysis was not used to compare groups. No information on missing data regarding adverse events

Abbreviations: RoB=risk of bias.