# Appendix D Excluded Studies

List of Exclusion Codes:

- X 1: Wrong publication type (editorials, letters, opinions, or commentaries to the editor with no primary data)
- X 2: Wrong population (persons not capable of getting pregnant, persons with history NTDs)
- X 3: Wrong intervention (food fortification only, naturally occurring folate only, counseling to improve dietary supplementation)
- X 4: Wrong timing (supplementation initiated after the first month of pregnancy for benefits only)
- X 5: Wrong comparator (folic acid vs. active comparators, lower vs. higher doses of folic acid supplementation for timing and duration only)
- X 6: Wrong outcome (benefits other than NTDs)
- X 7: Wrong country (countries with Human Development Index of low to high)
- X 8: Wrong study design (case reports, case series, systematic reviews)
- X 9: Wrong Language (non-English)
- X 10: Data not abstractable (insufficient evidence reported in conference abstract, full-text irretrievable)

1 The use of folic acid in pregnancy and prevalence of neural tube defects in Europe. Geneesmiddelenbulletin. 2016;50(11):125–6. Exclusion Code: X 1.
2 Impact of folic acid supplementation during pregnancy on cognitive performance of children at age 11 years: preliminary results from the FASSTT Offspring study. Proceedings of the Nutrition Society. 2018;77(OCE3)doi: 10.1017/S0029665118001027. PMID: CN-01993569. Exclusion Code: X 6.
3 Early life primary prevention against infant bronchial asthma: a 3-year follow-up. International journal of clinical and experimental medicine. 2020;13(3):2009‐15. PMID: CN-02147346. Exclusion Code: X 7.
4 Abe M. Impact of season of birth and maternal folic acid supplementation on food allergy in children. Allergy: European Journal of Allergy and Clinical Immunology. 2016;71:369–70. doi: 10.1111/all.12974. Exclusion Code: X 10.
5 Abe M. The effects of egg and folic acid intake on food allergy onset by the birth season of children. Allergy: European Journal of Allergy and Clinical Immunology. 2018;73:650–1. doi: 10.1111/all.13539. Exclusion Code: X 10.
6 Abe M. Effect of folic acid supplementation to pregnant women on food hypersensitivities in children in which neither parent had any allergies. Allergy: European Journal of Allergy and Clinical Immunology. 2020;75(SUPPL 109):530–1. doi: 10.1111/all.14508. Exclusion Code: X 10.
7 Alfonso VH, Bandoli G, von Ehrenstein O, Early Folic Acid Supplement Initiation and Risk of Adverse Early Childhood Respiratory Health: A Population-based Study. Matern Child Health J. 2018 Jan;22(1):111–9. doi: 10.1007/s10995-017-2360-6. PMID: 28887720. Exclusion Code: X 5.28887720
8 Alfonso VH, von Ehrenstein O, Bandoli G, The Influence of Pre-natal Supplement Initiation on Preterm Birth Among Majority Hispanic Women in Los Angeles County: The Role of Nativity. Matern Child Health J. 2016 Sep;20(9):1861–8. doi: 10.1007/s10995-016-1990-4. PMID: 27060911. Exclusion Code: X 6.27060911
9 Alotbi FK S, al-Dulaimy AF J, Jameel GH. Carcinoembryonic Antigen, Alpha Fetoprotein And Folic Acid Levels In Pregnant Women And Fetuses With Anencephaly. Biochemical and Cellular Archives. 2019;19(1):1713–6. Exclusion Code: X 7.
10 Amitai Y, Shental H, Atkins-Manelis L, Pre-conceptional folic acid supplementation: A possible cause for the increasing rates of ankyloglossia. Med Hypotheses. 2020 Jan;134:109508. doi: 10.1016/j.mehy.2019.109508.31835174
11 Balogun OO, da Silva Lopes K, Ota E, Vitamin supplementation for preventing miscarriage. Cochrane Database Syst Rev. 2016 May 6;2016(5):Cd004073. doi: 10.1002/14651858.CD004073.pub4. PMID: 27150280. Exclusion Code: X 6.27150280
12 Baron R, Te Velde SJ, Heymans MW, The Relationships of Health Behaviour and Psychological Characteristics with Spontaneous Preterm Birth in Nulliparous Women. Matern Child Health J. 2017 Apr;21(4):873–82. doi: 10.1007/s10995-016-2160-4. PMID: 27581004. Exclusion Code: X 6.27581004
13 Belokrinitskaya T, Frolova N, Turanova O, Effect of folic acid, metafolin and docosahexaenoic acid supplementation on singleton pregnancy outcomes and congenital heart defects in offspring. European Journal of Obstetrics Gynecology and Reproductive Biology. 2019;234:e73. doi: 10.1016/j.ejogrb.2018.08.316. Exclusion Code: X 6.
14 Bendahan ZC, Escobar LM, Castellanos JE, Effect of folic acid on animal models, cell cultures, and human oral clefts: a literature review. Egyptian Journal of Medical Human Genetics. 2020;21(1)doi: 10.1186/s43042-020-00108-x. Exclusion Code: X 6.
15 Bergman JE, Otten E, Verheij JB, Folic acid supplementation influences the distribution of neural tube defect subtypes: A registry-based study. Reprod Toxicol. 2016 Jan;59:96–100. doi: 10.1016/j.reprotox.2015.11.007. PMID: 26627544. Exclusion Code: X 8.26627544
16 Bo Y, Zhu Y, Tao Y, Association Between Folate and Health Outcomes: An Umbrella Review of Meta-Analyses. Front Public Health. 2020;8:550753. doi: 10.3389/fpubh.2020.550753. PMID: 33384976. Exclusion Code: X 8.33384976
17 Bragg M, Chavarro JE, Hamra GB, Prenatal Diet as a Modifier of Environmental Risk Factors for Autism and Related Neurodevelopmental Outcomes. Curr Environ Health Rep. 2022 Mar 19doi: 10.1007/s40572-022-00347-7. PMID: 35305256. Exclusion Code: X1.35305256
18 Bulloch RE, Lovell AL, Jordan VM B, Maternal folic acid supplementation for the prevention of preeclampsia: A systematic review and meta-analysis. Paediatr Perinat Epidemiol. 2018 Jul;32(4):346–57. doi: 10.1111/ppe.12476. PMID: 29882975. Exclusion Code: X 8.29882975
19 Bupp CP, Sarasua SM, Dean JH, When folic acid fails: Insights from 20 years of neural tube defect surveillance in South Carolina. Am J Med Genet A. 2015 Oct;167a(10):2244–50. doi: 10.1002/ajmg.a.37168. PMID: 26108864. Exclusion Code: X 5.26108864
20 Caffrey A, McNulty H, Rollins M, Effects of maternal folic acid supplementation during the second and third trimesters of pregnancy on neurocognitive development in the child: an 11-year followup from a randomised controlled trial. BMC Med. 2021 Mar 10;19(1):73. doi: 10.1186/s12916-021-01914-9. PMID: 33750355. Exclusion Code: X 6.33750355
21 Castro K, Klein Lda S, Baronio D, Folic acid and autism: What do we know? Nutr Neurosci. 2016 Sep;19(7):310–7. doi: 10.1179/1476830514y.0000000142. PMID: 25087906. Exclusion Code: X 8.25087906
22 Charles DH M, Ness AR, Campbell D, Folic acid supplements in pregnancy and birth outcome: re-analysis of a large randomised controlled trial and update of Cochrane review. Paediatric and perinatal epidemiology. 2005;19(2):112–24. PMID: CN-01767664. Exclusion Code: X 6.15787886
23 Chavarro JE. Folic acid and female fertility in natural and assisted reproduction. International Journal of Fertility and Sterility. 2015;9:12. doi: 10.22074/ijfs.2015.4697. Exclusion Code: X 6.
24 Chen Z, Xing Y, Yu X, Effect of Folic Acid Intake on Infant and Child Allergic Diseases: Systematic Review and Meta-Analysis. Front Pediatr. 2020;8:615406. doi: 10.3389/fped.2020.615406. PMID: 33537268. Exclusion Code: X 8.33537268
25 Cheng G, Sha T, Gao X, The Associations between the Duration of Folic Acid Supplementation, Gestational Diabetes Mellitus, and Adverse Birth Outcomes based on a Birth Cohort. Int J Environ Res Public Health. 2019 Nov 15;16(22)doi: 10.3390/ijerph16224511. PMID: 31731641. Exclusion Code: X 7.31731641
26 Cheng J, Eskenazi B, Widjaja F, Improving autism perinatal risk factors: A systematic review. Med Hypotheses. 2019 Jun;127:26–33. doi: 10.1016/j.mehy.2019.03.012. PMID: 31088644. Exclusion Code: X 8.31088644
27 Compañ Gabucio LM, García de la Hera M, Torres Collado L, The Use of Lower or Higher Than Recommended Doses of Folic Acid Supplements during Pregnancy Is Associated with Child Attentional Dysfunction at 4–5 Years of Age in the INMA Project. Nutrients. 2021 Jan 23;13(2)doi: 10.3390/nu13020327. PMID: 33498619. Exclusion Code: X6.33498619
28 Corsi DJ, Gaudet LM, El-Chaar D, Effect of high-dose folic acid supplementation on the prevention of preeclampsia in twin pregnancy. J Matern Fetal Neonatal Med. 2020 Feb 18:1–6. doi: 10.1080/14767058.2020.1725882. PMID: 32067533. Exclusion Code: X 6.32067533
29 Cortés-Albornoz MC, García-Guáqueta DP, Velez-van-Meerbeke A, Maternal Nutrition and Neurodevelopment: A Scoping Review. Nutrients. 2021 Oct 8;13(10)doi: 10.3390/nu13103530. PMID: 34684531. Exclusion Code: X1.34684531
30 Crider KS, Qi YP, Devine O, Modeling the impact of folic acid fortification and supplementation on red blood cell folate concentrations and predicted neural tube defect risk in the United States: have we reached optimal prevention? Am J Clin Nutr. 2018 Jun 1;107(6):1027–34. doi: 10.1093/ajcn/nqy065. PMID: 29767673. Exclusion Code: X 8.29767673
31 Cueto HT, Riis AH, Hatch EE, Folic acid supplementation and fecundability: a Danish prospective cohort study. Eur J Clin Nutr. 2016 Jan;70(1):66–71. doi: 10.1038/ejcn.2015.94. PMID: 26081493. Exclusion Code: X 6.26081493
32 Czeizel AE, Vereczkey A, Szabó I. Folic acid in pregnant women associated with reduced prevalence of severe congenital heart defects in their children: a national population-based case-control study. Eur J Obstet Gynecol Reprod Biol. 2015 Oct;193:34–9. doi: 10.1016/j.ejogrb.2015.06.024. PMID: 26225846. Exclusion Code: X 6.26225846
33 Daly M, Kipping RR, Tinner LE, Preconception exposures and adverse pregnancy, birth and postpartum outcomes: Umbrella review of systematic reviews. Paediatr Perinat Epidemiol. 2022 Mar;36(2):288–99. doi: 10.1111/ppe.12855. PMID: 34970757. Exclusion Code: X1.34970757
34 Davies E, Rogers NK, Lloyd-Lavery A, Whaťs new in atopic eczema? An analysis of systematic reviews published in 2015. Part 1: epidemiology and methodology. Clin Exp Dermatol. 2018 Jun;43(4):375–9. doi: 10.1111/ced.13377. PMID: 29314180. Exclusion Code: X 8.29314180
35 De Ocampo MP G, Araneta MR G, Macera CA, Folic acid supplement use and the risk of gestational hypertension and preeclampsia. Women Birth. 2018 Apr;31(2):e77–e83. doi: 10.1016/j.wombi.2017.08.128. PMID: 28870524. Exclusion Code: X 6.28870524
36 De-Regil LM, Peña-Rosas JP, Fernández-Gaxiola AC, Effects and safety of periconceptional oral folate supplementation for preventing birth defects. Cochrane Database Syst Rev. 2015 Dec 14(12):Cd007950. doi: 10.1002/14651858.CD007950.pub3. PMID: 26662928. Exclusion Code: X 8.26662928
37 Dokter EM J, Van Rooij IALM, Wijers CHW, Interaction between MTHFR 677C>T and periconceptional folic acid supplementation in the risk of hypospadias. European Journal of Epidemiology. 2015;30(8):927–8. doi: 10.1007/s10654-015-0072-z. Exclusion Code: X 6.
38 Dolk H, McCullough N, Callaghan S, Risk factors for congenital heart disease: The Baby Hearts Study, a population-based case-control study. PLoS One. 2020;15(2):e0227908. doi: 10.1371/journal.pone.0227908. PMID: 32092068. Exclusion Code: X 6.32092068
39 Donnan J, Walsh S, Sikora L, A systematic review of the risks factors associated with the onset and natural progression of spina bifida. Neurotoxicology. 2017 Jul;61:20–31. doi: 10.1016/j.neuro.2016.03.008. PMID: 27000518. Exclusion Code: X 8.27000518
40 Douglas Wilson R, Audibert F, Brock JA, Pre-conception folic acid and multivitamin supplementation for the primary and secondary prevention of neural tube befects and other folic acid-sensitive congenital anomalies. Journal of Obstetrics and Gynaecology Canada. 2015;37(6):550–2. doi: 10.1016/S1701-2163(15)30231-0. Exclusion Code: X 9.
41 Esposito DB, Parker SE, Mitchell AA, Periconceptional nonsteroidal antiinflammatory drug use, folic acid intake, and the risk of spina bifida. Birth Defects Res. 2021 Oct 15;113(17):1257–66. doi: 10.1002/bdr2.1944. PMID: 34346174. Exclusion Code: X6.34346174
42 Feng Y, Cai J, Tong X, Non-inheritable risk factors during pregnancy for congenital heart defects in offspring: A matched case-control study. Int J Cardiol. 2018 Aug 1;264:45–52. doi: 10.1016/j.ijcard.2018.04.003. PMID: 29685690. Exclusion Code: X 6.29685690
43 Fisher BG, Lakshman R. QUESTION 1: Does folic acid supplementation reduce the incidence or severity of anaemia in neonates with a positive direct Coombs test? Archives of Disease in Childhood. 2016;101(11):1071–3. doi: 10.1136/archdischild-2016-311508. Exclusion Code: X 1.
44 Fogacci S, Fogacci F, Cicero AF G. Nutraceuticals and Hypertensive Disorders in Pregnancy: The Available Clinical Evidence. Nutrients. 2020 Jan 31;12(2)doi: 10.3390/nu12020378. PMID: 32023928. Exclusion Code: X 6.32023928
45 Gao Y, Sheng C, Xie RH, New Perspective on Impact of Folic Acid Supplementation during Pregnancy on Neurodevelopment/Autism in the Offspring Children - A Systematic Review. PLoS One. 2016;11(11):e0165626. doi: 10.1371/journal.pone.0165626. PMID: 27875541. Exclusion Code: X 8.27875541
46 Gardner H, Green K, Gardner AS, Observations on the health of infants at a time of rapid societal change: a longitudinal study from birth to fifteen months in Abu Dhabi. BMC Pediatr. 2018 Feb 7;18(1):32. doi: 10.1186/s12887-018-1016-z. PMID: 29415674. Exclusion Code: X 6.29415674
47 Gong R, Wang ZP, Wang M, Effects of folic acid supplementation during different pregnancy periods and relationship with the other primary prevention measures to neural tube defects. JMatern Fetal Neonatal Med. 2016 Dec;29(23):3894–901. doi: 10.3109/14767058.2016.1152241. PMID: 27023398. Exclusion Code: X 7.27023398
48 Goodrich AJ, Volk HE, Tancredi DJ, Joint effects of prenatal air pollutant exposure and maternal folic acid supplementation on risk of autism spectrum disorder. Autism Res. 2018 Jan;ll(l):69–80. doi: 10.1002/aur. 1885. PMID: 29120534. Exclusion Code: X 3.29120534
49 Guo BQ, Li HB, Zhai DS, Association of maternal prenatal folic acid intake with subsequent risk of autism spectrum disorder in children: A systematic review and metaanalysis. Prog Neuropsychopharmacol Biol Psychiatry. 2019 Aug 30;94:109650. doi: 10.1016//.pnpbp.2019.109650. PMID: 31085214. Exclusion Code: X 8.31085214
50 Hausman DB, Holder A, Park HJ, Vitamin B12 status and infant outcome in a community-based folic acid intervention study. FASEB journal. Conference: experimental biology 2016, EB. San diego, CA united states. Conference start: 20160402. Conference end: 20160406. Conference publication: (var.pagings). 2016;30(no pagination)PMID: CN01266506. Exclusion Code: X 6.
51 Hoyt AT, Canfield MA, Shaw GM, The relationship of sociodemographic and hispanic acculturation factors with isolated anotia/microtia. Birth Defects Research Part A - Clinical and Molecular Teratology. 2014;100(5):399. Exclusion Code: X 6.
52 Huang L, Yu X, Li L, Duration of periconceptional folic acid supplementation and risk of gestational diabetes mellitus. Asia Pac JClin Nutr. 2019;28(2):321–9. doi: 10.6133/apjcn.201906_28(2).0014. PMID: 31192561. Exclusion Code: X6.31192561
53 Hugonin B. Telemedicine and telemonitoring in preconceptional and prenatal health during COVID-19, for reduce the risks in woman, mother and newborn. Education, surveillance, management of chronic diseases, teleassistance for improve the quality of preconceptional health and maternal fetal care. Journal of Maternal-Fetal and Neonatal Medicine. 2021;34(SUPPL 1):20. doi: 10.1080/14767058.2021.1962370. Exclusion Code: X1.
54 Husebye ES N, Daltveit AK, Spigset O, Language delay in children of mothers with epilepsy is associated with the use of antiepileptic drugs - The Norwegian Mother and Child Cohort Study. European Journal of Neurology. 2019;26:102. doi: 10.1111/ene.14017. Exclusion Code: X 2.
55 Jankovic-Karasoulos T, Furness DL, Leemaqz SY, Maternal folate, one-carbon metabolism and pregnancy outcomes. Matern Child Nutr. 2021 Jan;17(1):e13064. doi: 10.1111/mcn.13064. PMID: 32720760. Exclusion Code: X 6.32720760
56 Jensen ET, Kuhl JT, Martin LJ, Prenatal, intrapartum, and postnatal factors are associated with pediatric eosinophilic esophagitis. J Allergy Clin Immunol. 2018 Jan;141(1):214–22. doi: 10.1016/j.jaci.2017.05.018. PMID: 28601683. Exclusion Code: X 6.28601683
57 Kalem P, Benli AR, Koroglu M, The effect of ferritin, vitamin B12 and folic acid on pregnancy outcomes. International Journal of Clinical and Experimental Medicine. 2016;9(11):22413–7. Exclusion Code: X 6.
58 Kapapa M, Becker N, Serra A. Risk factors for anorectal and associated malformations in German children: A 10-year analysis. Pediatr Neonatol. 2021 Jan;62(1):97–105. doi: 10.1016/j.pedneo.2020.09.008. PMID: 33071156. Exclusion Code: X 6.33071156
59 Kar A, Kar T, Kanungo S, Risk factors, organ weight deviation and associated anomalies in neural tube defects: A prospective fetal and perinatal autopsy series. Indian J Pathol Microbiol. 2015 Jul-Sep;58(3):285–91. doi: 10.4103/0377-4929.162832. PMID: 26275247. Exclusion Code: X 5.26275247
60 Kavlak E, Tekin F, Kavlak HA. Effect of parental factors on quality of life and motor performance of children with spina bifida. Turkish Journal of Physiotherapy and Rehabilitation. 2019;30(2):S101. Exclusion Code: X 2.
61 Kerr SM, Parker SE, Mitchell AA, Periconceptional maternal fever, folic acid intake, and the risk for neural tube defects. Ann Epidemiol. 2017 Dec;27(12):777–82.e1. doi: 10.1016/j.annepidem.2017.10.010. PMID: 29133009. Exclusion Code: X 3.29133009
62 Kerr SM, Parker SE, Mitchell AA, Folic acid antagonist use before and during pregnancy and risk for selected birth defects. Birth Defects Res. 2020 Nov;112(18):1526–40. doi: 10.1002/bdr2.1789. PMID: 32875745. Exclusion Code: X 2.32875745
63 Koning IV, Dudink J, Groenenberg IA L, Prenatal cerebellar growth trajectories and the impact of periconceptional maternal and fetal factors. Hum Reprod. 2017 Jun 1;32(6):1230–7. doi: 10.1093/humrep/dex079. PMID: 28453631. Exclusion Code: X 6.28453631
64 Lauda-Świeciak A, Bednarek S, Skórczewski J, Analysis of the origin of birth defects in pregnant women from the Kujawy-Pomerania Region. Ginekol Pol. 2016;87(10):711–6. doi: 10.5603/gp.2016.0073. PMID: 27958624. Exclusion Code: X 5.27958624
65 Lee YQ, Collins CE, Gordon A, The Relationship between Maternal Nutrition during Pregnancy and Offspring Kidney Structure and Function in Humans: A Systematic Review. Nutrients. 2018 Feb 21;10(2)doi: 10.3390/nu10020241. PMID: 29466283. Exclusion Code: X 6.29466283
66 Li M, Francis E, Hinkle SN, Preconception and Prenatal Nutrition and Neurodevelopmental Disorders: A Systematic Review and Meta-Analysis. Nutrients. 2019 Jul 17;11(7)doi: 10.3390/nu11071628. PMID: 31319515. Exclusion Code: X 8.31319515
67 Li M, Li S, Chavarro JE, Prepregnancy Habitual Intakes of Total, Supplemental, and Food Folate and Risk of Gestational Diabetes Mellitus: A Prospective Cohort Study. Diabetes Care. 2019 Jun;42(6):1034–41. doi: 10.2337/dc18-2198. PMID: 31010874. Exclusion Code: X 6.31010874
68 Li W, Xu B, Cao Y, Association of maternal folate intake during pregnancy with infant asthma risk. Sci Rep. 2019 Jun 6;9(1):8347. doi: 10.1038/s41598-019-44794-z. PMID: 31171831. Exclusion Code: X 8.31171831
69 Liu J, Li Z, Ye R, Periconceptional folic acid supplementation and risk of parent-reported asthma in children at 4–6 years of age. ERJ Open Res. 2020 Jan;6(1)doi: 10.1183/23120541.00250-2019. PMID: 32280668. Exclusion Code: X 7.32280668
70 Lowry RB, Bedard T, MacFarlane AJ, Prevalence rates of spina bifida in Alberta, Canada: 2001–2015. Can we achieve more prevention? Birth Defects Res. 2019 Feb 1;111(3):151–8. doi: 10.1002/bdr2.1438. PMID: 30561844. Exclusion Code: X 5.30561844
71 Martinussen MP, Bracken MB, Triche EW, Folic acid supplementation in early pregnancy and the risk of preeclampsia, small for gestational age offspring and preterm delivery. Eur J Obstet Gynecol Reprod Biol. 2015 Dec;195:94–9. doi: 10.1016/j.ejogrb.2015.09.022. PMID: 26500184. Exclusion Code: X 6.26500184
72 McAlpine JM, Scott R, Scuffham PA, The association between third trimester multivitamin/mineral supplements and gestational length in uncomplicated pregnancies. Women Birth. 2016 Feb;29(1):41–6. doi: 10.1016/j.wombi.2015.07.185. PMID: 26319504. Exclusion Code: X 6.26319504
73 McNulty H, Rollins M, Cassidy T, Effect of continued folic acid supplementation beyond the first trimester of pregnancy on cognitive performance in the child: a follow-up study from a randomized controlled trial (FASSTT Offspring Trial). BMC Med. 2019 Oct 31;17(1):196. doi: 10.1186/s12916-019-1432-4. PMID: 31672132. Exclusion Code: X 6.31672132
74 Meador KJ, Pennell PB, May RC, Effects of periconceptional folate on cognition in children of women with epilepsy: NEAD study. Neurology. 2020 Feb 18;94(7):e729–e40. doi: 10.1212/wnl.0000000000008757. PMID: 31871217. Exclusion Code: X 2.31871217
75 Minns RA. Folic acid and neural tube defects. Spinal cord. 1996;34(8):460–5. PMID: CN-01763218. Exclusion Code: X 1.8856852
76 Monteagudo C, Mariscal-Arcas M, Heras-Gonzalez L, Effects of maternal diet and environmental exposure to organochlorine pesticides on newborn weight in Southern Spain. Chemosphere. 2016 Aug;156:135–42. doi: 10.1016/j.chemosphere.2016.04.103. PMID: 27174826. Exclusion Code: X 6.27174826
77 Murphy MS Q, Muldoon KA, Sheyholislami H, Impact of high-dose folic acid supplementation in pregnancy on biomarkers of folate status and 1-carbon metabolism: An ancillary study of the Folic Acid Clinical Trial (FACT). Am J Clin Nutr. 2021 May 8;113(5):1361–71. doi: 10.1093/ajcn/nqaa407. PMID: 33675351. Exclusion Code: X 6.33675351
78 Murray LK, Smith MJ, Jadavji NM. Maternal oversupplementation with folic acid and its impact on neurodevelopment of offspring. Nutr Rev. 2018 Sep 1;76(9):708–21. doi: 10.1093/nutrit/nuy025. PMID: 30010929. Exclusion Code: X 8.30010929
79 Mutlu M, Aslan Y, Kader S, Evaluation of newborns with open neural tube defect retrospectively. Turkiye Klinikleri Pediatri. 2018;27(1):20–7. doi: 10.5336/pediatr.2017-59455. Exclusion Code: X 9.
80 NCT02685813 (https://clinicaltrials.gov/show/NCT02685813). Incidence of Pregnancies and Births With Spina Bifida in Denmark in 2008–2014. 2016. Exclusion Code: X 6.
81 Nct. Fish Oil and Folate Supplementation During Pregnancy. https://clinicaltrials.gov/show/NCT01180933. 2010PMID: CN-02025733. Exclusion Code: X 6.
82 Neumann D, Herbert SE, Peterson ER, A longitudinal study of antenatal and perinatal risk factors in early childhood cognition: Evidence from Growing Up in New Zealand. Early Hum Dev. 2019 May;132:45–51. doi: 10.1016/j.earlhumdev.2019.04.001. PMID: 30974313. Exclusion Code: X 6.30974313
83 Oakley GP Jr. Classifying by cause and preventing the many causes of spina bifida and anencephaly. Pediatr Res. 2020 Jan;87(2):183–4. doi: 10.1038/s41390-019-0658-3. PMID: 31683272. Exclusion Code: X 1.31683272
84 O'Malley EG, Cawley S, Kennedy RA K, Maternal anaemia and folate intake in early pregnancy. J Public Health (Oxf). 2018 Sep 1;40(3):e296–e302. doi: 10.1093/pubmed/fdy013. PMID: 29394368. Exclusion Code: X 6.29394368
85 Oulhote Y, Lanphear B, Braun JM, Gestational Exposures to Phthalates and Folic Acid, and Autistic Traits in Canadian Children. Environ Health Perspect. 2020 Feb;128(2):27004. doi: 10.1289/ehp5621. PMID: 32073305. Exclusion Code: X 3.32073305
86 Palmsten K, Suhl J, Conway KM, Influenza vaccination during pregnancy and risk of selected major structural non-cardiac birth defects, National Birth Defects Prevention Study 2006–2011. Pharmacoepidemiol Drug Saf. 2022 Apr 2 doi: 10.1002/pds.5435. PMID: 35366035. Exclusion Code: X3.35366035
87 Parr CL, Magnus MC, Karlstad Ø, Maternal Folate Intake during Pregnancy and Childhood Asthma in a Population-based Cohort. Am J Respir Crit Care Med. 2017 Jan 15;195(2):221–8. doi: 10.1164/rccm.201604-0788OC. PMID: 27518161. Exclusion Code: X 3.27518161
88 Petersen JM, Parker SE, Crider KS, One-Carbon Cofactor Intake and Risk of Neural Tube Defects Among Women Who Meet Folic Acid Recommendations: A Multicenter Case-Control Study. Am J Epidemiol. 2019 Jun 1;188(6):1136–43. doi: 10.1093/aje/kwz040. PMID: 30976786. Exclusion Code: X 2.30976786
89 Piro E, Serra G, Schierz IA M, Neonatal ten-year retrospective study on neural tube defects in a second level University Hospital. Ital J Pediatr. 2020 May 24;46(1):72. doi: 10.1186/s13052-020-00836-1. PMID: 32448340. Exclusion Code: X 5.32448340
90 Prentice M, Hickey J, Vanderpump M, Iodine and folate-essential for mothers to be. Lancet Diabetes Endocrinol. 2020 Jan;8(1):9–10. doi: 10.1016/s2213-8587(19)30380-8. PMID: 31786045. Exclusion Code: X 1.31786045
91 Qian YY, Huang XL, Liang H, Effects of maternal folic acid supplementation on gene methylation and being small for gestational age. J Hum Nutr Diet. 2016 Oct;29(5):643–51. doi: 10.1111/jhn.12369. PMID: 27230729. Exclusion Code: X 6.27230729
92 Reijnders IF, Mulders A, van der Windt M, The impact of periconceptional maternal lifestyle on clinical features and biomarkers of placental development and function: a systematic review. Hum Reprod Update. 2019 Jan 1;25(1):72–94. doi: 10.1093/humupd/dmy037. PMID: 30407510. Exclusion Code: X 6.30407510
93 Richardson JL, George N, Stephens S, An exploratory linkage and analysis of national congenital anomaly and medication dispensing data in the United Kingdom. Reproductive Toxicology. 2020;97:11–2. doi: 10.1016/j.reprotox.2020.04.047. Exclusion Code: X 5.
94 Rios P, Bailey HD, Orsi L, Risk of neuroblastoma, birth-related characteristics, congenital malformations and perinatal exposures: A pooled analysis of the ESCALE and ESTELLE French studies (SFCE). Int J Cancer. 2016 Nov 1;139(9):1936–48. doi: 10.1002/ijc.30239. PMID: 27342419. Exclusion Code: X 6.27342419
95 Roffman J, Sipahi E, Dowling K, Association of Adverse Prenatal Exposures and Maternal Folic Acid Use With Psychopathology at Age 9–10 in the ABCD Study. Biological Psychiatry. 2020;87(9):S365. doi: 10.1016/j.biopsych.2020.02.935. Exclusion Code: X 6.
96 Roffman JL. Neuroprotective Effects of Prenatal Folic Acid Supplementation: Why Timing Matters. JAMA Psychiatry. 2018 Jul 1;75(7):747–8. doi: 10.1001/jamapsychiatry.2018.0378. PMID: 29801055. Exclusion Code: X 1.29801055
97 Rosas-Salazar C, Hartert TV. Prenatal exposures and the development of childhood wheezing illnesses. Curr Opin Allergy Clin Immunol. 2017 Apr;17(2):110–5. doi: 10.1097/aci.0000000000000342. PMID: 28079560. Exclusion Code: X 1.28079560
98 Rosenthal YS, Chodick G, Grossman Z, The incidence of infantile hypertrophic pyloric stenosis and its association with folic acid supplementation during pregnancy: A nested case-control study. J Pediatr Surg. 2019 Apr;54(4):701–6. doi: 10.1016/j.jpedsurg.2018.05.005. PMID: 29884554. Exclusion Code: X 6.29884554
99 Saccone G, Berghella V. Folic acid supplementation in pregnancy to prevent preterm birth: a systematic review and metaanalysis of randomized controlled trials. Eur J Obstet Gynecol Reprod Biol. 2016 Apr;199:76–81. doi: 10.1016/j.ejogrb.2016.01.042. PMID: 26901401. Exclusion Code: X 6.26901401
100 Samson KL I, Loh SP, Lee SS, Weekly iron-folic acid supplements containing 2.8 mg folic acid are associated with a lower risk of neural tube defects than the current practice of 0.4 mg: a randomised controlled trial in Malaysia. BMJ Glob Health. 2020 Dec;5(12)doi: 10.1136/bmjgh-2020-003897. PMID: 33272946. Exclusion Code: X 6.33272946
101 Saravanan P, Sukumar N, Adaikalakoteswari A, Association of maternal vitamin B(12) and folate levels in early pregnancy with gestational diabetes: a prospective UK cohort study (PRiDE study). Diabetologia. 2021 Oct;64(10):2170–82. doi: 10.1007/s00125-021-05510-7. PMID: 34296321. Exclusion Code: X6.34296321
102 Schmidt RJ, Iosif AM, Guerrero Angel E, Association of Maternal Prenatal Vitamin Use With Risk for Autism Spectrum Disorder Recurrence in Young Siblings. JAMA Psychiatry. 2019 Apr 1;76(4):391–8. doi: 10.1001/jamapsychiatry.2018.3901. PMID: 30810722. Exclusion Code: X 5.30810722
103 Schmidt RJ, Kogan V, Shelton JF, Combined Prenatal Pesticide Exposure and Folic Acid Intake in Relation to Autism Spectrum Disorder. Environ Health Perspect. 2017 Sep 8;125(9):097007. doi: 10.1289/ehp604. PMID: 28934093. Exclusion Code: X 3.28934093
104 Shaw GM, Yang W, Finnell RH. Male-to-female ratios among NTDs and women's periconceptional intake of folic acid. Birth Defects Res. 2020 Oct;112(16):1187–93. doi: 10.1002/bdr2.1708. PMID: 32415919. Exclusion Code: X 1.32415919
105 Shen M, Smith GN, Rodger M, Comparison of risk factors and outcomes of gestational hypertension and pre-eclampsia. PLoS One. 2017;12(4):e0175914. doi: 10.1371/journal.pone.0175914. PMID: 28437461. Exclusion Code: X 6.28437461
106 Silva C, Keating E, Pinto E. The impact of folic acid supplementation on gestational and long term health: Critical temporal windows, benefits and risks. Porto Biomed J. 2017 Nov-Dec;2(6):315–32. doi: 10.1016/j.pbj.2017.05.006. PMID: 32258789. Exclusion Code: X 8.32258789
107 Simkiss D. Preventing Neural Tube Defects. J Trop Pediatr. 2017 Apr 1;63(2):85–6. doi: 10.1093/tropej/fmw079. PMID: 28013255. Exclusion Code: X 1.28013255
108 Singh MD, Thomas P, Owens J, Potential role of folate in pre-eclampsia. Nutr Rev. 2015 Oct;73(10):694–722. doi: 10.1093/nutrit/nuv028. PMID: 26359215. Exclusion Code: X 6.26359215
109 Sordillo J, Rifas-Shiman SL, Switkowski K, Oxidative Balance in Fetal Life and Allergic Disease Risk in Adolescence: Investigating the role of Prenatal Nutrient Intakes and Potential Sources of Oxidative Stress in Utero. Journal of Allergy and Clinical Immunology. 2019;143(2):AB107. doi: 10.1016/j.jaci.2018.12.324. Exclusion Code: X 3.
110 Timms JA, Relton CL, Sharp GC, Exploring a potential mechanistic role of DNA methylation in the relationship between in utero and post-natal environmental exposures and risk of childhood acute lymphoblastic leukaemia. Int J Cancer. 2019 Dec 1;145(11):2933–43. doi: 10.1002/ijc.32203. PMID: 30740682. Exclusion Code: X 6.30740682
111 Trivedi M, Sharma S, Rifas-Shiman S, Maternal intake of dietary methyl donors in pregnancy and childhood asthma at 7 years. American Journal of Respiratory and Critical Care Medicine. 2014;189. Exclusion Code: X 3.
112 Trivedi MK, Sharma S, Rifas-Shiman SL, Folic Acid in Pregnancy and Childhood Asthma: A US Cohort. Clin Pediatr (Phila). 2018 Apr;57(4):421–7. doi: 10.1177/0009922817729482. PMID: 28884603. Exclusion Code: X 3.28884603
113 Valera-Gran D, Navarrete-Muñoz EM, Garcia de la Hera M, Effect of maternal high dosages of folic acid supplements on neurocognitive development in children at 4–5 y of age: the prospective birth cohort Infancia y Medio Ambiente (INMA) study. Am J Clin Nutr. 2017 Sep;106(3):878–87. doi: 10.3945/ajcn.117.152769. PMID: 28724645. Exclusion Code: X 6.28724645
114 Veena SR, Gale CR, Krishnaveni GV, Association between maternal nutritional status in pregnancy and offspring cognitive function during childhood and adolescence; a systematic review. BMC Pregnancy Childbirth. 2016 Aug 12;16:220. doi: 10.1186/s12884-016-1011-z. PMID: 27520466. Exclusion Code: X 6.27520466
115 Vereczkey A, Czeizel AE. Birth outcomes and risk or protective factors of ventricular Septal defects during pregnancy. Birth Defects Research Part A - Clinical and Molecular Teratology. 2015;103(5):420. doi: 10.1002/bdra.23387. Exclusion Code: X 6.
116 Walker M. Fact: a randomized trial of high dose folic acid for the prevention of preeclampsia in pregnancy. International journal of gynaecology and obstetrics. 2018;143:177‐. doi: 10.1002/ijgo.12582. PMID: CN-01654040. Exclusion Code: X 6.
117 Walker M, Wen SW, White RR, EFFECT OF HIGH DOSE FOLIC ACID SUPPLEMENTATION THROUGHOUT PREGNANCY ON PREECLAMPSIA (FACT): A DOUBLE-BIND, RANDOMIZED CONTROLLED MULTICENTRE TRIAL. Journal of Obstetrics and Gynaecology Canada. 2019;41(5):736. doi: 10.1016/j.jogc.2019.02.244. Exclusion Code: X 6.
118 Wang M, Li K, Zhao D, The association between maternal use of folic acid supplements during pregnancy and risk of autism spectrum disorders in children: a meta-analysis. Mol Autism. 2017;8:51. doi: 10.1186/s13229-017-0170-8. PMID: 29026508. Exclusion Code: X 8.29026508
119 Wang T, Zhang HP, Zhang X, Is Folate Status a Risk Factor for Asthma or Other Allergic Diseases? Allergy Asthma Immunol Res. 2015 Nov;7(6):538–46. doi: 10.4168/aair.2015.7.6.538. PMID: 26333700. Exclusion Code: X 8.26333700
120 Weber KA, Yang W, Carmichael SL, Nutrient intake in women before conception and risks of anophthalmia and microphthalmia in their offspring. Birth Defects Res. 2018 Jun 1;110(10):863–70. doi: 10.1002/bdr2.1201. PMID: 29504274. Exclusion Code: X 6.29504274
121 Wen SW, White RR, Rybak N, Effect of high dose folic acid supplementation in pregnancy on pre-eclampsia (FACT): double blind, phase III, randomised controlled, international, multicentre trial. Bmj. 2018 Sep 12;362:k3478. doi: 10.1136/bmj.k3478. PMID: 30209050. Exclusion Code: X 6.30209050
122 Wojtowicz A, Babczyk D, Galas A, Evaluation of the prevalence of folic acid supplementation before conception and through the first 12 weeks of pregnancy in Polish women at high risk of fetal anomalies. Ginekol Pol. 2022 Jan 24doi: 10.5603/GP.a2021.0192. PMID: 35072243. Exclusion Code: X2.35072243
123 Wood AG, Nadebaum C, Anderson V, Prospective assessment of autism traits in children exposed to antiepileptic drugs during pregnancy. Epilepsia. 2015 Jul;56(7):1047–55. doi: 10.1111/epi.13007. PMID: 25963613. Exclusion Code: X 2.25963613
124 Xie RH, Liu YJ, Retnakaran R, Maternal folate status and obesity/insulin resistance in the offspring: a systematic review. Int J Obes (Lond). 2016 Jan;40(1):1–9. doi: 10.1038/ijo.2015.189. PMID: 26392017. Exclusion Code: X 6.26392017
125 Ye Y, Dou L, Zhang Y, Maternal periconceptional folate status and atopic dermatitis: A prospective cohort study. Journal of the Dermatology Nurses' Association. 2020;12(2). Exclusion Code: X 7.
126 Ye Y, Dou LM, Zhang Y, Maternal periconceptional folate status and infant atopic dermatitis: A prospective cohort study. Pediatr Allergy Immunol. 2021 Jan;32(1):137–45. doi: 10.1111/pai.13321. PMID: 32663346. Exclusion Code: X 7.32663346
127 Yusuf KK, Salihu HM, Wilson R, Comparing Folic Acid Dosage Strengths to Prevent Reduction in Fetal Size Among Pregnant Women Who Smoked Cigarettes: A Randomized Clinical Trial. JAMA Pediatr. 2019 May 1;173(5):493–4. doi: 10.1001/jamapediatrics.2019.0112. PMID: 30882856. Exclusion Code: X 6.30882856
128 Zheng L, Huang J, Kong H, The effect of folic acid throughout pregnancy among pregnant women at high risk of preeclampsia: A randomized clinical trial. Pregnancy Hypertens. 2020 Jan; 19:253–8. doi: 10.1016/j.preghy.2020.01.005. PMID: 31987769. Exclusion Code: X 6.31987769
129 Zwink N, Jenetzky E. Maternal drug use and the risk of anorectal malformations: systematic review and meta-analysis. Orphanet J Rare Dis. 2018 May 10; 13( 1):75. doi: 10.1186/sl3023-018-07893. PMID: 29747656. Exclusion Code: X 6.29747656
130 Zwink N, Rissmann A, Potzsch S, Parental risk factors of anorectal malformations: Analysis with a regional population-based control group. Birth Defects Res A Clin Mol Teratol. 2016 Feb;106(2): 133–41. doi: 10.1002/bdra.23469. PMID: 26690556. Exclusion Code: X 6.26690556