# Appendix C Inclusion/Exclusion Criteria

Criteria | Include | Exclude
Populations | KQ 1: Persons capable of getting pregnant; KQ 2: Persons capable of getting pregnant; fetus, neonate, or child from index pregnancy | KQ 1: Persons not capable of getting pregnant (i.e., biological male sex, prepubertal persons, postmenopausal persons, sterilized persons, or persons with medical conditions rendering them sterile, persons on antiseizure medications); persons with history of NTDs
Interventions | Folic acid supplementation^*^, with or without food fortification or naturally occurring folate, for the prevention of NTDs and other birth defects; Supplementation with micronutrients (e.g., multivitamins, iron) in combination with folic acid | Food fortification only; Naturally occurring folate only; Counseling to improve dietary supplementation
Comparisons | KQs 1a, 1b, 1c (timing, duration), 2a: Placebo or no treatment or diet only (when compared with folic acid supplementation); supplementation with prenatal vitamins without folic acid (when compared with prenatal vitamin supplementation with folic acid); iron supplements without folic acid (when compared with iron supplementation with folic acid); Food fortification alone when compared folic acid supplementation with food fortification^‡^; KQs 1c, 2b (dose): Different doses of folic acid or micronutrient plus folic acid supplementation | Folic acid vs. other active comparators (e.g., multivitamins); KQs 1a, 1b, 1c (timing, duration), 2a: Lower vs. higher doses of folic acid supplementation
Outcomes | Neonatal outcomes: NTDs; Harms from treatment:; Colorectal cancer or other reported types of cancer; Inability to diagnose vitamin B6 or B12 adequately (masking of vitamin B6 or B12 deficiency); Autism; Asthma or allergies; Other reported child, neonatal, fetal, or maternal harms | Benefits not specified in inclusion criteria
Timing | KQs 1a: Supplementation initiated before index pregnancy and in the first month of pregnancy; KQs 1 b, c, 2a, 2b: All timing | KQs 1a: Supplementation initiated after the first month of pregnancy
Study designs | Efficacy (KQ 1): Randomized, controlled trials; controlled clinical trials; cohort or case-control studies; Harms (KQ 2): RCTs, controlled clinical trials, or observational studies (case-control, cohort, registry data) | Systematic reviews, case reports, case series
Publication type | Original research | Commentaries, editorials
Setting | Countries ranked as very high on the Human Development Index as defined by the United Nations Development Programme in 2020^†^ | All other countries
Sample size | All | None
Quality | Good and fair quality | Poor quality
Language | English | Non-English studies

* Terms for folic acid are broad and include folate, folic acid, folvite, folacin, vitamin B, and methyltetrahydrofolate among others.

† Countries designated as very high on the Human Development Index include Andorra, Argentina, Australia, Austria, Bahamas, Bahrain, Barbados, Belarus, Belgium, Brunei, Bulgaria, Canada, Chile, Costa Rica, Croatia, Cyprus, Czech Rep., Denmark, Estonia, Finland, France, Georgia, Germany, Greece, Hong Kong, Hungary, Iceland, Ireland, Israel, Italy, Japan, Kazakhstan, Kuwait, Latvia, Liechtenstein, Lithuania, Luxembourg, Malaysia, Malta, Mauritius, Montenegro, Netherlands, New Zealand, Norway, Oman, Palau, Panama, Poland, Portugal, Qatar, Romania, Russian Federation, Saudi Arabia, Serbia, Singapore, Slovakia, Slovenia, South Korea, Spain, Sweden, Switzerland, Taiwan, Turkey, UAE, UK, Uruguay, USA.

‡ Listed incorrectly in the protocol as “Folic acid supplementation alone when compared folic acid supplementation with food fortification”; the intent of this comparison was to include studies that allowed attribution of effects to folic acid supplementation alone.

Abbreviations: KQ=key question; NTD=neural tube defect; RCT=randomized, controlled trial; vs.=versus.