# Appendix B Search Strategy

## 7/01/2021 PubMed Benefits Search

Search | Query | Items Found
1 | “5-Me-THF*” OR “5-Me-H4F” OR “5-methyltetrahydrofolate” OR “5-methyltetrahydropteroylpentaglutamate”[Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate”[Supplementary Concept] OR “folacin”[tw] OR “folate”[tw] OR “folic acid”[MeSH] OR “folic acid”[tw] OR “folvite”[tw] OR MTHFR[tw] OR “Methylenetetrahydrofolate reductase”[tw] OR “vitamin b 9”[tw] OR “vitamin b9”[tw] OR “vitamin m”[tw] OR “Pteroylglutamic Acid”[tw] | 68,749
2 | multivitamin OR multivitamins OR “prenatal vitamin”[all fields] OR “prenatal vitamins”[all fields] OR “vitamin supplement”[all fields] OR “vitamin supplements”[all fields] | 5,916
3 | #1 OR #2 | 73,336
4 | Acrania[tw] OR Acranias[tw] OR Craniorachischisis[tw] OR Craniorachischises[tw] OR Diastematomyelia[tw] OR Diastematomyelias[tw] OR Exencephaly[tw] OR Exencephalies[tw] OR Iniencephalies[tw] OR “neural tube defects”[MeSH] OR “neural tube damage”[All Fields] OR “neural tube defect”[All Fields] OR “neural tube defects”[All Fields] OR “neural tube disorders”[All Fields] OR “Neural tube defect, folate-sensitive”[Supplementary Concept] OR “Neurenteric Cyst”[tw] OR “Neurenteric Cysts”[tw] OR “Neuroenteric Cyst”[tw] OR “Neuroenteric Cysts”[tw] OR “Occult Spinal Dysraphism”[tw] OR “Occult Spinal Dysraphisms”[tw] OR “spina bifida”[All Fields] OR “Spinal Cord Myelodysplasia”[tw] OR “Spinal Cord Myelodysplasias”[tw] OR “Tethered Cord Syndrome”[tw] OR “Tethered Cord Syndromes”[tw] OR “Tethered Spinal Cord Syndrome”[tw] | 34,623
5 | #3 AND #4 | 3,695
6 | #5 AND (“2015/07/01”[Date - Publication] : “3000”[Date - Publication]) | 772
7 | “Female”[MeSH] OR “Preconception Care”[MeSH] OR Pregnancy[MeSH] OR “Pregnant Women”[MeSH] OR “Prenatal Care”[MeSH] OR “Women”[MeSH:noexp] OR childbearing[tw] OR child-bearing[tw] OR gestation*[tiab] OR conception*[tw] OR maternal[tw] OR nonpregnant[tw] OR non-pregnant[tw] OR periconception*[tw] OR preconception*[tw] OR prenatal*[tw] OR pregnancy[tw] OR pregnancies[tw] OR pregnant[tw] OR ((women[tiab] OR woman[tiab]) AND reproduct*[tiab]) | 9,290,701
8 | #6 AND #7 | 651
9 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case report”[tw] OR “case reports”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | 10,674,879
10 | #8 NOT #9 | 531
11 | #8 NOT #9 | 508
12 | “Systematic Review”[pt] OR (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “Systematic Reviews as Topic”[Mesh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Umbrella Review”[tiab] | 381,030
13 | #11 AND #12 | 42
14 | #11 NOT #13 | 466

## 7/02/2021 PubMed Harms Search

Search | Query | Items Found
1 | “5-Me-THF*” OR “5-Me-H4F” OR “5-methyltetrahydrofolate” OR “5-methyltetrahydropteroylpentaglutamate”[Supplementary Concept] OR “5-methyltetrahydrofolate triglutamate”[Supplementary Concept] OR “folacin”[tw] OR “folate”[tw] OR “folic acid”[MeSH] OR “folic acid”[tw] OR “folvite”[tw] OR MTHFR[tw] OR “Methylenetetrahydrofolate reductase”[tw] OR “vitamin b 9”[tw] OR “vitamin b9”[tw] OR “vitamin m”[tw] OR “Pteroylglutamic Acid”[tw] | 68,769
2 | multivitamin OR multivitamins OR “prenatal vitamin”[all fields] OR “prenatal vitamins”[all fields] OR “vitamin supplement”[all fields] OR “vitamin supplements”[all fields] | 5,917
3 | #1 OR #2 | 73,357
4 | “adverse effect”[tiab] OR “adverse effects”[Subheading] OR “adverse effects”[tiab] OR “adverse event”[tiab] OR “adverse events”[tiab] OR “Asthma”[Mesh] OR asthma* OR atopy OR allerg* OR “Bronchial Hyperreactivity”[Mesh] OR “Colorectal Neoplasms”[Mesh] OR complication[tiab] OR complications[tiab] OR “Drug-Related Side Effects and Adverse Reactions”[Majr] OR harm[tiab] OR harms[tiab] OR Hypersensitivity[MeSH] OR “Patient Harm”[Majr] OR “Pregnancy Complications”[Mesh] OR “Pregnancy, Twin”[Mesh] OR “reactive airway*” OR respiratory OR “Respiratory Sounds”[Majr:NoExp] OR twinning OR “Twins”[Mesh] OR twins OR “Vitamin B 6 Deficiency”[Mesh] OR (“vitamin b 6”[MeSH] AND deficien*) OR “Vitamin B 12 Deficiency”[Mesh] OR (“vitamin b 12”[MeSH] AND deficien*) OR wheez* | 4,834,660
5 | #3 AND #4 | 24,469
6 | #5 AND (“2015/07/01”[Date - Publication] : “3000”[Date - Publication]) | 4,963
7 | #5 AND (“2015/07/01”[Date - Publication] : “3000”[Date - Publication]) | 4,710
8 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt]OR “case report”[tw] OR “case reports”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | 10,651,998
9 | #7 NOT #8 | 3,677
10 | “Preconception Care”[MeSH] OR Pregnancy[MeSH] OR “Pregnant Women”[MeSH] OR “Prenatal Care”[MeSH] OR “Women”[MeSH:noexp] OR childbearing[tw] OR child-bearing[tw] OR gestation*[tiab] OR conception*[tw] OR maternal[tw] OR nonpregnant[tw] OR non-pregnant[tw] OR periconception*[tw] OR preconception*[tw] OR prenatal*[tw] OR pregnancy[tw] OR pregnancies[tw] OR pregnant[tw] OR ((women[tiab] OR woman[tiab]) AND reproduct*[tiab]) | 1,297,068
11 | #9 AND #10 | 1,130
12 | “Systematic Review”[pt] OR (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “Systematic Reviews as Topic”[Mesh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Umbrella Review”[tiab] | 381,072
13 | #11 AND #12 | 125
14 | #11 NOT #13 | 1005

## 7/02/2021 Cochrane Library Benefits Search

Search | Query | Items Found
1 | “5-Me-THF*” OR “5-Me-H4F” OR “5-methyltetrahydrofolate” OR “5-methyltetrahydropteroylpentaglutamate” OR “5-methyltetrahydrofolate triglutamate” OR folacin OR folate OR [mh “folic acid”] OR “folic acid” OR folvite OR MTHFR OR “Methylenetetrahydrofolate reductase” OR “vitamin b 9” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” | 8219
2 | multivitamin OR multivitamins OR “prenatal vitamin” OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” | 1994
3 | #1 OR #2 | 9735
4 | Acrania OR Acranias OR Craniorachischisis OR Craniorachischises OR Diastematomyelia OR Diastematomyelias OR Exencephaly OR Exencephalies OR Iniencephaly OR Iniencephalies OR “neural tube damage” OR [mh “neural tube defects”] OR “neural tube defect” OR “neural tube defects” OR “neural tube disorders” OR “Neural tube defect, folate-sensitive” OR “Neurenteric Cyst” OR “Neurenteric Cysts” OR “Neuroenteric Cyst” OR “Neuroenteric Cysts” OR “Occult Spinal Dysraphism” OR “Occult Spinal Dysraphisms” OR “spina bifida” OR “Spinal Cord Myelodysplasia” OR “Spinal Cord Myelodysplasias” OR “Tethered Cord Syndrome” OR “Tethered Cord Syndromes” OR “Tethered Spinal Cord Syndrome” | 625
5 | #3 AND #4 | 261
6 | #5 with Cochrane Library publication date Between Jul 2015 and Dec 2021 | 131
7 | [mh Female] OR [mh “Preconception Care”] OR [mh Pregnancy] OR [mh “Pregnant Women”] OR [mh “Prenatal Care”] OR [mh ^Women] OR childbearing:ti,ab,kw OR child-bearing:ti,ab,kw OR gestation*:ti,ab,kw OR conception*:ti,ab,kw OR maternal:ti,ab,kw OR nonpregnant:ti,ab,kw OR non-pregnant:ti,ab,kw OR periconception*:ti,ab,kw OR preconception*:ti,ab,kw OR prenatal*:ti,ab,kw OR pregnancy:ti,ab,kw OR pregnancies:ti,ab,kw OR pregnant:ti,ab,kw OR ((women:ti,ab OR woman:ti,ab) AND reproduct*:ti,ab) | 524,998
8 | #6 AND #7 | 108
9 | Address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case report” OR “case reports” OR “comment”:pt OR “comment on” OR congress:pt OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | 55,043
10 | #8 NOT #9 | 82

## 7/01/2021 Cochrane Library Harms Search

Search | Query | Items Found
1 | “5-Me-THF*” OR “5-Me-H4F” OR “5-methyltetrahydrofolate” OR “5-methyltetrahydropteroylpentaglutamate” OR “5-methyltetrahydrofolate triglutamate” OR folacin OR folate OR [mh “folic acid”] OR “folic acid” OR folvite OR MTHFR OR “Methylenetetrahydrofolate reductase” OR “vitamin b 9” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” | 8219
2 | multivitamin OR multivitamins OR “prenatal vitamin” OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” | 1994
3 | #1 OR #2 | 9735
4 | “adverse effect”:ti,ab OR “adverse effects”:ti,ab OR “adverse event”:ti,ab OR “adverse events”:ti,ab OR [mh “Asthma”] OR asthma* OR atopy OR allerg* OR [mh “Bronchial Hyperreactivity”] OR [mh “Colorectal Neoplasms”] OR complication:ti,ab OR complications:ti,ab OR [mh “Drug-Related Side Effects and Adverse Reactions”[mj]] OR harm:ti,ab OR harms:ti,ab OR [mh Hypersensitivity] OR [mh “Patient Harm”[mj]] OR [mh “Pregnancy Complications”] OR [mh “Pregnancy, Twin”] OR “reactive airway*” OR respiratory OR [mh ^”Respiratory Sounds”[mj]] OR tWinning OR [mh “Twins”] OR twins OR [mh “Vitamin B 6 Deficiency”] OR ([mh “vitamin b 6”] AND deficien*) OR [mh “Vitamin B 12 Deficiency”] OR ([mh “Vitamin B l2”] AND deficien*) oR wheez* | 370952
5 | #3 AND #4 | 3526
6 | #5 with Cochrane Library publication date Between Jul 2015 and Dec 2021 | 1831
7 | Address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case report” OR “case reports” OR “comment”:pt OR “comment on” OR congress:pt OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh “Animals”] NOT [mh “Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae | 55,043
8 | #6 NOT #7 | 1431
9 | [mh “Preconception Care”] OR [mh Pregnancy] OR [mh “Pregnant Women”] OR [mh “Prenatal Care”] OR [mh ^Women] OR childbearing:ti,ab,kw OR child-bearing:ti,ab,kw OR gestation*:ti,ab,kw OR conception*:ti,ab,kw OR maternal:ti,ab,kw OR nonpregnant:ti,ab,kw OR non-pregnant:ti,ab,kw OR periconception*:ti,ab,kw OR preconception*:ti,ab,kw OR prenatal*:ti,ab,kw OR pregnancy:ti,ab,kw OR pregnancies:ti,ab,kw OR pregnant:ti,ab,kw OR ((women:ti,ab OR woman:ti,ab) AND reproduct*:ti,ab) | 91,731
10 | #8 AND #9 | 364

## 7/02/2021 EMBASE Benefits Search

Search | Query | Items Found
1 | ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ OR ‘folacin’/exp OR folacin OR ‘folate’/exp OR ‘folate’ OR ‘folic acid’/exp OR ‘folic acid’ OR ‘folvite’/exp OR folvite OR mthfr OR ‘methylenetetrahydrofolate reductase’ OR ‘vitamin b 9’ OR ‘vitamin b9’ OR ‘vitamin m’/exp OR ‘vitamin m’ OR ‘pteroylglutamic acid’/exp OR ‘pteroylglutamic acid’ | 98,009
2 | ‘multivitamin’/exp OR multivitamin OR multivitamins OR ‘prenatal vitamin’ OR ‘prenatal vitamins’ OR ‘vitamin supplement’ OR ‘vitamin supplements’ | 14,517
3 | #1 OR #2 | 109,353
4 | acrania OR acranias OR craniorachischisis OR craniorachischises OR ‘diastematomyelia’/exp OR diastematomyelia OR diastematomyelias OR ‘exencephaly’/exp OR exencephaly OR exencephalies OR ‘iniencephaly’/exp OR iniencephaly OR iniencephalies OR ‘neural tube damage’ OR ‘neural tube defect’/exp OR ‘neural tube defect’ OR ‘neural tube defects’/exp OR ‘neural tube defects’ OR ‘neural tube defect, folate-sensitive’ OR ‘neural tube disorder’ OR ‘neural tube disorders’ OR ‘neurenteric cyst’ OR ‘neurenteric cysts’ OR ‘neuroenteric cyst’ OR ‘neuroenteric cysts’ OR ‘occult spinal dysraphism’/exp OR ‘occult spinal dysraphism’ OR ‘occult spinal dysraphisms’ OR ‘spina bifida’ OR ‘spinal cord myelodysplasia’ OR ‘spinal cord myelodysplasias’ OR ‘spinal dysraphism’/exp OR ‘spinal dysraphism’ OR ‘tethered cord syndrome’/exp OR ‘tethered cord syndrome’ OR ‘tethered cord syndromes’ OR ‘tethered spinal cord syndrome’ | 42,652
5 | #3 AND #4 | 5,788
6 | #5 AND [1-7-2015]/sd NOT [02-7-2021]/sd | 1,346
7 | ‘female’/exp OR ‘prepregnancy care’/exp OR ‘pregnancy’/exp OR ‘pregnant woman’/exp OR ‘prenatal care’/exp OR childbearing:ti,ab,kw OR child-bearing:ti,ab,kw OR gestation*:ti,ab,kw OR conception*:ti,ab,kw OR maternal:ti,ab,kw OR nonpregnant:ti,ab,kw OR non-pregnant:ti,ab,kw OR periconception*:ti,ab,kw OR preconception*:ti,ab,kw OR prenatal*:ti,ab,kw OR pregnancy:ti,ab,kw OR pregnancies:ti,ab,kw OR pregnant:ti,ab,kw OR ((women:ti,ab OR woman:ti,ab) AND reproduct*:ti,ab) | 10,828,926
8 | #6 AND #7 | 1,129
9 | #8 NOT ([conference review]/lim OR [editorial]/lim OR [letter]/lim OR [note]/lim) | 1.056
10 | #9 NOT (([animal cell]/lim OR [animal experiment]/lim OR [animal model]/lim OR [animal tissue]/lim OR ‘nonhuman’/exp OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae) NOT ‘human’/exp) | 979
11 | #9 NOT (([animal cell]/lim OR [animal experiment]/lim OR [animal model]/lim OR [animal tissue]/lim OR ‘nonhuman’/exp OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae) NOT ‘human’/exp) AND [english]/lim | 943
12 | #9 NOT (([animal cell]/lim OR [animal experiment]/lim OR [animal model]/lim OR [animal tissue]/lim OR ‘nonhuman’/exp OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae) NOT ‘human’/exp) AND [english]/lim AND ([medline]/lim OR [pubmed-not-medline]/lim) | 621
13 | #11 NOT #12 | 322
14 | ‘systematic review’/exp OR ‘systematic review (topic)’/exp OR ‘meta analysis’/exp OR ‘meta analysis (topic)’/exp OR ‘systematic literature review’:ti,ab OR ‘this systematic review’:ti,ab OR ‘umbrella review’:ti,ab OR ‘meta-analysis’:ti,ab OR ‘meta-analyses’:ti,ab OR ‘meta-synthesis’:ti,ab OR ‘meta-syntheses’:ti,ab | 516,396
15 | #13 AND #14 | 12
16 | #13 NOT #15 | 310

## 7/02/2021 EMBASE Harms Search

Search | Query | Items Found
1 | ‘5 me thf’ OR ‘5 me h4f’ OR ‘5 methyltetrahydrofolate’ OR ‘5 methyltetrahydropteroylpentaglutamate’ OR ‘5-methyltetrahydrofolate triglutamate’ OR ‘folacin’/exp OR folacin OR ‘folate’/exp OR ‘folate’ OR ‘folic acid’/exp OR ‘folic acid’ OR ‘folvite’/exp OR folvite OR mthfr OR ‘methylenetetrahydrofolate reductase’ OR ‘vitamin b 9’ OR ‘vitamin b9’ OR ‘vitamin m’/exp OR ‘vitamin m’ OR ‘pteroylglutamic acid’/exp OR ‘pteroylglutamic acid’ | 97,677
2 | ‘multivitamin’/exp OR multivitamin OR multivitamins OR ‘prenatal vitamin’ OR ‘prenatal vitamins’ OR ‘vitamin supplement’ OR ‘vitamin supplements’ | 14,516
3 | #1 OR #2 | 109,020
4 | ‘abnormal respiratory sound’/exp OR ‘adverse drug reaction’/exp OR ‘adverse drug reaction’ OR ‘adverse effect’ OR ‘adverse effects’ OR ‘adverse event’ OR ‘adverse events’ OR ‘asthma’/exp OR asthma OR ‘atopy’/exp OR atopy OR ‘allergic reaction’/exp OR ‘allergy’/exp OR allerg* OR (b12 AND deficien*) OR (‘b 12’ AND deficien*) OR (b6 AND deficien*) OR (‘b 6’ AND deficien*) OR ‘bronchus hyperreactivity’/exp OR ‘bronchial hyperreactivity’:ti,ab OR ‘colorectal tumor’/exp OR ‘colorectal tumor’:ti,ab OR ‘colorectal cancer’:ti,ab OR complication OR complications OR ‘cyanocobalamin deficiency’/exp OR harm OR harms OR ‘patient harm’/exp/mj OR ‘pregnancy complication’/exp OR ‘pregnancy complication’ OR ‘pregnancy complications’ OR ‘pyridoxine deficiency’/exp OR ‘reactive airway*’ OR respiratory:ti,ab OR ‘twin pregnancy’/exp OR ‘twins’/exp OR twin OR twins OR twinning OR ‘wheezing’/exp OR wheez*:ti,ab | 6,375,031
5 | #3 AND #4 | 34,224
6 | #5 AND [1-7-2015]/sd NOT [2-7-2021]/sd | 9,764
7 | #5 AND [1-7-2015]/sd NOT [2-7-2021]/sd AND [english]/lim | 9,537
8 | #7 NOT ([conference review]/lim OR [editorial]/lim OR [letter]/lim OR [note]/lim) | 9,088
9 | #8 NOT (([animal cell]/lim OR [animal experiment]/lim OR [animal model]/lim OR [animal tissue]/lim OR ‘nonhuman’/exp OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae) NOT ‘human’/exp) | 8,737
10 | #8 NOT (([animal cell]/lim OR [animal experiment]/lim OR [animal model]/lim OR [animal tissue]/lim OR ‘nonhuman’/exp OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae) NOT ‘human’/exp) AND ([medline]/lim OR [pubmed-not-medline]/lim) | 4,730
11 | #9 NOT #10 | 4,007
12 | ‘prepregnancy care’/exp OR ‘pregnancy’/exp OR ‘pregnant woman’/exp OR ‘prenatal care’/exp OR childbearing:ti,ab,kw OR child-bearing:ti,ab,kw OR gestation*:ti,ab,kw OR conception*:ti,ab,kw OR maternal:ti,ab,kw OR nonpregnant:ti,ab,kw OR non-pregnant:ti,ab,kw OR periconception*:ti,ab,kw OR preconception*:ti,ab,kw OR prenatal*:ti,ab,kw OR pregnancy:ti,ab,kw OR pregnancies:ti,ab,kw OR pregnant:ti,ab,kw OR ((women:ti,ab OR woman:ti,ab) AND reproduct*:ti,ab) | 1,439,087
13 | #11 AND #12 | 867
14 | ‘systematic review’/exp OR ‘systematic review (topic)’/exp OR ‘meta analysis’/exp OR ‘meta analysis (topic)’/exp OR ‘systematic literature review’:ti,ab OR ‘this systematic review’:ti,ab OR ‘umbrella review’:ti,ab OR ‘meta-analysis’:ti,ab OR ‘meta-analyses’:ti,ab OR ‘meta-synthesis’:ti,ab OR ‘meta-syntheses’:ti,ab | 516,061
15 | #13 AND #14 | 52
16 | #13 NOT #15 | 815

Grey Literature Searches, 6-30-2021 and 7-02-2021

WHO International Clinical Trials Registry Platform (ICTRP), 06/30/2021 Searched Beta Advanced Search portal (ICTRP Search Portal Advanced Search (ictrptest.azurewebsites.net) because existing site: https://apps.who.int/trialsearch/AdvSearch.aspx was not working.

Benefits search: 102 results, 102 imported

[underlined: In Condition box] –

No wildcards, let synonym search in the database handle synonyms:

spina bifida OR neural tube OR Craniorachischis OR Diastematomyelia OR Tethered Cord OR Occult Spinal Dysraphism OR Iniencephaly OR Neurenteric Cyst OR Neuroenteric Cyst OR Myelodysplasia OR Acrania OR Exencephaly

Recruitment status: ALL

Date registered between July 1, 2015 – June 30, 2021

Harms search: 11 results, 11 imported

[underlined: Intervention box] - folic acid OR folvite OR folacin OR folate

[underlined: Condition box]: drug-related side effects OR adverse reaction OR harm OR harms OR adverse effect OR adverse effects OR adverse event OR adverse events OR Complication OR Complications OR asthma OR atopy OR allerg* OR reactive airway OR respiratory OR wheez*

Recruitment status: ALL

Date registered between July 1, 2015 – June 30, 2021

ClinicalTrials.gov, 7-02-2021, all limited to Last Updated date of 07/01/2015 – 07/02/2021.

Benefits Advanced Search:

[underlined: In Condition box] – (“neural tube defects” OR “spina bifida” OR “neural tube damage” OR “neural tube defect” OR “neural tube disorders” OR Craniorachischisis OR Craniorachischises OR Diastematomyelia OR Diastematomyelias OR “Tethered Cord Syndrome” OR “Tethered Cord Syndromes” OR “Tethered Spinal Cord Syndrome” OR “Occult Spinal Dysraphism” OR “Occult Spinal Dysraphisms” OR Iniencephaly OR Iniencephalies OR “Neurenteric Cyst” OR “Neurenteric Cysts” OR “Neuroenteric Cyst” OR “Neuroenteric Cysts” OR “Spinal Cord Myelodysplasia” OR “Spinal Cord Myelodysplasias” OR Acrania OR Acranias OR Exencephaly OR Exencephalies)

[underlined: In Intervention box] – (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR multivitamin OR multivitamins OR “prenatal vitamin” OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR ‘5 me thf’ OR ‘5 me h4f’ OR 5-methyltetrahydrofolate OR mthfr OR ‘methylenetetrahydrofolate reductase’)

All put together in Expert search: 14 results, 14 imported

AREA[ConditionSearch] (“neural tube defects” OR “spina bifida” OR “neural tube damage” OR “neural tube defect” OR “neural tube disorders” OR Craniorachischisis OR Craniorachischises OR Diastematomyelia OR Diastematomyelias OR “Tethered Cord Syndrome” OR “Tethered Cord Syndromes” OR “Tethered Spinal Cord Syndrome” OR “Occult Spinal Dysraphism” OR “Occult Spinal Dysraphisms” OR Iniencephaly OR Iniencephalies OR “Neurenteric Cyst” OR “Neurenteric Cysts” OR “Neuroenteric Cyst” OR “Neuroenteric Cysts” OR “Spinal Cord Myelodysplasia” OR “Spinal Cord Myelodysplasias” OR Acrania OR Acranias OR Exencephaly OR Exencephalies) AND AREA[InterventionSearch] (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR multivitamin OR multivitamins OR “prenatal vitamin” OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR ‘5 me thf’ OR ‘5 me h4f’ OR 5-methyltetrahydrofolate OR mthfr OR ‘methylenetetrahydrofolate reductase’) AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[07/01/2015, 07/02/2021]

ClinicalTrials.gov Harms Advanced Search

Search 1:

[underlined: Intervention box] - (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR multivitamin OR multivitamins OR “prenatal vitamin” OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR ‘5 me thf’ OR ‘5 me h4f’ OR 5-methyltetrahydrofolate OR mthfr OR ‘methylenetetrahydrofolate reductase’)

[underlined: Other terms box] – (Pregnancy OR pregnancies OR prepregnancy OR pregnant OR prenatal* OR childbearing OR child-bearing OR gestation* OR conception OR maternal* OR nonpregnant OR non-pregnant OR periconception* OR preconception* OR ((woman OR women) AND reproduct*))

[underlined: Condition box]: (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications OR asthma OR atopy OR allerg* OR ‘reactive airway’ OR respiratory OR wheez*)

Expert search box: 234 results, 234 imported

(Pregnancy OR pregnancies OR prepregnancy OR pregnant OR prenatal* OR childbearing OR child-bearing OR gestation* OR conception OR maternal* OR nonpregnant OR non-pregnant OR periconception* OR preconception* OR ((woman OR women) AND reproduct*)) AND AREA[ConditionSearch] (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications OR asthma OR atopy OR allerg* OR ‘reactive airway’ OR respiratory OR wheez*)AND AREA[InterventionSearch] (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR multivitamin OR multivitamins OR “prenatal vitamin” OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR ‘5 me thf’ OR ‘5 me h4f’ OR 5-methyltetrahydrofolate OR mthfr OR ‘methylenetetrahydrofolate reductase’) AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[07/01/2015, 07/02/2021]

Search 2:

[underlined: Intervention box] - (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR multivitamin OR multivitamins OR “prenatal vitamin” OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR ‘5 me thf’ OR ‘5 me h4f’ OR 5-methyltetrahydrofolate OR mthfr OR ‘methylenetetrahydrofolate reductase’)

[underlined: Other terms box] – [underlined: Other terms box] – (Pregnancy OR pregnancies OR prepregnancy OR pregnant OR prenatal* OR childbearing OR child-bearing OR gestation* OR conception OR maternal* OR nonpregnant OR non-pregnant OR periconception* OR preconception* OR ((woman OR women) AND reproduct*)) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications OR asthma OR atopy OR allerg* OR ‘reactive airway’ OR respiratory OR wheez*)

Expert search box: 364 results, 129 imported

(Pregnancy OR pregnancies OR prepregnancy OR pregnant OR prenatal* OR childbearing OR child-bearing OR gestation* OR conception OR maternal* OR nonpregnant OR non-pregnant OR periconception* OR preconception* OR ((woman OR women) AND reproduct*)) AND (“drug-related side effects” OR “adverse reaction” OR harm OR harms OR “adverse effect” OR “adverse effects” OR “adverse event” OR “adverse events” OR Complication OR Complications OR asthma OR atopy OR allerg* OR ‘reactive airway’ OR respiratory OR wheez*) AND AREA[InterventionSearch] (“folic acid” OR “vitamin b9” OR “vitamin m” OR “Pteroylglutamic Acid” OR folvite OR folacin OR folate OR multivitamin OR multivitamins OR “prenatal vitamin” OR “prenatal vitamins” OR “vitamin supplement” OR “vitamin supplements” OR ‘5 me thf’ OR ‘5 me h4f’ OR 5-methyltetrahydrofolate OR mthfr OR ‘methylenetetrahydrofolate reductase’) AND AREA[LastUpdatePostDate] EXPAND[Term] RANGE[07/01/2015, 07/02/2021]