# Appendix A Definitions and Guidelines

Appendix A Table 1 Measures and Definitions

Measure | Definition
Recommended Daily Allowance (RDA)^124^ | The RDA is the average daily dietary nutrient intake level sufficient to meet the nutrient requirement of nearly all (97% to 98%) healthy individuals in a particular life stage and gender group.; The primary indicators to determine RDA are RBC folate, plasma homocysteine, and folate concentration levels.; If the standard deviation is available and the data are normally distributed, the RDA = estimated average requirement (EAR) + 2 SD of EAR. If data about variability in requirements are insufficient to calculate an SD, a coefficient of variation for the EAR of 10% is assumed. The resulting equation for the RDA is then RDA = 1.2 × EAR.; The RDA for folate is set by assuming a coefficient of variation of 10% because information is not available on the standard deviation of the requirement for folate; the RDA is defined as equal to the EAR plus twice the CV to cover the needs of 97% to 98% of the individuals in the group. For folate, the RDA is 120% of the EAR.; The U.S. Institute of Medicine (IOM) recommends an RDA for men, women, and adolescents of 14–18 is 400 μg/day.; The IOM recommended RDA for pregnant women is 600 μg/day. The recommendation for women capable of becoming pregnant exceeds the RDA. They are recommended to consume 400 μg/day of folate from supplements and/or fortified foods and to consume naturally occurring food folate from a varied diet.; The IOM relied on case reports (from 1947 to 1990, of 1 to 48 cases) of progression of neurological disorders of vitamin B12-deficient patients who were receiving oral doses of folate to identify the lowest observed adverse effect level. They observed that an exposure 5 mg/day was associated with more than 100 reported cases of neurological progression, whereas lower exposures (0.33 to 2.5 mg/day) were associated with 8 cases. The threshold of 5 mg/day was divided by an uncertainty factor of 5 to arrive at an upper level of 1 mg/day.^68^
Dietary Folic Equivalent (DFE) | 1 μg DFE = 1 μg food folate = 0.6 μg folic acid from fortified food or as a supplement consumed with food = 0.5 μg of a folic acid supplement taken on an empty stomach^68^
Estimated Average Requirement (EAR) | The EAR is the average daily nutrient intake level estimated to meet the requirement of half the healthy individuals in a particular life stage and gender group.; The U.S. IOM EAR for females 19–50: 320 μg/day of DFE^68^; The IOM EAR for pregnancy is 520 μg/day of DFE.; The 320 DFE is based on one study of five patients who were fed a diet of 319 DFE.^125^ Of these women, three had RBC folate <305 nmol/L, suggesting that with 320 DFE half would have RBC folate over 305 nmol/L.; The threshold of 305 nmol/L (140 ng/mL) of folate was chosen as the cutoff point for adequate folate status based on evidence that lower levels were associated with the appearance of hypersegmented neutrophils (1 case^126^; 2 cases^127^ and its association with megaloblastic anemia (40 patients with megaloblastic anemia also had RBC folate <305 nmol/L^128^; 238 pregnant women with RBC <327 nmol/L had megoblastic marrow^129^ or chromosomal damage (8 patients with RBC folate <305 nmol/L had a threefold higher frequency of cellular micronuclei (suggesting DNA and chromosomal damage) than 14 control patients.
Plasma/serum folate concentration | Concentration of folate in the circulation based on recent intake of folate from natural-food sources, foods fortified with folic acid, and folic acid supplementation.; It is estimated that steady state is achieved after 12–14 weeks of supplementation once cellular folate stores have been saturated.; Low folate levels (<6.8 nmol/L) at single time points may reflect only transient changes in intake versus true deficiency and must be combined with other markers of deficiency.^68,^ ^130,^ ^131^ No threshold value for plasma/serum folate concentration to prevent NTDs.
Red Blood Cell (RBC) Folate Concentrations | Reflects tissue stores of folate; therefore, considered to be the most reliable biomarker of folate.; Folate is incorporated during their maturation in the bone marrow and remains at the same level throughout their 120-day life span.; RBC folate levels can be assessed with microbiological assays or commercial protein-binding assays on automated clinical analyzers.; In women of reproductive age, RBC folate concentrations should be above 400 ng/mL (906 nmol/L).^58^ There is a dose response relationship with RBC folate levels and folate intake from diet and supplements, but there are not yet clear guidelines incorporating RBC folate levels into individualized folic acid supplementation recommendations.^29,^ ^58^

Abbreviations: CV= coefficient of variation; DFE=dietary folic equivalent; DNA=deoxyribonucleic acid; EAR=estimated average requirement; IOM=Institute of Medicine; NTD=neural tube defect; RBC=red blood cell; RDA=recommended daily allowance; SD=standard deviation; U.S.=United States; vs.=versus.

Appendix A Table 2 Current Guidelines for Folic Acid Supplementation

Organization (Year) | Definition of Treatment Population | Guideline
American College of Obstetrics and Gynecology (2019, reaffirmed in 2020)^65^ | General population: Women capable of becoming pregnant | All women of reproductive age (15–45 years) should take folic acid supplementation. For average-risk women, supplementation with 400 μg per day is adequate. Women at increased risk of NTDs, including women with a prior pregnancy with an NTD or women with seizure disorders, should be counseled to take 4 mg of folic acid daily
American Academy of Pediatrics (1999)^66^, reaffirmed January 2007 | General population: Women with no history of a previous pregnancy affected by an NTD | All women of childbearing age, capable of becoming pregnant, and having no history of a previous pregnancy affected by an NTD should consume 400 μg (0.4 mg) of folic acid daily.
Centers for Disease Control (1993)^64^ | General population: Women of childbearing age in the United States | Women of childbearing age in the United States who are capable of becoming pregnant should consume 0.4 mg of folic acid per day to reduce the risk of having a pregnancy affected with spina bifida or other NTDs. Because the effects of high intakes are not well known but include complicating the diagnosis of vitamin B12 deficiency, care should be taken to keep total folate consumption at less than 1 mg per day, except under the supervision of a physician.
American Academy of Family Physicians (2014)^67,^ ^71,*^ | Women planning pregnancy | Folic acid supplementation should be recommended early, preferably before conception. Folic acid, 400 mcg daily, started before pregnancy and continued until 6 to 12 weeks’ gestation reduces the rate of NTDs by nearly 75%.
Institute of Medicine (1998)^68^ | Women capable of becoming pregnant | 400 μg of folic acid daily from fortified foods, supplements, or both in addition to consuming food folate from a varied diet.
National Institute for Health and Care Excellence (United Kingdom, 2014)^69,^ ^70^ | General population: Women who may become pregnant and women in early pregnancy | A daily dose of 400 μg of folic acid before pregnancy and throughout the first 12 weeks is recommended.

* The American Academy of Family Physicians cites the 2017 USPSTF guidance.^132^

Abbreviation: NTD=neural tube defect.