# Acknowledgments

The author thanks Robert Utiger, Marc Stone, and David Atkins for their comments on an earlier draft of this article.