# Summary

The results of this review are summarized in Table 5. The ability of screening programs to detect subclinical thyroid dysfunction has been demonstrated in good-quality cohort studies, and some of the complications of subclinical thyroid dysfunction are well-documented. The main gap in the evidence is the lack of convincing data from controlled trials that early treatment improves outcomes for patients with subclinical hypothyroidism and subclinical hyperthyroidism detected by screening.

Table 5. Summary of Findings of Systematic Review