# Results

## Efficacy of Treatment for Subclinical Hyperthyroidism

No controlled trials of treatment for subclinical hyperthyroidism have been done. Small observational studies of patients with nodular thyroid disease not detected by screening have shown improvements in bone metabolism and hemodynamic measures after treatment. ^53,^ ^90–92^

## Efficacy of Treatment for Subclinical Hypothyroidism

We identified 14 randomized trials of levothyroxine therapy. We excluded 2 trials that compared levothyroxine to levothyroxine plus triiodothyronine in patients with overt hypothyroidism, ^93,^ ^94,^ 1 trial of different levothyroxine preparations, ^95^ and 1 of levothyroxine suppressive therapy for solitary nodules. ^96^ Two trials of levothyroxine treatment in patients with subclinical hypothyroidism reported no clinical outcomes or lipid results; one of these concerned bone density ^97^ and the other, cardiac function parameters from Doppler echocardiography and videodensitometric analysis. ^98^ These trials are not included in evidence tables but are discussed briefly.

Of the 8 included trials, ^15,^ ^74,^ ^75,^ ^99–103^ 6 concerned patients with elevated TSH levels. One concerned hyperlipidemic patients with high-normal TSH levels, ^99^ and the last trial concerned patients with a normal TSH who had symptoms of hypothyroidism. ^101^

Randomized trials of levothyroxine treatment in subclinical hypothyroidism and in symptomatic patients who have a normal TSH are described in Table 3 (quality ratings) and in Table 4 (description and results). The first 2 trials in Table 4 concerned patients followed in thyroid specialty clinics. In both trials, subjects had a mean serum TSH above 10 mU/L. The first trial (Cooper et al) concerned patients who had been treated for Graves' disease in whom TSH was rising relatively quickly. ^75^ Symptoms were rated on the “Cooper Questionnaire,” a 24-point scale that records how 6 symptoms of hypothyroidism change over time. After 1 year, patients taking levothyroxine improved by 2.1 points, while patients taking placebo deteriorated by 1.2 points (P = 0.037). The difference (3.3 points) is roughly equivalent to complete relief of one symptom and partial relief of a second symptom per patient. Eight (47%) of 17 treated patients reported reduced or milder symptoms; 4 felt worse; and 5 reported no change in symptoms. In the placebo group, 3 (19%) of 16 patients felt better, 6 felt worse, and 7 reported no change. The difference between the proportion of patients who felt better in each group was 0.28 (CI, -0.09–0.65), indicating that 1 patient improved for every 3.5 patients treated with levothyroxine. ^75^ Treatment had no effect on lipid levels. The internal validity of this trial was rated “good-quality;” it was the highest-quality trial of the group.

Table 4. Description and Results of Randomized Trials of Thyroxine Replacement Therapy

Study, Year | Patients | Setting | Age, Gender | Eligibility Criteria | Other Population Characteristics | Outcomes Assessed/When Assessed | How Outcomes Assessed (eg, Scaled Used) | LT4 vs Placebo Group Results | Before/After Results | Adverse Effects Assessed? | Adverse Effects | Quality Rating (Good/Fair/Poor) | Relevance to screening | Comments | Questions
Known history of thyroid disease
Cooper et al, 1984 ^(75)^ | Previously treated Graves' disease, stage c subclinical hypothyroidism | Thyroid specialty clinic, Boston | 32 women and 1 man, mean age 55 yrs | TSH > 3.5 mU/L on 2 occasions | History of Graves' disease | Symptoms, lipid profile at 1 yr | Symptom change scores (“Cooper questionnaire”) | Improved symptoms (-1.2 vs +2.1) in LT4 group, 47% improved in LT4 group vs 19% in placebo group (NNT = 3.6), no difference in lipid profiles | Placebo group's TSH and symptoms rose during the year, suggesting the patients had rapidly advancing subclinical hypothyroidism | Only through symptom scores | 4 patients in LT4 group felt worse, vs 6 in placebo group | Good | Low | Well-conducted trial, but subjects had known thyroid disease and the study is not relevant to screening | What proportion of all patients who had elevated TSH and normal FT4 were eligible for the study?
Meier et al, 2001 ^(100)^ | Autoimmune thyroiditis (n = 33), previously treated Graves' disease (n = 22), previously treated goiter (7) | Thyroid specialty clinic, Switzerland | 63 women, mean age 58.5 ± 1 .3 yrs | Women 18–75 yrs; TSH > 6.0 mU/L on 2 occasions; exaggerated TSH response to TRH; good general health | History of autoimmune thyroiditis (n = 33), Graves' disease (n = 22), goiter (n = 7), only 4 had idiopathic subclinical hypothyroidism | Symptoms, lipid profile at 1 yr | Thyroid symptom questionnaire | Post-treatment LDLc was the same in both groups (3.7± 0.2, p = 0.11), and symptoms scores were not significantly different (p = .53) | LDLc reduced from 4.0- 3.7 in the LT4 group (p = 0.004) and there were borderline improvements in symptom scores (p = 0.02), placebo group TSH was stable | No | Not assessed | Poor | Low | The discrepency between before/after results and LT4 vs placebo results suggests that randomization was probably flawed | Were patients informed of their LDLc levels?
Caraccio et al, 2002 ^(102)^ | Hashimoto's thyroiditis (48) or Graves' disease (1) | Medical school internal medicine clinic, Italy | 42 premenopausal women, 7 men | TSH > 3.6 mU/Lfor > 6 mos, + atP and anti-Tg, good general health | Subclinical hypothyroid patients had higher TC, LDL, and ApoB levels than healthy controls | Lipid profile at 6 mos for placebo group vs about 11 mos for LT4 group | Biochemical tests | There were no significant differences between LT4 and placebo groups in any lipid parameter | LT4 group: TC reduced from 5.5-5.0, LDLc from 3. 6-3.1 | No | Not assessed | Poor | Fair | Analyzed as an open, uncontrolled study | Was completion of the study a criterion for inclusion in the analysis? How many patients were screened, eligible, enrolled, and randomized? Were patients and providers aware of treatment? How was randomization done? Were baseline differences statistically significant? What proportion of subjects in each group had aTC > 6.2?
No known history or not stated
Jaeschke et al, 1996 ^(15)^ | Diagnosis of subclinical hypothyroidism | Unclear setting, Ontario | 28 women and 9 men over age 55, mean age 68 yrs | TSH > 6 mU/L on 2 occasions | None stated | Quality of life, symptoms, lipid profile at 6 mos | Chronic Thyroid Questionnaire, Cooper questionnaire, SIP, cognitive tests | No improvement in symptoms or lipids, improved memory in LT4 group (mean difference of .58 on z score scale, described as “small and of questionable clinical importance”) | Placebo group's TSH rose from 9.42–10.32 over 6 mos | Only through dropouts | 1 case of atrial fibrillation and 1 case of angina in LT4 group | Fair | Fair | Description of recruitment was inadequate | Were patients referred from family practitioners? Were patients who had a history of thyroid disease included?
Kong et al, 2002 ^(103)^ | Women with a diagnosis of subclinical hypothyroidism | Referrals from GPs for thyroid function tests, London | 45 women, mean age ~49 yrs | Women over 18 years; 5 < TSH < 10 mU/L | Most patients were referred because of symptoms | Quality of life, symptoms, lipid profile at 6 mos | Thyroid symptom questionnaire, GHQ-30, HADS | No improvement in symptoms or lipids | Placebo group's TSH dropped from 7.3-5.6 over 6 mos | Only through symptom scores | Anxiety scores were higher in the LT4 group | Poor | Fair | High dropout rate, but patients were relevant to primary care: symptomatiic with borderline TSH values
Nystrom et al, 1988 ^(74)^ | Women identified by screening | Population-based screening study, Gothenburg | 20 women, aged 51–73 | Women over 18 years; 4 < TSH < 15 mU/L, exaggerated TSH response to TRH | Symptoms did not differ between subjects and healthy controls | Quality of life, symptoms, psychometric tests, vital signs, ECG, lipid profile at 6 mos | Thyroid symptom questionnaire, reaction time, Bingley's memory test | No difference in lipids. | Symptom scores improved by the equivalent of 1 symptom per subject (P < 0.001), and 4 patients felt better with LT4 than with placebo | Only through dropouts | In LT4 group, 1 subject dropped out because of nervousness, 1 because of a sense of tachycardia | Poor | Good | The flaws in analyzing data make the study uninterpretable, but the patients are most like those encountered in screening
Biochemically euthyroid patients
Michalopoulou et al, 1998 ^(99)^ | Patients referred for lipid assessment | Preventive Medicine (Lipid) hospital-based clinic, Greece | Not stated | TC > 7.5 mmol/L and TSH 0.4–4.0 mU/L | | Lipid profile | Not assessed | LDL reduced from 6.2-6.1 in 25 mg group and from 6.8-5.9 in 50 mg group | LDLc reduction was significant in 50 mg group | No | Not assessed | Poor | Fair | Randomization was probably flawed, and blinding is not reported
Pollock et al, 2001 ^(101)^ | Symptomatic patients with normal TSH and FT4 | Referrals from GPs, hospital clinic, and response to newspaper ad, Glasgow | 25 symptomatic and 19 asymptomatic subjects, sex and age not given | “Recent thyroid function tests within the reference range” plus (a) at least 3 symptoms of hypothyroidism (tiredness, lethargy, weight gain, or 3 others) or (b) no symptoms | Symptomatic subjects weighed more and had worse memory and psychological function than healthy controls | Symptoms, vital signs, biochemical tests after 14 weeks | SF-36 plus validated cognitive/memory testing | Among symptomatic patients (n = 22), there were no important differences between LT4 and placebo groups in any SF-36, memory, or cognitive measures | Placebo significantly improved SF-36 general health and physical health scores | Not assessed, except for SF-36 scores | In asymptomatic patients, LT4 sign, reduced SF-36 vitality scores | Fair | N/A | Too small; authors note that it is only a “pilot study.” Placebo effect, adverse effeet of LT4 in healthy subjects, and baseline difference in cholesterol levels (6.3 vs 5.2) between symptomatic and asymptomatic subjects deserve more study

* Symptomatic group only.

anti-TG, anti-thyroglobulin; ApoB, Apolipoprotein B; atP, antithyroid-peroxidase; ECG, electrocardiogram; GHQ, General Health Questionnaire; GP, general practitioner; HADS, Hospital Anxiety and Depression Questionnaire; LDL, low-density lipoprotein; LDLc, low-density lipoprotein cholesterol; LT4, levothyroxine; SF=36, Medical Outcomes Study short form; SIP, Sickness Impact Profile; TC, total cholesterol; FT4, free thyroxine; TFT, thyroid function test; TRH, thyrotropin-releasing hormone; TSH, thyroid-stimulating hormone.

The second trial (Meier et al) concerned patients with thyroiditis or a history of Graves' disease. ^100^ In this trial, treatment with levothyroxine had no effect on symptoms. In reporting results, the authors emphasized that there was a significant reduction in LDL cholesterol in the levothyroxine-treated group from 4.0 to 3.7 mmol/L (P = 0.004) and no significant reduction in the placebo group. The difference appears to be related to an imbalance in the groups at baseline: pre-treatment LDL cholesterol was 4.0 mmol/L in the treatment group versus 3.7 mmol/L in the placebo group. In fact, post-treatment LDL cholesterol was the same in both groups (3.7 ± 0.2, P = 0.11). When analyzed as a randomized trial, the difference between the treatment and control groups in lipid levels was not significant. The discrepancy suggests that randomization may have been flawed.

We rated the relevance of these 2 studies to screening and found it to be “low.” The Cooper study supports treatment in patients with a history of treated Graves' disease, especially if the serum TSH is above 10 mU/L, but it has little relevance to screening because the natural history of treated Graves' disease differs from the natural history of spontaneous hypothyroidism in the general population.

The third trial, in patients known to have Hashimoto's thyroiditis and positive antithyroid antibodies who had mildly elevated TSH levels, had a similar flaw. ^102^ When analyzed as a randomized trial, there were no significant differences between levothyroxine-treated and placebo groups in any lipid parameter. When analyzed as a pre-/post-treatment study, there was a statistically significant reduction in LDL cholesterol levels (3.6-3.1 mmol/L) in the levothyroxine-treated group, but not in the control group. The study appeared to be unblinded; this could be a major flaw, since differential attention to lipid levels in the treatment and control groups could lead to different behavioral approaches to reducing lipid levels. If the results are valid, they would be fairly relevant to screening; the mean TSH was only slightly elevated, and patients who have antithyroid antibodies and a modestly elevated TSH are found commonly in screening programs.

The next 3 studies may have had more relevance to screening or primary care: they generally concerned patients, mostly women, with subclinical hypothyroidism who were not previously treated for Graves' disease or nodular thyroid disease. However, 2 of the 3 studies had poor internal validity. In the fair-quality trial by Jaeschke and colleagues, 37 patients with subclinical hypothyroidism were recruited from the outpatient clinics of a community hospital and randomized to levothyroxine treatment or placebo. ^15^ Patients given placebo did as well or better than those given levothyroxine. After 6 months, in the levothyroxine group, 8 patients improved, 3 were worse, and 5 were the same according to the “Cooper Questionnaire.” In the placebo group, 11 patients improved, 1 was worse, and 4 were the same. After 11 months, patients treated with levothyroxine had a small but statistically significant improvement in short-term memory, but treatment did not improve general health status as measured by a standardized questionnaire, the Sickness Impact Profile (SIP). In that study, the mean SIP score in patients with subclinical hypothyroidism recruited from a general medical clinic was initially 3.1 out of 10. On this scale, a score of 3.0 is usually interpreted as the border between no disability and mild disability. A random sample of healthy older adults had a similar mean SIP of 3.4.

The other negative trial was too small to achieve balance in the compared groups and had high loss to follow-up. ^103^

A small crossover trial ^74^ concerned women identified by screening in the general population. The 20 subjects were women aged 50 and older who had an initial serum TSH between 4 and 15 mU/L. After 6 months of treatment, the mean symptom score improved by 1.81 units, equivalent to complete relief of one symptom per patient. As judged by subjective improvement and cognitive measures, 4 (24%) of the 19 patients who received levothyroxine improved, while 2 (12%) felt worse with treatment.

The last 2 studies listed in Table 4 concern patients who have TSH levels in the normal range. In 1 of these, 50 micrograms of levothyroxine therapy reduced LDL cholesterol levels from 6.8 to 5.9 mmol/L in patients with elevated total cholesterol levels (>7/5 mmol/L) and normal TSH levels. ^99^ In the other study, levothyroxine was ineffective in patients who had symptoms of hypothyroidism but normal TSH and T4 levels. ^101^ The latter study, designed as a crossover study, found that levothyroxine significantly reduced SF-36 vitality score in healthy subjects and also documented a clinically important and statistically significant effect of placebo.

Many observational studies have examined the effects of treatment in patients with subclinical hypothyroidism. One meta-analysis of these observational studies found that treatment reduced LDL cholesterol levels by 0.4 mmol/L, and a more recent meta-analysis of both observational and randomized studies found that, in previously untreated patients, total cholesterol was reduced by 0.14 mmol/L (-5.6 mg/dL). ^104^ Another review concluded that levothyroxine treatment might reduce serum cholesterol by 8% in selected patients who have both a serum TSH ≥10 mU/L and an elevated total cholesterol (≥ 6.2 mmol/L). ^25^ About 7% of individuals with subclinical hypothyroidism meet these criteria.

Most of the studies on which these analyses are based have important limitations. ^13,^ ^25,^ ^104^ Many of these studies were before/after studies in which reductions in serum lipids could have been due to regression toward the mean. In most, samples were small, selection of patients was poorly described, clinicians and patients were aware of the treatment and of the need to lower lipid levels, and outcome assessment may have been biased. That is, the problem is not that these studies are observational, but that many of them are poor-quality observational studies.

The hazards of relying on observational studies of the effect of drug therapy is illustrated by a large (n = 139) open study of levothyroxine to treat symptoms of hypothyroidism in patients who had normal thyroid function tests. This study found that the mean number of signs and symptoms of hypothyroidism decreased from 13 to 3 following 6 months or more of treatment; 76% of patients had improvement or disappearance of over 12 findings. ^105^ Whether or not these effects are real, they illustrate that only well-controlled trials can determine the effects of thyroxine therapy in patients with subclinical hypothyroidism.

In summary, treatment of subclinical hypothyroidism appears to reduce symptoms in the subset of patients who have a history of Graves' disease and a serum TSH > 10 mU/L. In other subgroups of patients with subclinical hypothyroidism, there is insufficient evidence to determine whether or not treatment is effective in reducing symptoms. Most trials found there was no effect on lipid levels, but because of the number of subjects and the limited quality of the trials, the evidence from randomized trials is insufficient to determine whether treatment has a clinically important effect. No trials of treatment for subclinical hypothyroidism in pregnant patients were identified.

## Other Benefits

One randomized trial of levothyroxine versus placebo used Doppler echocardiography and videodensitometric analysis to assess myocardial structure and parameters of myocardial contractility in 20 patients followed for 1 year. ^98^ We excluded this trial because it did not report any clinical outcome measures.

Another benefit of treating subclinical hypothyroidism is to prevent the spontaneous development of overt hypothyroidism, diagnosed when a patient with subclinical hypothyroidism develops a low FT4 level (see Table 2). This potential benefit has not been studied in randomized trials, so it is necessary to estimate it based on data from observational studies. Based on data from the Whickham study, a previous analysis estimated that, if 1,000 women age 35 and over are screened, 80 will be diagnosed to have subclinical hypothyroidism, and 43 will have a mildly elevated TSH and positive antithyroid antibodies. If these 43 individuals are treated with levothyroxine, by 5 years overt hypothyroidism would be prevented in 3 women ([number needed to treat] NNT = 14.3), while 40 will have taken medication for 5 years without a clear benefit. By 20 years, overt hypothyroidism would be prevented in 29 (67%) of the 43 women, but 14 otherwise healthy women will have taken medication for 20 years.

In assessing the balance of benefits and harms, the key uncertainties are:

1. Without screening or prophylaxis, how long would overt hypothyroidism be undetected?
2. How much morbidity would undiagnosed overt hypothyroidism cause while undetected?
3. What are the harms of treatment in those who do not progress?

No studies have measured the severity of symptoms or degree of disability in newly diagnosed hypothyroid patients or the length of time spent in that state. There are no published data on the effect of careful follow-up on health outcomes in patients with subclinical hypothyroidism. The case for treatment to prevent progression of subclinical hypothyroidism would be greatly strengthened by data showing that this progression is associated with significant burden of illness that could be prevented by earlier treatment.

## Adverse Effects of Levothyroxine

Adverse effects of replacement doses of levothyroxine include nervousness, palpitations, atrial fibrillation, and exacerbation of angina pectoris. Adverse effects were not assessed carefully in the randomized trials listed in Table 4, although some reported them incidentally. In 1 of the trials, 2 of 20 (10%) patients taking levothyroxine quit the protocol because of nervousness and a sense of palpitations. ^74^ In another, 2 of the 18 (11%) patients assigned to levothyroxine withdrew because of complications: 1 because of an increase in angina, and 1 because of new onset atrial fibrillation. ^15^ In a third, anxiety scores were higher in the levothyroxine group. ^103^

A systematic review of observational studies published from 1966 to 1997 found that replacement doses of levothyroxine have not been associated with osteoporosis or with any other serious long-term adverse effects. ^106^ A short-term randomized trial of levothyroxine for subclinical hypothyroidism confirms this view. ^97^ By contrast, thyroid hormone to suppress TSH because of thyroid cancer, goiters, or nodules contributed to osteoporosis in postmenopausal women. ^106^

Overtreatment with levothyroxine, indicated by an undetectable TSH, is another potential risk. About one-fourth of patients receiving levothyroxine for primary hypothyroidism are maintained unintentionally on doses sufficient to cause the TSH to be undetectable. ^2,^ ^35^ Data from the Framingham cohort suggest that 1 excess case of atrial fibrillation might occur for every 114 patients treated with doses of levothyroxine sufficient to suppress the TSH. ^35^ As mentioned above, 2 meta-analyses of older studies and a recent nested case-control study from SOF suggest that, in patients taking levothyroxine, a low TSH is associated with an increased risk for osteoporosis ^42,^ ^43^ and of osteoporotic fractures. ^49^ Another potential risk for overtreatment with levothyroxine is left ventricular hypertrophy and abnormalities of cardiac output, ^54,^ ^58^ but there is insufficient evidence for these effects in patients inadvertently overtreated for hypothyroidism.