# Methods

## Search Strategy

We identified articles published before 1998 from the reference lists of previous reviews ^9,^ ^12,^ ^13,^ ^23,^ ^24,^ ^76,^ ^82–87^ and by searching our own files of over 1,600 full-text articles from the period 1910 to 1998. We then searched MEDLINE® and EMBASE® from 1996 to February 2002, PREMEDLINE March 2002, and the Cochrane Library (2002, Issue 2) to identify additional articles. In a MEDLINE® search, the medical subject headings (MeSH) thyroid function tests and thyroid diseases were combined with the term mass screening, and the text words screening or case-finding. We conducted a separate search for controlled studies of the effect of thyroid-directed treatments on potential complications of subclinical thyroid disease, using the word levothyroxine in title, abstract, or keywords combined with terms for clinical trials. We also searched MEDLINE® from 1966-May 2002 for articles about the adverse effects of thyroid hormone replacement. Periodic hand searching of endocrinologic and major medical journals, review of the reference lists of retrieved articles, and suggestions from peer reviewers of earlier versions of this article supplemented the electronic searches.

## Inclusion Criteria

We selected controlled trials of treatment of thyroid dysfunction that reported at least one health outcome (symptoms, cognitive function, or quality of life) or lipid levels. Broad inclusion criteria were used to get a picture of the benefits and adverse effects of treatment on patients with different degrees of thyroid dysfunction. Specifically, we included any trial that used TSH levels as a criterion for entry, in any population, including patients with known thyroid disease. We also identified observational studies of treatment for subclinical thyroid dysfunction; we included recent studies that had not been included in previous meta-analyses. ^13,^ ^24,^ ^25,^ ^88^

To assess the prevalence of thyroid disease and the causal relationships between thyroid dysfunction and potential complications, we used the following sources:

- Previous meta-analyses and systematic reviews.
- More recent cross-sectional, cohort, and case-control studies of the prevalence of overt or subclinical thyroid dysfunction.
- Cross-sectional and longitudinal studies of the relationship between an elevated or low TSH to potential complications of subclinical hypothyroidism or subclinical hyperthyroidism.

For these categories of studies, we included studies in the general adult population, a demographic segment of the adult population, or among patients seen in the general clinic setting. We excluded studies of screening for congenital or familial thyroid disorders and studies of screening in inpatients, institutionalized patients, and series of patients seen in specialized referral clinics for depression or obesity.

Finally, we identified observational studies of the long-term adverse effects of levothyroxine therapy. We excluded studies of suppressive doses of thyroxine; to be included, the study had to include at least some patients that were taking replacement doses of thyroxine.

## Data Extraction

We used predefined criteria from the USPSTF to assess the internal validity of trials, which we rated as “good,” “fair,” or “poor.” We also rated the applicability of each study to screening. The rating system is described in detail elsewhere. ^89^ (The criteria are listed as column headings in Table 3.) We also abstracted information about its setting, patients, interventions, and outcomes. When possible, we recorded the difference between the probability of a response in the treatment and control groups for each complication studied.

Table 3. Quality of Randomized Trials of Thyroxine Replacement Therapy

Study, Year | Random Assignment? | Allocation concealed? | Groups Similar at Baseline? | Eligibility Criteria Specified? | Outcome Assessors Blinded? | Care Provider Blinded? | Patient Unaware of Treatment? | Intention-to-Treat Analysis?* | Maintenance of Comparable Groups? | Reporting of Attrition, Crossovers, Adherence, and Contamination? | Differential Loss to Follow-up or Overall High Loss to Follow-up? | Statistical Analysis Appropriate? | Score (Good/Fair/Poor)
Cooper et al, 1984 ^(75)^ | Yes, by individual | Not stated | LT4 subjects were older (58.2 vs 50.2) and had fewer symptoms (2.1 vs 2.4) but otherwise similar | Yes | Yes | Probably (1 of 2 investigators is said to be blinded) | Yes, not verified | No | The number of patients randomized appears to be 41 ; 33 patients were analyzed. It is not clear which group the other 8 belonged to | Partially | Unclear, probably not | Yes, except it did not address dropouts | Good
Meier et al, 2001 ^(100)^ | Sequential assignment using a predefined list; randomized by matched pairs | No | LT4 subjects had higher TSH(14.4±1.7 vs 11.3±1.0)and LDLc (4.1 vs 3.7) but groups were otherwise similar for the whole groups (n = 66); comparisons were not presented for the analyzed group (n = 63) | Yes | Not stated | Yes | Yes, not verified | No | Yes | No | No | No, analyzed as RCT, but reported primarily as a before/after study | Poor
Meier et al, 2001 ^(100)^ | Yes, by individual | Not stated | Generally yes, but mean TSH (6 vs 4.9) and LDLc (3.6 vs 3.3) were higher in LT4 group | Yes | No | No | Probably were aware, since dosing and length of follow-up differed. It is not clear whether patients were informed of their lipid levels. | Yes, assuming that completion of study was not a criterion for inclusion | Probably | No | No | Yes, when analyzed as an RCT | Poor
Jaeschke et al, 1996 ^(15)^ | Yes, by individual | Not stated | LT4 subjects had higher TSH (12.1 vs 9.4) and slightly more symptoms (14 vs 13) but similar in age | Yes | Yes | 1 investigator was not blinded but was not involved in assessment or care | Yes, not verified | No | Probably, 3 dropouts in each group | Partially | Overall 6 out of 40 dropped out | Yes, except it did not address dropouts | Fair
Kong et al, 2002 ^(103)^ | Yes, in blocks of 6 | Yes | LT4 subjects were older (53 vs 45 years), had lower FT4 (.9 vs 1), and higher TSH (8 vs 7.3) | Yes | Yes | 1 investigator was not blinded but was not involved in care | Yes, not verified | No | Unknown | Yes | Yes, especially for lipid comparison | Yes, except it did not address dropouts | Poor
Nystrom et al, 1988 ^(74)^ | Not stated | Not stated | No baseline data were given for the groups initially assigned LT4 and placebo | Yes | Yes | Yes | Probably aware, verified | No | Yes | No | No | No, no baseline comparisons or results provided about the first assignment | Poor
Michalopoulou et al, 1998 ^(99)^ | Yes, method not stated | Not stated | Inadequately described. LDL was higher in 50 mg group (6.8 vs 6.2) | Yes | Not stated | Not stated | Not stated | Probably yes | Yes | No | No | No, analyzed as before/after | Poor
Pollock et al, 2001 ^(101)^ | Yes, by coin toss in blocks of 4 | No | No baseline data were given for the groups initially assigned LT4 and placebo | Yes | Not stated | Yes | Yes, verified | No | Probably, but all 3 dropouts were from the LT4 group | No | No | Yes | Fair

* Analysis based on assignment to treatment groups AND includes all randomized subjects.

FT4, free thyroxine; LDL, low-density lipoprotein; LDLc, low-density lipoprotein cholesterol; LT4, levothyroxine; RCT, randomized controlled trial; TSH, thyroid-stimulating hormone.