# Introduction

## Burden of Illness

Hyperthyroidism and hypothyroidism are common conditions that have lifelong effects on health. About 5% of U.S. adults report having thyroid disease or taking thyroid medication. ^1,^ ^2^ In a cross-sectional study of 2,799 well-functioning adults aged 70–79, 9.7% of black women, 6% of white women, 3.2% of black men, and 2.2% of white men reported a history of hyperthyroidism. ^3^ In the same study, 6.2% of black women, 16.5% of white women, 1.7% of black men, and 5.6% of white men reported a history of hypothyroidism.

Hyperthyroidism has several causes. Graves' disease, the most common intrinsic cause, is an autoimmune disorder associated with the development of long-acting thyroid stimulating antibodies (LATS). Single or multiple thyroid nodules that produce thyroid hormones can also cause hyperthyroidism. The use of excessive doses of the thyroid hormone supplement levothyroxine is also a common cause.

The most common cause of hypothyroidism is thyroiditis due to antithyroid antibodies, a condition called “Hashimoto's thyroiditis.” Another common cause of hypothyroidism is prior treatment for Graves' disease with surgery or radioiodine.

Consequences of untreated hyperthyroidism include atrial fibrillation, congestive heart failure, osteoporosis, and neuropsychiatric disorders. Both hyperthyroidism and hypothyroidism cause symptoms that reduce functional status and quality of life.

Subclinical thyroid dysfunction, which can be diagnosed by thyroid function tests before symptoms and complications occur, is viewed as a risk factor for developing hyperthyroidism and hypothyroidism complications. The goal of screening is to identify and treat patients with subclinical thyroid dysfunction before they develop these complications.

This article focuses on whether it is useful to order a thyroid function test for patients who have no history of thyroid disease when they are seen by a primary care clinician for other reasons. The review was used by 2 expert panels: the U.S. Preventive Services Task Force (USPSTF), which will make recommendations regarding screening in the general adult population, and the Institute of Medicine, which will focus on the Medicare population.

## Definition of Screening and Case-finding

Screening can be defined as “the application of a test to detect a potential disease or condition in a person who has no known signs or symptoms of that condition at the time the test is done.” ^4^ By this definition, screening with thyroid function tests may identify asymptomatic individuals as well as patients who are have mild, nonspecific symptoms such as cold intolerance or feeling “a little tired.”

The symptoms associated with thyroid dysfunction are shown in Table 1. ^5,^ ^6^ When many of these symptoms and signs occur together, the clinician may have strong suspicion that the patient has thyroid disease. However, patients who complain of 1 or 2 of the symptoms in Table 1 may be no more likely to have abnormal thyroid function test than those who have no symptoms. In older patients ^7^ and in pregnant women, such symptoms are so common that it becomes meaningless to try to distinguish between “asymptomatic” patients and those who have symptoms that may or may not be related to thyroid status.

Table 1. Symptoms and Signs of Thyroid Dysfunction

Studies of screening can be classified according to the setting in which the decision to screen takes place. In case finding, testing for thyroid dysfunction is performed among patients who come to their physicians for unrelated reasons. When the screening test is abnormal, the patient is called back for a detailed thyroid-directed history. Studies of case-finding programs provide the most realistic estimates of the effects and costs of screening in clinic or office practice.

Population-based studies of screening use special methods to recruit, contact, and follow patients in the context of an epidemiologic research effort. Such studies show the extent of unsuspected thyroid disease in a population sample of a particular geographic area, but do not reflect the yield or costs of screening in office-based practice.

## Classification of Thyroid Dysfunction

Thyroid dysfunction is a graded phenomenon, and progresses from early to more advanced forms. As better biochemical tests have come into use, classification of the grades of thyroid dysfunction has changed dramatically. Historically, clinical, biochemical, and immunologic criteria have been used to classify patients with milder degrees of thyroid dysfunction. ^8,^ ^9^ Today, the most common approach is to classify patients according to the results of thyroid function tests (Table 2). In this classification, “overt hypothyroidism” refers to patients who have an elevated thyrotropin (TSH) and a low thyroxine (T4) level. “Overt hyperthyroidism” refers to patients who have a low TSH and an elevated T4 or triiodothyronine (T3).

The primary rationale for screening is to diagnose and treat subclinical thyroid dysfunction. ^10–12^ This rationale views subclinical thyroid dysfunction as a risk factor for the later development of complications and as a condition that may have symptoms that respond to treatment. Controversy centers on whether early treatment or close follow-up is warranted in apparently healthy people in whom the only indication of a thyroid disorder is an abnormal TSH result.

The terms “subclinical hypothyroidism” and “mild thyroid failure” refer to patients who have an elevated TSH and a normal thyroxine level (Table 2). ^12^ In some classification schemes, patients who have an elevated TSH and a normal thyroxine level are subclassified according to the degree of TSH elevation and the presence of symptoms, signs, and antithyroid antibodies. ^13^

Table 2. Classification of Thyroid Dysfunction

In the literature, the term “subclinical hypothyroidism” has been used to describe several conditions:

1. Patients who have subclinical hypothyroidism as a result of surgery or radioiodine treatment for Graves' disease.
2. Patients who take inadequate doses of levothyroxine therapy for known thyroid disease.
3. Patients who have mildly elevated TSH levels, normal T4 levels, and non-specific symptoms that could be due to hypothyroidism.
4. Asymptomatic patients who are found by screening to have an elevated TSH and normal T4.

In this report, we are primarily concerned with the last 2 groups: patients who have no known history of thyroid disease and have no, or few, signs or symptoms.

The term “subclinical hyperthyroidism” is used to describe conditions characterized by a low TSH and normal levels of circulating thyroid hormones (thyroxine and triiodothyronine). Subclinical hyperthyroidism has the same causes as overt hyperthyroidism. These include excessive doses of levothyroxine, Graves' disease, multinodular goiter, and solitary thyroid nodule. Most studies of the course of subclinical hyperthyroidism concern patients whose history, physical examination, ultrasound, or thyroid scan suggests one of these causes. There are relatively few studies of patients found by screening to have a low TSH, normal T4 and T3 levels, and a negative thyroid evaluation, the largest group identified in a screening program.

## Accuracy of Screening Tests

Screening for thyroid dysfunction can be done using a history and physical examination, antithyroid antibodies, or thyroid function tests, including various assays for TSH and T4. Today, the TSH test is usually proposed as the initial test in screening because of its ability to detect abnormalities before serum thyroxine and triiodothyronine levels are abnormal. When used to confirm suspected thyroid disease in patients referred to an endocrine specialty clinic, the sensitive TSH has a sensitivity above 98% and a specificity greater than 92% for the clinical and functional diagnosis. ^14^

The accuracy of a TSH when used to screen primary care patients has proved difficult to evaluate. The greatest difficulty is in classifying a patient who has an abnormal TSH, normal T4 and T3 levels, and no evidence supporting thyroid disease on physical examination. Those who consider the TSH to be the “gold standard” determination of disease would define such a patient as a “true positive.” Others argue that patients who have an abnormal TSH, but never develop complications and never progress, should be considered “false positives.” They argue that these patients happen to have TSH levels outside the 95% reference limits for the general population, but never truly had a thyroid disorder to begin with. ^13^

In screening programs and in the primary care clinic, many patients found to have an abnormal TSH revert to normal over time. In one randomized trial, for example, mildly elevated TSH levels reverted to normal in 8 of 19 patients given placebo. ^15^ In older subjects, only 59% (range, 14%–87%) of patients with an undetectable TSH on initial screening had an undetectable TSH level when the TSH was repeated. ^16,^ ^17^ In the Framingham cohort, screening identified 41 people with an undetectable serum TSH (≤ 0.1 mU/L) and a normal serum T4 level (< 129 nmol/L). ^18^ After 4 years of follow-up, when 33 of these people were retested, 29 had higher serum TSH levels (> 0.1 mU/L).

Nonthyroidal illness is an important cause of false positive TSH test results. In a recent systematic review of screening patients admitted to acute care and geriatric hospitals, the positive predictive value of a low serum TSH (< 0.1 mU/L) was 0.24, meaning that approximately 1 in 4 patients proved to have hyperthyroidism. ^19^ For hypothyroidism, the predictive value of a serum TSH between 6.7 and 20 mU/L was 0.06.

The predictive value of a low TSH may also be low in frail or very elderly subjects. ^20–22^ One retrospective study reviewed the course of 40 female nursing home residents who had a low TSH and initially normal T4. ^21^ In 10 subjects (3 with low T3 levels and 7 who died) nonthyroidal illnesses probably caused the low TSH. In 18 other women, the TSH subsequently normalized, but the reason for the initially low TSH was not apparent. Only 3 subjects were later diagnosed to have thyroid disease as the cause of the low TSH (positive predictive value 0.075).

## Prevalence

In a population that has not been screened previously, the prevalence of the disease, along with the sensitivity of the screening test and follow-up tests, determine the potential yield of screening. These factors, along with the proportion of subjects who have a screening test and comply with follow-up testing if indicated, determine the actual yield of a screening program.

Over 40 studies reported the prevalence of thyroid dysfunction in defined geographic areas, health systems, primary care clinics, and at health fairs. ^1,^ ^2,^ ^23–33^

In cross-sectional, population-based studies, a serum TSH ≥ 4 mU/L in conjunction with a normal thyroxine level (subclinical hypothyroidism) is found in about 5% of women and in up to 3% of men. In an analysis of the third National Health and Nutrition Examination Survey (NHANES-III), a population-based survey of 17,353 people aged 12 and older representing the U.S. population, subclinical hypothyroidism was defined as a serum TSH level above 4.5 mU/L and a serum T4 ≥ 57.9 nmol/L. ^1^ Among those who did not have a history of thyroid disease, the prevalence of subclinical hypothyroidism was 5.8% among white, non-Hispanic females, 1.2% among black, non-Hispanic females, and 5.3% among Mexican Americans. For men, the prevalence was 3.4% among whites, 1.8% among blacks, and 2.4% among Mexican Americans. Older age and female sex are well-documented risk factors for subclinical hypothyroidism. In the NHANES-III survey, the overall prevalence of a serum TSH ≥ 4.5 mU/L was about 2% at ages 30-29, 6% at ages 50–59, 8% at ages 60–69, and 12% at ages 70–79. In a population-based study in Whickham, England, the prevalence (serum TSH ≥ 6 mU/L and normal T4) was 4% to 5% in women age 18 to 44, 8% to 10% in women age 45 to 74, and 17.4% in women over the age of 75. ^34^ The prevalence was 1% to 3% in men age 18 to 65 and 6.2% in men over the age of 65.

Population factors, such as iodine intake and ethnicity, affect the prevalence of subclinical hypothyroidism, but differences among studies are also due to differences in the definition of an abnormal TSH level and ascertainment of a history of thyroid disease or levothyroxine use.

The prevalence of subclinical hyperthyroidism (a low TSH in conjunction with normal T4 and T3 levels) depends on how a low TSH is defined. A meta-analysis found that, when defined as an undetectable TSH level in a person with a normal free thyroxine level, the prevalence of subclinical hyperthyroidism was about 1% (confidence interval [CI], 0.4%–1.7%) in men older than 60 and 1.5% (CI, 0.8%–2.5%) in women older than 60. ^25^ Other studies defined subclinical hyperthyroidism as a TSH below the lower limit of the normal range (about 0.4 mU/L) in a person with a normal T4 level. When defined in this way, the prevalence of subclinical hyperthyroidism in men and women aged 60 and older is as high as 12%. ^35^

## Incidence

In a population that has been screened previously, the incidence of new cases of thyroid dysfunction is the most important factor in determining the yield of a second round of screening. In a 20-year follow-up of the Whickham population, the annual incidence of overt thyroid dysfunction was 4.9 per 1,000 in women (4.1 hypothyroid and 0.8 hyperthyroid) and 0.6 per 1,000 in men (all hypothyroid). ^36^ In most other studies, the incidence of hyperthyroidism is 0.3 to 0.4 per 1,000 in women and 0.01 to 0.1 per 1,000 in men. ^23^

Within a given geographic region, older age, an elevated TSH level, antithyroid antibodies, and female sex are the strongest risk factors for developing overt hypothyroidism. In the Whickham survey, for a 50-year-old woman who has a serum TSH level of 6 mU/L and positive antithyroid antibodies, the risk for developing overt hypothyroidism over 20 years is 57%; for a serum TSH of 9 mU/L, the risk is 71%. ^36^ A 50-year-old woman who had a normal TSH and negative antibody test had a risk for only 4% over 20 years. The risk for progression was not evenly distributed throughout the follow-up period. Nearly all women who developed hypothyroidism within 5 years had an initial serum TSH greater than 10 mU/L.

Exposure to ionizing radiation has also received attention as a potential risk factor for thyroid dysfunction. In general, studies of populations exposed to radioactive fallout have focused primarily on screening for thyroid cancer. A large cohort study of populations exposed to radiation from the Hanford nuclear facility provides the best-quality evidence about the risk for thyroid dysfunction. The study proved definitively that exposure to radioactive fallout from Hanford conferred no additional risk for hyperthyroidism or hypothyroidism compared to unexposed populations. ^37^ Specifically, the study found that there was no dose-response relationship between exposure to radioactive fallout and the incidence of thyroid disease. It also found that the rate of thyroid dysfunction in the Hanford region was no higher than that reported in areas which had not been exposed.

## Evidence Regarding the Complications of Subclinical Hyperthyroidism

Advocates of screening for subclinical hyperthyroidism argue that early treatment might prevent the later development of atrial fibrillation, osteoporotic fractures, and complicated overt hyperthyroidism. Other potential benefits of screening are earlier treatment of neuropsychiatric symptoms and prevention of the long-term consequences of exposure of the heart muscle to excessive stimulation from thyroid hormones.

Atrial fibrillation. A good-quality cohort study in the Framingham population found that, in subjects older than 60 who did not take levothyroxine and had a low TSH, the risk for atrial fibrillation was 32% (CI, 14%–71%) over 10 years. ^35^ The risk for subjects who had a normal TSH level was 8%. Patients with low serum TSH values were stratified into 2 groups, those with serum TSH values ≤ 0.1 mU/L and those with values of > 0.1 to 0.4 mU/L; only in the former group was the risk for atrial fibrillation increased. A more recent cross-sectional study of atrial fibrillation in overt and subclinical hyperthyroidism had serious flaws and was rated poor-quality. ^38^

The clinical consequences of atrial fibrillation in patients who have a low TSH have not been studied. In general, chronic atrial fibrillation is associated with stroke, a higher risk for death, and other complications. ^39^

Mortality. A population-based, 10-year cohort study of 1,191 people aged 60 and older found a higher mortality rate among patients who had a low TSH initially. ^40^ The excess mortality was due primarily to higher mortality from cardiovascular diseases. In this study, the recruitment strategy and the statistical adjustment for potential confounders were inadequate; patients who had a low TSH may have had a higher prevalence of other illnesses, but adjustment was done only for age and sex, and not for comorbidity. Such adjustment would be critical because acutely and chronically ill elderly patients have more false low TSH than relatively healthy patients, presumably as a result of their illness. ^19^ Thus, while it is possible that patients who had a low initial TSH had higher mortality because of their thyroid disease, it is also possible that patients who were ill to begin with had a low TSH as a result of their illness.

Osteoporosis and fracture. A good-quality study from the Study of Osteoporotic Fractures (SOF) cohort found similar bone loss among women with undetectable, low, and normal TSH levels. ^41^ Two meta-analyses of older studies ^42,^ ^43^ suggest that women who have a low TSH because they take thyroid hormones are at a higher risk for developing osteoporosis. Other studies of the risk for osteoporosis concern small numbers of subjects with nodular thyroid disease or Graves' disease ^44–47^ rather than patients who have no obvious clinical signs of thyroid disease.

Among women in the SOF population, a history of treated hyperthyroidism is associated with an increased risk for having a hip fracture later in life. ^48^ A more recent nested sample of cases and controls from SOF examined the relationship between fractures and a low TSH in a broader group of women who had been followed for 6 years. ^49^ The sample consisted of 148 women with hip fractures, 149 with vertebral fractures, and 304 women without fracture who were selected as controls. The subjects were classified according to their initial TSH level. Among the 148 women with hip fractures, 22 had an undetectable serum TSH (<0.1 mU/L). At baseline, the cases were significantly older, weighed less, and were less likely to be healthy by self-report than controls. They were also twice as likely to have a history of hyperthyroidism and had lower bone density at baseline. After adjustment for all of these confounding factors, the risk for hip fracture among women who had an undetectable TSH was elevated, but the value was of borderline statistical significance (adjusted relative hazard ratio 3.6; CI, 1.0–12.9). Similarly, after adjustment for confounders the risk for vertebral fracture among women who had an undetectable TSH was significantly elevated when compared with 235 controls (odds ratio [OR], 4.5; CI, 1.3–15.6). Among women who had a borderline low serum TSH (0.1–0.5 mU/L), the risk for vertebral fracture (OR, 2.8; CI, 1.0–8.5), but not hip fracture, was elevated.

This analysis has limited relevance to screening because the investigators were not able to obtain serum FT4 or FT3 tests, which could have distinguished between overt and subclinical hyperthyroidism. Also, among the 148 women with hip fractures, 22 had an undetectable serum TSH (< 0.1 mU/L); approximately 19 of these (86%) took thyroid hormones when their initial TSH measurement was made. Bauer and colleagues stated that “thyroid hormone use was not associated with increased risk for...fracture,” but there were not enough women with undetectable TSH levels not taking thyroid hormones to make a valid comparison. ^49^ The analysis could not exclude the possibility that some of the women with low TSH levels had multiple, interacting risk factors and that other factors concomitant with age or socioeconomic status could have been confounders.

Complicated thyrotoxicosis and progression to overt hyperthyroidism. Thyrotoxicosis can be complicated by severe cardiovascular or neuropsychiatric manifestations requiring hospitalization and urgent treatment. There are no data linking subclinical hyperthyroidism to the later development of complicated thyrotoxicosis. Such a link is unlikely to be made because 1) complicated thyrotoxicosis is rare, 2) one-half of cases occur in patients with known hyperthyroidism, and 3) complications are associated with social factors, including insurance status, that may also affect access to screening and follow-up services. ^50^

Progression from subclinical hyperthyroidism is well-documented in patients with known thyroid disease (goiter or nodule), but not in patients found by screening to have a low TSH and no thyroid signs. Based on the sparse data from screening studies, each year 1.5% of women and 0% of men who have a low TSH and normal T4 and T3 levels develop an elevated T4 or T3. ^16,^ ^25,^ ^51^ In one population-based study (n = 2,575), 33 of 41 patients who had an initially low TSH had a serum TSH higher than 0.1 mU/L on repeat testing 4 years later. ^18^ Two patients developed overt hyperthyroidism during the follow-up period. In another population-based study, screening in 886 85-year-olds found 6 women and 2 men who had an undetectable TSH and were not already taking levothyroxine. ^51^ After 3 years of follow-up, 2 women were diagnosed to have hyperthyroidism: one was apparently healthy initially, while the other had atrial fibrillation on the initial examination.

Dementia. In the Rotterdam study, a population-based, longitudinal study with 2-year follow-up (discussed in detail below), people with reduced TSH levels at baseline had a more than threefold increased incidence of dementia (RR = 3.5; 95% CI, 1.2–10.0) and of Alzheimer's disease (RR = 3.5; 95% CI, 1.1–11.5), after adjustment for age and sex. ^52^ With respect to this result, Kalmijn et al stated that the results were similar “when controlling for the effects of atrial fibrillation or excluding subjects taking beta-blockers.” These results are not reported, however, and it is unclear whether they were statistically significant. Later, after presenting several other results, they stated that “adjustments for education, symptoms of depression, cigarette smoking, or apolipoprotein ϵ4 did not alter any of these findings,” ^52^ but it is not clear whether this statement pertains to the main result.

Symptoms and cardiac effects. Untreated or inadequately treated hyperthyroid patients who have neuropsychiatric symptoms or congestive heart failure may respond to treatment. In the setting of nodular thyroid disease, Graves' disease, or the long-term use of suppressive doses of levothyroxine, subclinical hyperthyroidism has also been associated with cognitive abnormalities, abnormalities in cardiac contractility, and exercise intolerance. ^53–58^ However, the frequency of symptoms or myocardial contractility abnormalities in patients who have subclinical hyperthyroidism found by screening is not well-studied, and no study has linked abnormalities in cardiac contractility or output to the development of clinically important heart failure.

## Evidence Regarding the Complications of Subclinical Hypothyroidism

The best-studied potential complications of hypothyroidism are hyperlipidemia, atherosclerosis, symptoms, and (for subclinical disease) progression to overt hypothyroidism. In pregnancy, subclinical hypothyroidism confers additional risks to both mother and infant.

Hyperlipidemia. Overt hypothyroidism has long been known to be associated with elevated levels of cholesterol; ^59^ however, patients in the earliest studies had very severe hypothyroidism. In more recent studies, there is a clinically important increase in total cholesterol and low-density lipoprotein (LDL) cholesterol among men ^60^ and women ^61,^ ^62^ with overt hypothyroidism, who usually have serum TSH levels higher than 20 mU/L.

In women with milder forms of hypothyroidism, the relation between TSH and total cholesterol or LDL cholesterol is inconsistent. About 1 in 4 patients with subclinical hypothyroidism has a total cholesterol concentration higher than 6.2 mmol/L. The Whickham survey found no relationship between subclinical hypothyroidism and hyperlipidemia. ^34^ Recent, cross-sectional, population-based studies of the relation between TSH and lipid levels in women have had mixed results. In the Rotterdam study ^33^ (discussed in detail below), lipid levels were significantly lower among women with subclinical hypothyroidism than among euthyroid women. A fair-quality study of randomly selected Medicare recipients found no differences in total cholesterol, LDL cholesterol, high-density lipoprotein (HDL) cholesterol, or triglycerides between subjects who had a serum TSH < 4.6 (n = 684) and those who had a serum TSH between 4.7 and 10 (n = 105). There were non-significant increases in LDL cholesterol and HDL cholesterol among women who had a serum TSH >10 (LDL cholesterol 143 vs 128 in euthyroid women, P = 0.08; HDL cholesterol 41.6 vs 47.5, P = 0.053). ^31^

Conversely, a cross-sectional, population-based study from the Netherlands found that the prevalence of subclinical hypothyroidism was correlated with lipid levels; the prevalence was 4% among women with a total cholesterol level < 5 mmol/l; 8.5% when total cholesterol was 5 to 8 mmol/l; and 10.3% when total cholesterol was > 8 mmol/l. ^63^ Another recent cross-sectional study of 279 women over the age of 65 found a strong relationship between hyperlipidemia and serum TSH levels. ^64^ Of the 279 women, 19 (6.8%) had a serum TSH > 5.5 mU/L. After adjustment for age, weight, and estrogen use, women who had a serum TSH > 5.5 mU/L had 13% higher LDL cholesterol (95% CI, 1%–25%) and 13% lower HDL cholesterol (CI, -25%–0%) than women with a normal serum TSH (0.1–5.5 mU/L). However, 2 of the 19 women who had an elevated TSH used thyroxine, suggesting that they had inadequately treated overt hypothyroidism. Because T4 and T3 levels were not measured, it is possible that others in this group had overt hypothyroidism as well. Moreover, only 1 of the 19 women (6%) took estrogen replacement therapy, whereas 32 of 250 women in the euthyroid group used estrogen. The analysis was adjusted for estrogen use, but not for other factors, such as socioeconomic status, that is associated with lipid levels and is also known to be associated with estrogen use.

Men with a mildly elevated TSH generally do not have an increased risk for hyperlipidemia, but data on men are sparse. Hypercholesterolemic men do not have a higher prevalence of subclinical hypothyroidism than men with low lipid levels. ^63^

Another cross-sectional study of 2,799 adults age 70–79 illustrates some of the difficulties in determining whether subclinical hypothyroidism is associated with hypercholesterolemia, especially in men. ^3^ For the entire group, a serum TSH > 5.5 mU/L was associated with a 9 mg/dL (0.23 mmol/L) higher total cholesterol after adjustment for age, sex, race, body mass index, tobacco, alcohol, and estrogen use, and diabetes. Among men, the association was statistically significant for a cutoff serum TSH ≥ 7.0 mU/L, but not for a serum TSH ≥ 5.5 mU/L. About 23% of white subjects and 14% of black subjects took lipid-lowering medication and a substantial proportion took thyroid hormones (eg, 18% of white women, 6.1% of white men). Among subjects taking thyroid hormones but not lipid-lowering medication, a serum TSH ≥ 5.5 mU/L was associated with 15 mg/dL higher total cholesterol. However, the results for subjects not taking either medication were not reported.

Atherosclerosis. The relationship of subclinical hypothyroidism to the later development of atherosclerosis is unclear. ^31,^ ^33,^ ^65^ The Whickham survey found no relationship between initial TSH levels and the subsequent development of ischemic heart disease over 20 years of follow-up. ^65^

A widely publicized population-based study of 1,149 women age 55 or older, from Rotterdam, came to a different conclusion. ^33^ The main analysis in the paper was cross-sectional. In that analysis, after adjustment for age, body mass index, cholesterol level, blood pressure, and tobacco use, a serum TSH>4.0 mU/L was associated with a history of myocardial infarction (OR, 2.3; CI, 1.3–4.2) and with atherosclerosis of the abdominal aorta, diagnosed by blinded review of a lateral radiograph of the lumbar spine (OR, 1.9; CI, 1.2–3.1). An analysis of incident myocardial infarction over 3 to 6 years of follow-up found a statistically non-significant increased risk in women with a serum TSH > 4.0 mU/L (adjusted relative risk 2.5; CI, 0.7–9.1).

The strengths of the Rotterdam study are the relatively large sample size, adjustment for some potential confounders, and validated, blinded assessment of outcomes. Because the study was primarily cross-sectional, the findings do not prove that an elevated TSH precedes the development of atherosclerosis. The prospective part of the study adds little because, at baseline, women who had an elevated TSH had a higher prevalence of atherosclerotic disease; they would be expected to have a higher incidence of myocardial infarction over 3 to 6 years, in any case. The prospective analysis would have been more consequential if subjects who had atherosclerosis at baseline were excluded. In contrast, the long follow-up period in the Whickham study reduces the chance that baseline differences in the prevalence of coronary disease affected the results. ^65^ None of the cross-sectional studies adequately adjusted for several factors that may influence rates of cardiovascular disease, such as socioeconomic status, diet, diabetes, estrogen use, and other health practices. The relation of these factors to the development of subclinical hypothyroidism has not been well studied, so it is possible that 1 or more of them are confounders.

In the Rotterdam study, ^33^ women with subclinical hypothyroidism had lower lipid levels than euthyroid women; this might be a result of higher use of diet or other lipid-lowering therapy in women with known cardiovascular risk factors, but it also might suggest that the women developed atherosclerosis by another mechanism. One hypothesis is that elevations in both homocysteine and cholesterol may contribute to the elevated risk for atherosclerosis in overt hypothyroidism. In cross-sectional studies, including an analysis of the second National Health and Nutrition Examination Survey (NHANES-II) sample, patients who had overt hypothyroidism had higher homocysteine levels than euthyroid subjects. ^66,^ ^67^ Although no single study has adjusted statistically for all potential confounders, the association of elevated homocysteine and hypothyroidism appears to persist after controlling for serum folate levels, which are decreased in hypothyroidism. ^66–70^ In overtly hypothyroid patients, homocysteine levels decreased after treatment with levothyroxine in small, observational studies. ^69–73^ The association of homocysteine levels with subclinical hypothyroidism has not yet been established.

Symptoms, mood, and quality of life. In its 1998 review and guideline, the American College of Physicians concluded that, in the general population, it was not clear if the prevalence and severity of symptoms and quality of life differs for individuals who have mildly elevated TSH levels. ^7,^ ^74^ Since then, 2 cross-sectional studies in volunteers have addressed this question, with mixed results. A cross-sectional interview survey of 825 Medicare enrollees in New Mexico found no differences in the age-adjusted frequency of self-reported symptoms between participants with serum TSH elevations from 4.7 to 10 mU/L and those with normal TSH concentrations. ^31^ A larger survey from Colorado (n = 25,862) is less pertinent because it included subjects who took levothyroxine in the analysis of symptoms. It also found no difference between euthyroid subjects and those with subclinical hypothyroidism in current symptoms, but found a higher percentage of “changed symptoms” in the subclinical hypothyroid group (13.4% vs 15.4%). ^2^

Patients who have subclinical hypothyroidism and a history of antithyroid treatment for Graves' disease or nodular thyroid disease have a higher prevalence of symptoms than healthy controls. ^75,^ ^76^ It is likely that this observation is valid, but an important limitation of the evidence should be noted: the appropriate comparison group is not healthy volunteers, but patients who have a normal TSH and a history of antithyroid treatment. The reason is that euthyroid patients who have a history of treatment for hyperthyroidism also have a higher prevalence of anxiety, depression, and psychosocial dysfunction than healthy controls. ^77^

Pregnancy complications. Three recent reports from a cohort study of pregnant women have linked TSH levels in pregnancy to poor obstetric outcomes and to poor cognitive development in children. In the first report, among 9,403 women with singleton pregnancies, serum TSH measurements were 6 mU/l or greater in 209 women (2.2%). ^78^ The rate of fetal death was significantly higher in those pregnancies (3.8%) than in the women with serum TSH less than 6 mU/l (0.9%, OR, 4.4; 95% CI, 1.9–9.5). In the second report, the children of women who had a high serum TSH (mean 13.2 ± 0.3 mU/L) in the first trimester of pregnancy had lower IQ scores than matched controls (mean serum TSH 1.4 ± 0.2 mU/L) when they were 7 to 9 years of age. ^79^ The average difference in IQ was 7 points; 19% of the children of hypothyroid mothers had IQ scores of 85 or less. Although no statistical adjustment for baseline differences was done, at baseline, age, socioeconomic status, and other risk factors for low IQ were similar in the 2 groups. Results for the subgroup who had subclinical hypothyroidism were not broken out, but most of the women fell into this category (that is, they had normal T4 levels).

The third report from these authors analyzed TSH levels by outcomes. Fifty percent of the children of 20 mothers who had a TSH equal to or higher than the 99.85 percentile had IQ scores greater than 1 standard deviation (SD) below the control mean. Fifteen percent of the children of controls, and 21 percent of the children of women who had a TSH between the 98 and 99.85 percentile, had IQ scores this low. ^80^

## Prior Recommendations

In 1996, the USPSTF recommended against routine screening for thyroid disease in asymptomatic adults (D recommendation). ^81^ They found insufficient evidence to recommend for or against routine screening with thyroid function tests in the elderly, but recommended screening based on the higher prevalence of disease and the increased likelihood that symptoms of thyroid disease will be overlooked (C recommendation). At that time, 2 randomized trials of treatment for subclinical hypothyroidism had been done. The Task Force found that one of them ^75^ was not relevant to screening, because the subjects had a known history of thyroid disease. They found the other trial to be methodologically flawed. ^74^ There were no trials of treatment for subclinical hyperthyroidism.

## Analytic Framework and Key Questions

In this paper we address whether the primary care physician should screen for thyroid function in patients seen in general medical practice who have no specific indication for thyroid testing and who come to the physician for other reasons. We focus on whether screening should be aimed at detection of subclinical thyroid dysfunction and whether individuals who have mildly abnormal TSH values can benefit.

We used the analytic framework in Figure 1 to guide the literature review. The population of interest was adults who are seeing a primary care clinician, have no history of thyroid disease, and have no or few signs or symptoms of thyroid dysfunction.

Figure 1. Screening with Thyroid Function Tests Analytic Framework

*FT4, free thyroxine; FT3, free triiodothyronine.

Arrow 1 represents direct evidence of health benefits from controlled studies of screening; no such studies have been done. Arrows 2 and 3 represent the ability of screening to detect unsuspected thyroid dysfunction, the false positive rate of the screening tests, and the symptom status of the patients diagnosed by screening. These issues, summarized above, were reviewed in detail elsewhere. ^14,^ ^25^ In this article, we address key questions related to Arrows 4 and 5, focusing primarily on evidence about the benefits and harms of treating early thyroid dysfunction. Specifically, we addressed:

1. What are the benefits of earlier treatment of a) subclinical hyperthyroidism and b) hypothyroidism?
2. What are the adverse effects of treatment?

A thorough review of the adverse effects of antithyroid drugs, radioiodine therapy, thyroid surgery, and thyroid replacement therapy was beyond the scope of this review. Instead, we emphasize the frequency of adverse effects in trials of levothyroxine therapy for subclinical hypothyroidism and the potential adverse effects of long-term treatment with levothyroxine.