# References

1 U.S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Screening for Lipid Disorders in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(6):625–33. PMID: 27532917. 10.1001/jama.2016.9852 27532917
2 Lozano P, Henrikson NB, Dunn J, . Lipid Screening in Childhood and Adolescence for Detection of Familial Hypercholesterolemia: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 141. AHRQ Publication No. 14-05204-EF-2. Rockville (MD): Agency for Healthcare Research and Quality; 2016.
3 Lozano P, Henrikson NB, Morrison CC, . Lipid Screening in Childhood for Detection of Multifactorial Dyslipidemia: A Systematic Evidence Review for the U.S. Preventive Services Task Force. Evidence Synthesis No. 140. AHRQ Publication No14-05204-EF-1. Rockville (MD): Agency for Healthcare Research and Quality; 2016.
4 de Ferranti SD, Steinberger J, Ameduri R, . Cardiovascular Risk Reduction in High-Risk Pediatric Patients: A Scientific Statement From the American Heart Association. Circulation. 2019;139(13):e603–e34. PMID: 30798614. 10.1161/CIR.0000000000000618 30798614
5 Fahed AC, Nemer GM. Familial hypercholesterolemia: the lipids or the genes? Nutr Metab (Lond). 2011;8(1):23. PMID: 21513517. 10.1186/1743-7075-8-23 21513517
6 Zech LA, Jr., Hoeg JM. Correlating corneal arcus with atherosclerosis in familial hypercholesterolemia. Lipids health dis. 2008;7:7. PMID: 18331643. 10.1186/1476-511X-7-7 18331643
7 Hovingh GK, Davidson MH, Kastelein JJ, . Diagnosis and treatment of familial hypercholesterolaemia. Eur Heart J. 2013;34(13):962–71. PMID: 23416791. 10.1093/eurheartj/eht015 23416791
8 Brown EE, Sturm AC, Cuchel M, . Genetic testing in dyslipidemia: A scientific statement from the National Lipid Association. J Clin Lipidol. 2020;14(4):398–413. PMID: 32507592. 10.1016/j.jacl.2020.04.011 32507592
9 Benito-Vicente A, Uribe KB, Jebari S, . Familial Hypercholesterolemia: The Most Frequent Cholesterol Metabolism Disorder Caused Disease. Int J Mol Sci. 2018;19(11). PMID: 30388787. 10.3390/ijms19113426 30388787
10 Damgaard D, Larsen ML, Nissen PH, . The relationship of molecular genetic to clinical diagnosis of familial hypercholesterolemia in a Danish population. Atherosclerosis. 2005;180(1):155–60. PMID: 15823288. 10.1016/j.atherosclerosis.2004.12.001 15823288
11 Khera AV, Won HH, Peloso GM, . Diagnostic Yield and Clinical Utility of Sequencing Familial Hypercholesterolemia Genes in Patients With Severe Hypercholesterolemia. J Am Coll Cardiol. 2016;67(22):2578–89. PMID: 27050191. 10.1016/j.jacc.2016.03.520 27050191
12 Huijgen R, Kindt I, Defesche JC, . Cardiovascular risk in relation to functionality of sequence variants in the gene coding for the low-density lipoprotein receptor: a study among 29,365 individuals tested for 64 specific low-density lipoprotein-receptor sequence variants. Eur Heart J. 2012;33(18):2325–30. PMID: 22390909. 10.1093/eurheartj/ehs038 22390909
13 Leren TP, Finborud TH, Manshaus TE, . Diagnosis of familial hypercholesterolemia in general practice using clinical diagnostic criteria or genetic testing as part of cascade genetic screening. Community Genet. 2008;11(1):26–35. PMID: 18196915. 10.1159/000111637 18196915
14 Huijgen R, Kindt I, Verhoeven SB, . Two years after molecular diagnosis of familial hypercholesterolemia: majority on cholesterol-lowering treatment but a minority reaches treatment goal. PLoS ONE. 2010;5(2):e9220. PMID: 20169164. 10.1371/journal.pone.0009220 20169164
15 Forrest IS, Chaudhary K, Vy HMT, . Population-Based Penetrance of Deleterious Clinical Variants. JAMA. 2022;25(4):350–9. PMID: 35076666. 10.1001/jama.2021.23686 35076666
16 Khera AV, Hegele RA. What Is Familial Hypercholesterolemia, and Why Does It Matter? Population-Based Penetrance of Deleterious Clinical Variants. Circulation 2020. p. 1760–3. PMID: 32479201. 10.1161/CIRCULATIONAHA.120.046961 32479201
17 Brunham LR, Ruel I, Khoury E, . Familial hypercholesterolemia in Canada: Initial results from the FH Canada national registry. Atherosclerosis. 2018;277:419–24. PMID: 30270080. 10.1016/j.atherosclerosis.2018.05.040 30270080
18 Williams RR, Hunt SC, Schumacher MC, . Diagnosing heterozygous familial hypercholesterolemia using new practical criteria validated by molecular genetics. Am J Cardiol. 1993;72(2):171–6. PMID: 8328379. 10.1016/0002-9149(93)90155-6 8328379
19 Risk of fatal coronary heart disease in familial hypercholesterolaemia. Scientific Steering Committee on behalf of the Simon Broome Register Group. Bmj. 1991;303(6807):893–6. PMID: 1933004. 10.1136/bmj.303.6807.893 1933004
20 Civeira F, International Panel on Management of Familial H. Guidelines for the diagnosis and management of heterozygous familial hypercholesterolemia. Atherosclerosis. 2004;173(1):55–68. PMID: 15177124. 10.1016/j.atherosclerosis.2003.11.010 15177124
21 de Ferranti S, Newburger J. Dyslipidemia in children: Definition, screening, and diagnosis. https://www.uptodate.com/contents/dyslipidemia-in-children-definition-screening-and-diagnosis?csi=cb86ef0a-98c2-44ad-a6f4-5cd5d5901ae4&source=contentShare. Accessed: Jan 22, 2021.
22 Gidding SS, Barton BA, Dorgan JA, . Higher self-reported physical activity is associated with lower systolic blood pressure: the Dietary Intervention Study in Childhood (DISC). Pediatrics. 2006;118(6):2388–93. PMID: 17142523. 10.1542/peds.2006-1785 17142523
23 Wong ND, Hei TK, Qaqundah PY, . Television viewing and pediatric hypercholesterolemia. Pediatrics. 1992;90(1 Pt 1):75–9. PMID: 1614784.1614784
24 Barker AR, Gracia-Marco L, Ruiz JR, . Physical activity, sedentary time, TV viewing, physical fitness and cardiovascular disease risk in adolescents: The HELENA study. Int J Cardiol. 2018;254:303–9. PMID: 29221862. 10.1016/j.ijcard.2017.11.080 29221862
25 Martinez-Gomez D, Rey-Lopez JP, Chillon P, . Excessive TV viewing and cardiovascular disease risk factors in adolescents. The AVENA cross-sectional study. BMC Public Health. 2010;10:274. PMID: 20500845. 10.1186/1471-2458-10-274 20500845
26 Parks EJ, Hellerstein MK. Carbohydrate-induced hypertriacylglycerolemia: historical perspective and review of biological mechanisms. The American Journal of Clinical Nutrition. 2000;71(2):412–33. PMID: 10648253. 10.1093/ajcn/71.2.412 10648253
27 Jarauta E, Bea-Sanz AM, Marco-Benedi V, . Genetics of Hypercholesterolemia: Comparison Between Familial Hypercholesterolemia and Hypercholesterolemia Nonrelated to LDL Receptor. Front Genet. 2020;11:554931. PMID: 33343620. 10.3389/fgene.2020.554931 33343620
28 Tamir I, Heiss G, Glueck CJ, . Lipid and lipoprotein distributions in white children ages 6-19 yr. The Lipid Research Clinics Program Prevalence Study. J Chronic Dis. 1981;34(1):27–39. PMID: 7451637. 10.1016/0021-9681(81)90079-5 7451637
29 National Cholesterol Education Program (NCEP): highlights of the report of the Expert Panel on Blood Cholesterol Levels in Children and Adolescents. Pediatrics. 1992;89(3):495–501. PMID: 1741227.1741227
30 National Heart Lung and Blood Institute. Expert Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents. Bethesda, MD: US Department of Health and Human Services, National Institutes of Health; 2012.
31 Grundy SM, Stone NJ, Bailey AL, . 2018 AHA/ACC/AACVPR/AAPA/ABC/ACPM/ADA/AGS/APhA/ASPC/NLA/PCNA Guideline on the Management of Blood Cholesterol: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Circulation. 2019;139(25):e1082–e143. PMID: 30586774. 10.1161/cir.0000000000000625 30586774
32 Lozano P, Henrikson NB, Morrison CC, . Lipid Screening in Childhood and Adolescence for Detection of Multifactorial Dyslipidemia: Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2016;316(6):634–44. PMID: 27532918. 10.1001/jama.2016.6423 27532918
33 Hu P, Dharmayat KI, Stevens CAT, . Prevalence of Familial Hypercholesterolemia Among the General Population and Patients With Atherosclerotic Cardiovascular Disease: A Systematic Review and Meta-Analysis. Circulation. 2020;141(22):1742–59. PMID: 32468833. 10.1161/CIRCULATIONAHA.119.044795 32468833
34 Akioyamen LE, Genest J, Shan SD, . Estimating the prevalence of heterozygous familial hypercholesterolaemia: a systematic review and meta-analysis. BMJ Open. 2017;7(9):e016461. PMID: 28864697. 10.1136/bmjopen-2017-016461 28864697
35 Neil HA, Hammond T, Huxley R, . Extent of underdiagnosis of familial hypercholesterolaemia in routine practice: prospective registry study. BMJ. 2000;321(7254):148. PMID: 10894692. 10.1136/bmj.321.7254.148 10894692
36 Toft-Nielsen F, Emanuelsson F, Benn M. Familial Hypercholesterolemia Prevalence Among Ethnicities-Systematic Review and Meta-Analysis. Front Genet 2022. PMID: 35186049. 10.3389/fgene.2022.840797 35186049
37 World Health Organization. The Global Health Observatory: Raised cholesterol. https://www.who.int/data/gho/indicator-metadata-registry/imr-details/3236. Accessed: May 3, 2022.
38 Mohamed-Yassin MS, Baharudin N, Abdul-Razak S, . Global prevalence of dyslipidaemia in adult populations: a systematic review protocol. BMJ Open. 2021;11(12):e049662. PMID: 34862282. 10.1136/bmjopen-2021-049662 34862282
39 G. B. D. Risk Factor Collaborators. Global, regional, and national comparative risk assessment of 84 behavioural, environmental and occupational, and metabolic risks or clusters of risks for 195 countries and territories, 1990-2017: a systematic analysis for the Global Burden of Disease Study 2017. Lancet. 2018;392(10159):1923–94. PMID: 30496105. 10.1016/S0140-6736(18)32225-6 30496105
40 Kusters DM, Wiegman A, Kastelein JJ, . Carotid intima-media thickness in children with familial hypercholesterolemia. Circ Res. 2014;114(2):307–10. PMID: 24192652. 10.1161/CIRCRESAHA.114.301430 24192652
41 Wiegman A, de Groot E, Hutten BA, . Arterial intima-media thickness in children heterozygous for familial hypercholesterolaemia. Lancet. 2004;363(9406):369–70. PMID: 15070569. 10.1016/S0140-6736(04)15467-6 15070569
42 Perak AM, Ning H, de Ferranti SD, . Long-Term Risk of Atherosclerotic Cardiovascular Disease in US Adults With the Familial Hypercholesterolemia Phenotype. Circulation. 2016;134(1):9–19. PMID: 27358432. 10.1161/CIRCULATIONAHA.116.022335 27358432
43 Versmissen J, Oosterveer DM, Yazdanpanah M, . Efficacy of statins in familial hypercholesterolaemia: a long term cohort study. Bmj. 2008;337:a2423. PMID: 19001495. 10.1136/bmj.a2423 19001495
44 Scientific Steering Committee on behalf of the Simon Broome Register Group. Mortality in treated heterozygous familial hypercholesterolaemia: implications for clinical management. Atherosclerosis. 1999;142(1):105–12. PMID: 9920511.9920511
45 Prospective Studies Collaboration, Lewington S, Whitlock G, . Blood cholesterol and vascular mortality by age, sex, and blood pressure: a meta-analysis of individual data from 61 prospective studies with 55,000 vascular deaths. Lancet. 2007;370(9602):1829–39. PMID: 18061058. 10.1016/S0140-6736(07)61778-4 18061058
46 U. S. Preventive Services Task Force, Davidson KW, Barry MJ, . Aspirin Use to Prevent Cardiovascular Disease: US Preventive Services Task Force Recommendation Statement. JAMA. 2022;327(16):1577–84. PMID: 35471505. 10.1001/jama.2022.4983 35471505
47 Arnett DK, Blumenthal RS, Albert MA, . 2019 ACC/AHA Guideline on the Primary Prevention of Cardiovascular Disease: Executive Summary: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Circulation. 2019;140(11):e563–e95. PMID: 30879339. 10.1161/CIR.0000000000000677 30879339
48 U. S. Preventive Services Task Force. Statin Use for the Primary Prevention of Cardiovascular Disease in Adults. Update in progress. https://www.uspreventiveservicestaskforce.org/uspstf/draft-update-summary/statin-use-primary-prevention-cardiovascular-disease-adults. Accessed: May 3, 2022.
49 Jacobs DR, Jr., Woo JG, Sinaiko AR, . Childhood Cardiovascular Risk Factors and Adult Cardiovascular Events. N Engl J Med. 2022. PMID: 35373933. 10.1056/NEJMoa2109191 35373933
50 Ice CL, Murphy E, Cottrell L, . Morbidly obese diagnosis as an indicator of cardiovascular disease risk in children: results from the CARDIAC Project. Int J Pediatr Obes. 2011;6(2):113–9. PMID: 20545480. 10.3109/17477161003792556 20545480
51 Raman A, Sharma S, Fitch MD, . Anthropometric correlates of lipoprotein profile and blood pressure in high BMI African American children. Acta Paediatr. 2010;99(6):912–9. PMID: 20064141. 10.1111/j.1651-2227.2009.01639.x 20064141
52 Perak AM, Ning H, Kit BK, . Trends in Levels of Lipids and Apolipoprotein B in US Youths Aged 6 to 19 Years, 1999-2016. JAMA. 2019;321(19):1895–905. PMID: 31112258. 10.1001/jama.2019.4984 31112258
53 Oliosa PR, Zaniqueli DDA, Barbosa MCR, . Relationship between body composition and dyslipidemia in children and adolescentes. Cien Saude Colet. 2019;24(10):3743–52. PMID: 31577005. 10.1590/1413-812320182410.17662017 31577005
54 Oliosa PR, Zaniqueli D, Alvim RO, . Body fat percentage is better than indicators of weight status to identify children and adolescents with unfavorable lipid profile. J Pediatr (Rio J). 2019;95(1):112–8. PMID: 29306717. 10.1016/j.jped.2017.11.003 29306717
55 Interator H, Lebenthal Y, Hoshen M, . Distinct Lipoprotein Curves in Normal Weight, Overweight, and Obese Children and Adolescents. J Pediatr Gastroenterol Nutr. 2017;65(6):673–80. PMID: 28691976. 10.1097/MPG.0000000000001674 28691976
56 Norris AL, Steinberger J, Steffen LM, . Circulating oxidized LDL and inflammation in extreme pediatric obesity. Obesity (Silver Spring). 2011;19(7):1415–9. PMID: 21331062. 10.1038/oby.2011.21 21331062
57 Zachariah JP, Shittu T, Wang Y. Lipid temporal trends in normal-weight youth. Am Heart J. 2021;231(1097-6744 (Electronic)):68–72. PMID: 33096104. 10.1016/j.ahj.2020.10.050 33096104
58 Bao W, Srinivasan SR, Valdez R, . Longitudinal changes in cardiovascular risk from childhood to young adulthood in offspring of parents with coronary artery disease: the Bogalusa Heart Study. JAMA. 1997;278(21):1749–54. PMID: 9388151.9388151
59 Stone NJ, Levy RI, Fredrickson DS, . Coronary artery disease in 116 kindred with familial type II hyperlipoproteinemia. Circulation. 1974;49(3):476–88. PMID: 4813182. 10.1161/01.cir.49.3.476 4813182
60 Daniels SR. On the US Preventive Services Task Force Statement on Screening for Lipid Disorders in Children and Adolescents: One Step Forward and 2 Steps Sideways. JAMA Pediatr. 2016;170(10):932–4. PMID: 27533098. 10.1001/jamapediatrics.2016.2315 27533098
61 Nordestgaard BG, Chapman MJ, Humphries SE, . Familial hypercholesterolaemia is underdiagnosed and undertreated in the general population: guidance for clinicians to prevent coronary heart disease: consensus statement of the European Atherosclerosis Society. Eur Heart J. 2013;34(45):3478–90a. PMID: 23956253. 10.1093/eurheartj/eht273 23956253
62 deGoma EM, Ahmad ZS, O’Brien EC, . Treatment Gaps in Adults With Heterozygous Familial Hypercholesterolemia in the United States: Data From the CASCADE-FH Registry. Circ Cardiovasc Genet. 2016;9(3):240–9. PMID: 27013694. 10.1161/CIRCGENETICS.116.001381 27013694
63 Bright Futures, American Adademy of Pediatrics. Recommendations for Preventive Pediatric Health Care. https://downloads.aap.org/AAP/PDF/periodicity_schedule.pdf. Accessed: 4/25/2022.
64 Louter L, Defesche J, Roeters van Lennep J. Cascade screening for familial hypercholesterolemia: Practical consequences. Atheroscler Suppl. 2017;30:77–85. PMID: 29096865. 10.1016/j.atherosclerosissup.2017.05.019 29096865
65 Groselj U, Kovac J, Sustar U, . Universal screening for familial hypercholesterolemia in children: The Slovenian model and literature review. Atherosclerosis. 2018;277:383–91. PMID: 30270075. 10.1016/j.atherosclerosis.2018.06.858 30270075
66 Myers KD, Knowles JW, Staszak D, . Precision screening for familial hypercholesterolaemia: a machine learning study applied to electronic health encounter data. Lancet Digit Health. 2019;8:e393–e402. PMID: 33323221. 10.1016/S2589-7500(19)30150-5 33323221
67 McGowan MP, Cuchel M, Ahmed CD, . A proof-of-concept study of cascade screening for Familial Hypercholesterolemia in the US, adapted from the Dutch model. Am J Prev Cardiol. 2021;6(100170). PMID: 34327496. 10.1016/j.ajpc.2021.100170 34327496
68 Murabito JM, Nam BH, D’Agostino RB, Sr., . Accuracy of offspring reports of parental cardiovascular disease history: the Framingham Offspring Study. Ann Intern Med. 2004;140(6):434–40. PMID: 15023709. 10.7326/0003-4819-140-6-200403160-00010 15023709
69 Ritchie SK, Murphy EC, Ice C, . Universal versus targeted blood cholesterol screening among youth: The CARDIAC project. Pediatrics. 2010;126(2):260–5. PMID: 20624798. 10.1542/peds.2009-2546 20624798
70 de Ferranti SD, Rodday AM, Mendelson MM, . Prevalence of Familial Hypercholesterolemia in the 1999 to 2012 United States National Health and Nutrition Examination Surveys (NHANES). Circulation. 2016;133(11):1067–72. PMID: 26976914. 10.1161/CIRCULATIONAHA.115.018791 26976914
71 Cottrell L, John C, Murphy E, . Individual-, family-, community-, and policy-level impact of a school-based cardiovascular risk detection screening program for children in underserved, rural areas: the CARDIAC Project. J Obes. 2013;2013:732579.(doi):10.1155/2013/732579. Epub 2013 Jun 5. PMID: 23840946. 10.1155/2013/732579 23840946
72 Wald DS, Bestwick JP, Wald NJ. Child-Parent Familial Hypercholesterolemia Screening in Primary Care [Author Reply to editorials]. N Engl J Med. 2017;376(5):499–500. PMID: 28146661. 10.1056/NEJMc1615365 28146661
73 Frontini MG, Srinivasan SR, Xu J, . Usefulness of childhood non-high density lipoprotein cholesterol levels versus other lipoprotein measures in predicting adult subclinical atherosclerosis: the Bogalusa Heart Study. Pediatrics. 2008;121(5):924–9. PMID: 18450895. 10.1542/peds.2007-1472 18450895
74 Brunner FJ, Waldeyer C, Ojeda F, . Application of non-HDL cholesterol for population-based cardiovascular risk stratification: results from the Multinational Cardiovascular Risk Consortium. Lancet. 2019;394(10215):2173–83. PMID: 31810609. 10.1016/S0140-6736(19)32519-X 31810609
75 Goff DC, Jr., Lloyd-Jones DM, Bennett G, . 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2935–59. PMID: 24239921. 10.1016/j.jacc.2013.11.005 24239921
76 Nordestgaard BG, Langsted A, Mora S, . Fasting Is Not Routinely Required for Determination of a Lipid Profile: Clinical and Laboratory Implications Including Flagging at Desirable Concentration Cutpoints-A Joint Consensus Statement from the European Atherosclerosis Society and European Federation of Clinical Chemistry and Laboratory Medicine. Clin Chem. 2016;62(7):930–46. PMID: 27235445. 10.1373/clinchem.2016.258897 27235445
77 Friedewald WT, Levy RI, Fredrickson DS. Estimation of the concentration of low-density lipoprotein cholesterol in plasma, without use of the preparative ultracentrifuge. Clin Chem. 1972;18(6):499–502. PMID: 4337382.4337382
78 Sampson M, Ling C, Sun Q, . A New Equation for Calculation of Low-Density Lipoprotein Cholesterol in Patients With Normolipidemia and/or Hypertriglyceridemia. JAMA Cardiol. 2020;5(5):540–8. PMID: 32101259. 10.1001/jamacardio.2020.0013 32101259
79 Steiner MJ, Skinner AC, Perrin EM. Fasting might not be necessary before lipid screening: a nationally representative cross-sectional study. Pediatrics. 2011;128(3):463–70. PMID: 21807697. 10.1542/peds.2011-0844 21807697
80 Browne B, Vasquez S. Pediatric dyslipidemias: Prescription medication efficacy and safety. J Clin Lipidol. 2008;2(3):189–201. PMID: 21291737. 10.1016/j.jacl.2008.04.008 21291737
81 Eiland LS, Luttrell PK. Use of statins for dyslipidemia in the pediatric population. J Pediatr Pharmacol Ther. 2010;15(3):160–72. PMID: 22477808.22477808
82 Miller ML, Wright CC, Rodriguez B. Use of Lipid Lowering Medications in Youth. In: Feingold KR, Anawalt B, Boyce A, Chrousos G, de Herder WW, Dhatariya K, ., editors. Endotext. South Dartmouth (MA) 2000.
83 AMGEN. FDA Approves Repatha® (evolocumab) In Pediatric Patients Age 10 And Older With Heterozygous Familial Hypercholesterolemia. Approval Based on HAUSER-RCT Study Demonstrating a Significant Reduction in LDL-C. Thousand Oaks, CA: Amgen; 2021.
84 de Ferranti SD, Rodday AM, Parsons SK, . Cholesterol Screening and Treatment Practices and Preferences: A Survey of United States Pediatricians. J Pediatr. 2017;185:99–105.e2.(doi):10.1016/j.jpeds.2016.12.078. Epub 7 Feb 13. PMID: 28209292. 10.1016/j.jpeds.2016.12.078 28209292
85 Mihalopoulos NL, Stipelman C, Hemond J, . Universal Lipid Screening in 9- to 11-Year-Olds Before and After 2011 Guidelines. Acad Pediatr. 2018;18(2):196–9. PMID: 29180296. 10.1016/j.acap.2017.11.006 29180296
86 Allen-Tice C, Steinberger J, Murdy K, . Pediatric cholesterol screening practices in 9- to 11-year-olds in a large midwestern primary care setting. J. 2020;14(2):224–30. PMID: 32111582. 10.1016/j.jacl.2020.01.013 32111582
87 Herrington L, Susi A, Gorman G, . Factors Affecting Pediatric Dyslipidemia Screening and Treatment. Clin Pediatr (Phila). 2019;58(5):502–10. PMID: 30793626. 10.1177/0009922819832068 30793626
88 Sriram S, St Sauver JL, Jacobson DJ, . Temporal trends in lipid testing among children and adolescents: A population based study. Prev Med Rep. 2017;8:267–72. PMID: 29204335. 10.1016/j.pmedr.2017.11.001 29204335
89 Margolis KL, Greenspan LC, Trower NK, . Lipid screening in children and adolescents in community practice: 2007 to 2010. Circ Cardiovasc Qual Outcomes. 2014;7(5):718–26. PMID: 25160839. 10.1161/CIRCOUTCOMES.114.000842 25160839
90 de Ferranti SD, Shrader P, Linton MF, . Children with Heterozygous Familial Hypercholesterolemia in the United States: Data from the Cascade Screening for Awareness and Detection-FH Registry. Journal of Pediatrics. 2021;229:70–7. PMID: 32976895. 10.1016/j.jpeds.2020.09.042 32976895
91 U.S. Preventive Services Task Force. Screening for Lipid Disorders in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. https://www.uspreventiveservicestaskforce.org/uspstf/recommendation/lipid-disorders-in-children-screening-2007. Accessed: Jan 22, 2021.
92 U. S. Preventive Services Task Force, Grossman DC, Bibbins-Domingo K, . Screening for Obesity in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2017;317(23):2417–26. PMID: 28632874. 10.1001/jama.2017.6803 28632874
93 Krist AH, Davidson KW, Mangione CM, . Screening for High Blood Pressure in Children and Adolescents: US Preventive Services Task Force Recommendation Statement. JAMA. 2020;324(18):1878–83. PMID: 33170248. 10.1001/jama.2020.20122 33170248
94 US Preventive Services Task Force. US Preventive Services Task Force. Statin Use for the Primary Prevention of Cardiovascular Disease in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2022;328(8):746–53. PMID: 35997723. 10.1001/jama.2022.13044 35997723
95 Chou R, Dana T, Blazina I, . Screening for Dyslipidemia in Younger Adults: A Systematic Review for the U.S. Preventive Services Task Force. Ann Intern Med. 2016;165(8):560–4. PMID: 27538032. 10.7326/M16-0946 27538032
96 Liu J, Ma J, Orekoya O, . Trends in Metabolic Syndrome Among US Youth, From 1999 to 2018. JAMA Pediatr. 2022;176(10):1043–45. PMID: 35816325. 10.1001/jamapediatrics.2022.1850 35816325
97 United Nations Development Programme. Human Development Report 2020. The next fronteir: Human development and the Antropocene. New York, NY: United Nations Development Programme; 2020.
98 Lee C, Rivera-Valerio M, Bangash H, . New Case Detection by Cascade Testing in Familial Hypercholesterolemia: A Systematic Review of the Literature. Circ Genom Precis Med. 2019;12(11):e002723. PMID: 31638829. 10.1161/circgen.119.002723 31638829
99 Reeves B, Deeks J, Higgins J, . Chapter 24: Including non-randomized studies on intervention effects. In: Higgins JPT, Thomas J, Chandler J, Cumpston M, Li T, Page MJ, Welch VA (editors). Cochrane Handbook for Systematic Reviews of Interventions version 6.3 (updated February 2022). https://training.cochrane.org/handbook/current/chapter-24. Accessed.
100 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville (MD): Agency for Healthcare Research and Quality (US); 2021.
101 Sterne JA, Hernan MA, Reeves BC, . ROBINS-I: a tool for assessing risk of bias in non-randomised studies of interventions. Bmj. 2016;355:i4919. PMID: 27733354. 10.1136/bmj.i4919 27733354
102 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. 2003;22(17):2693–710. PMID: 12939780. 10.1002/sim.1482 12939780
103 Veroniki AA, Jackson D, Bender R, . Methods to calculate uncertainty in the estimated overall effect size from a random-effects meta-analysis. Res Synth Methods. 2019;10(1):23–43. PMID: 30129707. 10.1002/jrsm.1319 30129707
104 Terrin N, Schmid CH, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. 2005/08/09 ed2005. p. 894–901. PMID: 16085192. 10.1016/j.jclinepi.2005.01.006 16085192
105 Sterne JA, Sutton AJ, Ioannidis JP, . Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. Bmj. 2011;343:d4002. PMID: 21784880. 10.1136/bmj.d4002 21784880
106 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015;68(11):1312–24. PMID: 25721570. 10.1016/j.jclinepi.2014.11.023 25721570
107 Atkins D, Best D, Briss PA, . Grading quality of evidence and strength of recommendations. Bmj. 2004;328(7454):1490. PMID: 15205295. 10.1136/bmj.328.7454.1490 15205295
108 Jackson CL, Keeton JZ, Eason SJ, . Identifying Familial Hypercholesterolemia Using a Blood Donor Screening Program With More Than 1 Million Volunteer Donors. JAMA Cardiol. 2019;4(7):685–9. PMID: 31116347. 10.1001/jamacardio.2019.1518 31116347
109 Elliott E, Lilly C, Murphy E, . The Coronary Artery Risk Detection in Appalachian Communities (CARDIAC) Project: An 18 Year Review. Curr Pediatr Rev. 2017;13(4):265–76. PMID: 29345596. 10.2174/1573400514666180117093652 29345596
110 Bauer KW, Marcus MD, El ghormli L, . Cardio-metabolic risk screening among adolescents: understanding the utility of body mass index, waist circumference and waist to height ratio. Pediatr Obes. 2015;10(5):329–37. PMID: 25515620. 10.1111/ijpo.267 25515620
111 CARDIAC project. Summary of Results from 1998 to Present: Coronary Artery Risk Detection in Appalachian Communities 21 Year Summary - Fifth Grade 1998-2020. 2020. Accessed 6/20/2022 from https://www.cardiacwv.org/?pid=10
112 Nelson TL, Puccetti N, Luckasen GJ. Healthy hearts: a cross-sectional study of clinical cardiovascular disease risk factors in Northern Colorado school children (1992-2013). BMC Obes. 2015;2:48. PMID: 26664730. 10.1186/s40608-015-0078-9 26664730
113 Nguyen D, Kit B, Carroll M. Abnormal Cholesterol Among Children and Adolescents in the United States, 2011-2014. NCHS data brief. 2015(228):1–8. PMID: 26727279.26727279
114 Reina SA, Llabre MM, Vidot DC, . Metabolic Syndrome in Hispanic Youth: Results from the Hispanic Community Children’s Health Study/Study of Latino Youth. Metab. 2017;15(8):400–6. PMID: 28829223. 10.1089/met.2017.0054 28829223
115 Braamskamp MJ, Stefanutti C, Langslet G, . Efficacy and Safety of Pitavastatin in Children and Adolescents at High Future Cardiovascular Risk. J Pediatr. 2015;167(2):338–43 e5. PMID: 26059337. 10.1016/j.jpeds.2015.05.006 26059337
116 Knipscheer HC, Boelen CC, Kastelein JJ, . Short-term efficacy and safety of pravastatin in 72 children with familial hypercholesterolemia. Pediatr Res. 1996;39(5):867–71. PMID: 8726243. 10.1203/00006450-199605000-00021 8726243
117 Stein EA, Illingworth DR, Kwiterovich PO, Jr., . Efficacy and safety of lovastatin in adolescent males with heterozygous familial hypercholesterolemia: a randomized controlled trial. JAMA. 1999;281(2):137–44. PMID: 9917116. 10.1001/jama.281.2.137 9917116
118 McCrindle BW, Ose L, Marais AD. Efficacy and safety of atorvastatin in children and adolescents with familial hypercholesterolemia or severe hyperlipidemia: a multicenter, randomized, placebo-controlled trial. J Pediatr. 2003;143(1):74–80. PMID: 12915827. 10.1016/S0022-3476(03)00186-0 12915827
119 Avis HJ, Hutten BA, Gagné C, . Efficacy and safety of rosuvastatin therapy for children with familial hypercholesterolemia. J Am Coll Cardiol 2010. p. 1121–6. PMID: 20223367. 10.1016/j.jacc.2009.10.042 20223367
120 Couture P, Brun LD, Szots F, . Association of specific LDL receptor gene mutations with differential plasma lipoprotein response to simvastatin in young French Canadians with heterozygous familial hypercholesterolemia. Arterioscler Thromb Vasc Biol. 1998;18(6):1007–12. PMID: 9633944. 10.1161/01.atv.18.6.1007 9633944
121 de Jongh S, Ose L, Szamosi T, . Efficacy and safety of statin therapy in children with familial hypercholesterolemia: a randomized, double-blind, placebo-controlled trial with simvastatin. Circulation. 2002;106(17):2231–7. PMID: 12390953. 10.1161/01.cir.0000035247.42888.82 12390953
122 de Jongh S, Lilien MR, op’t Roodt J, . Early statin therapy restores endothelial function in children with familial hypercholesterolemia. J Am Coll Cardiol. 2002;40(12):2117–21. PMID: 12505222. 10.1016/s0735-1097(02)02593-7 12505222
123 Wiegman A, Hutten BA, de Groot E, . Efficacy and safety of statin therapy in children with familial hypercholesterolemia: a randomized controlled trial. JAMA. 2004;292(3):331–7. PMID: 15265847. 10.1001/jama.292.3.331 15265847
124 Clauss SB, Holmes KW, Hopkins P, . Efficacy and safety of lovastatin therapy in adolescent girls with heterozygous familial hypercholesterolemia. Pediatrics. 2005;116(3):682–8. PMID: 16140708. 10.1542/peds.2004-2090 16140708
125 Stein EA, Marais AD, Szamosi T, . Colesevelam hydrochloride: efficacy and safety in pediatric subjects with heterozygous familial hypercholesterolemia. J Pediatr. 2010;156(2):231–6. PMID: 19879596. 10.1016/j.jpeds.2009.08.037 19879596
126 Tonstad S, Knudtzon J, Sivertsen M, . Efficacy and safety of cholestyramine therapy in peripubertal and prepubertal children with familial hypercholesterolemia. J Pediatr. 1996;129(1):42–9. PMID: 8757561. 10.1016/s0022-3476(96)70188-9 8757561
127 Tonstad S, Sivertsen M, Aksnes L, . Low dose colestipol in adolescents with familial hypercholesterolaemia. Arch Dis Child. 1996;74(2):157–60. PMID: 8660081. 10.1136/adc.74.2.157 8660081
128 Kusters DM, Caceres M, Coll M, . Efficacy and safety of ezetimibe monotherapy in children with heterozygous familial or nonfamilial hypercholesterolemia. J Pediatr. 2015;166(6):1377–84. PMID: 25841542. 10.1016/j.jpeds.2015.02.043 25841542
129 Wheeler KA, West RJ, Lloyd JK, . Double blind trial of bezafibrate in familial hypercholesterolaemia. Arch Dis Child. 1985;60(1):34–7. PMID: 3882058. 10.1136/adc.60.1.34 3882058
130 Santos RD, Ruzza A, Hovingh GK, . Evolocumab in Pediatric Heterozygous Familial Hypercholesterolemia. New England Journal of Medicine. 2020;383(14):1317–27. PMID: 32865373. 10.1056/NEJMoa2019910 32865373
131 van der Graaf A, Cuffie-Jackson C, Vissers MN, . Efficacy and safety of coadministration of ezetimibe and simvastatin in adolescents with heterozygous familial hypercholesterolemia. J Am Coll Cardiol. 2008;52(17):1421–9. PMID: 18940534. 10.1016/j.jacc.2008.09.002 18940534
132 Kinnear FJ, Lithander FE, Searle A, . Reducing cardiovascular disease risk among families with familial hypercholesterolaemia by improving diet and physical activity: a randomised controlled feasibility trial. BMJ Open. 2020;10(12):e044200. PMID: 33372081. 10.1136/bmjopen-2020-044200 33372081
133 de Jongh S, Vissers MN, Rol P, . Plant sterols lower LDL cholesterol without improving endothelial function in prepubertal children with familial hypercholesterolaemia. J Inherit Metab Dis. 2003;26(4):343–51. PMID: 12971422. 10.1023/a:1025155002348 12971422
134 Gylling H, Siimes MA, Miettinen TA. Sitostanol ester margarine in dietary treatment of children with familial hypercholesterolemia. J Lipid Res. 1995;36(8):1807–12. PMID: 7595101. 10.1016/S0022-2275(20)41499-3 7595101
135 Amundsen AL, Ose L, Nenseter MS, . Plant sterol ester-enriched spread lowers plasma total and LDL cholesterol in children with familial hypercholesterolemia. Am J Clin Nutr. 2002;76(2):338–44. PMID: 12145004. 10.1093/ajcn/76.2.338 12145004
136 Engler MM, Engler MB, Malloy MJ, . Effect of docosahexaenoic acid on lipoprotein subclasses in hyperlipidemic children (the EARLY study). Am J Cardiol. 2005;95(7):869–71. PMID: 15781019. 10.1016/j.amjcard.2004.12.014 15781019
137 Shannon BM, Tershakovec AM, Martel JK, . Reduction of elevated LDL-cholesterol levels of 4- to 10-year-old children through home-based dietary education. Pediatrics. 1994;94(6 Pt 1):923–7. PMID: 7971012.7971012
138 The Writing Group for the DISC Collaborative Research Group. Efficacy and safety of lowering dietary intake of fat and cholesterol in children with elevated low-density lipoprotein cholesterol. The Dietary Intervention Study in Children (DISC). JAMA. 1995;273(18):1429–35. PMID: 7723156. 10.1001/jama.1995.03520420045036 7723156
139 Wong H, Chahal N, Manlhiot C, . Flaxseed in pediatric hyperlipidemia: a placebo-controlled, blinded, randomized clinical trial of dietary flaxseed supplementation for children and adolescents with hypercholesterolemia. JAMA Pediatr. 2013;167(8):708–13. PMID: 23733031. 10.1001/jamapediatrics.2013.1442 23733031
140 Gidding SS, Prospero C, Hossain J, . A double-blind randomized trial of fish oil to lower triglycerides and improve cardiometabolic risk in adolescents. J Pediatr. 2014;165(3):497–503.e2. PMID: 25008950. 10.1016/j.jpeds.2014.05.039 25008950
141 Guardamagna O, Abello F, Cagliero P, . Could dyslipidemic children benefit from glucomannan intake? Nutrition. 2013;29(7–8):1060–5. PMID: 23759268. 10.1016/j.nut.2013.02.010 23759268
142 Del Bo C, Deon V, Abello F, . Eight-week hempseed oil intervention improves the fatty acid composition of erythrocyte phospholipids and the omega-3 index, but does not affect the lipid profile in children and adolescents with primary hyperlipidemia. Food res. 2019;119:469–76. PMID: 30884679. 10.1016/j.foodres.2018.12.045 30884679
143 Deon V, Del Bo C, Guaraldi F, . Effect of hazelnut on serum lipid profile and fatty acid composition of erythrocyte phospholipids in children and adolescents with primary hyperlipidemia: A randomized controlled trial. Clin Nutr. 2018;37(4):1193–201. PMID: 28606702. 10.1016/j.clnu.2017.05.022 28606702
144 Dennison BA, Levine DM. Randomized, double-blind, placebo-controlled, two-period crossover clinical trial of psyllium fiber in children with hypercholesterolemia. J Pediatr. 1993;123(1):24–9. PMID: 8391569. 10.1016/s0022-3476(05)81532-x 8391569
145 Guardamagna O, Amaretti A, Puddu PE, . Bifidobacteria supplementation: effects on plasma lipid profiles in dyslipidemic children. Nutrition. 2014;30(7–8):831–6. PMID: 24985000. 10.1016/j.nut.2014.01.014 24985000
146 Martino F, Martino E, Morrone F, . Effect of dietary supplementation with glucomannan on plasma total cholesterol and low density lipoprotein cholesterol in hypercholesterolemic children. Nutr Metab Cardiovasc Dis. 2005;15(3):174–80. PMID: 15955465. 10.1016/j.numecd.2004.04.004 15955465
147 Verduci E, Agostoni C, Radaelli G, . Blood lipids profile in hyperlipidemic children undergoing different dietary long chain polyunsaturated supplementations: a preliminary clinical trial. Int J Food Sci Nutr. 2014;65(3):375–9. PMID: 24228803. 10.3109/09637486.2013.858239 24228803
148 Kusters DM, Avis HJ, de Groot E, . Ten-year follow-up after initiation of statin therapy in children with familial hypercholesterolemia. JAMA. 2014;312(10):1055–7. PMID: 25203086. 10.1001/jama.2014.8892 25203086
149 Desai NK, Mendelson MM, Baker A, . Hepatotoxicity of Statins as Determined by Serum Alanine Aminotransferase in a Pediatric Cohort With Dyslipidemia. Journal of Pediatric Gastroenterology & Nutrition. 2019;68(2):175–81. PMID: 30334928. 10.1097/MPG.0000000000002174 30334928
150 Joyce NR, Zachariah JP, Eaton CB, . Statin Use and the Risk of Type 2 Diabetes Mellitus in Children and Adolescents. Acad Pediatr. 2017;17(5):515–22. PMID: 28232259. 10.1016/j.acap.2017.02.006 28232259
151 Vuorio A, Kuoppala J, Kovanen PT, . Statins for children with familial hypercholesterolemia. Cochrane Database Syst Rev. 2019;11(11):07. PMID: 31696945. 10.1002/14651858.CD006401.pub5 31696945
152 Karapostolakis G, Vakaki M, Attilakos A, . The Effect of Long-Term Atorvastatin Therapy on Carotid Intima-Media Thickness of Children With Dyslipidemia. Angiology. 2021;72(4):322–31. PMID: 33242982. 10.1177/0003319720975635 33242982
153 Mamann N, Lemale J, Karsenty A, . Intermediate-Term Efficacy and Tolerance of Statins in Children. Journal of Pediatrics. 2019;210:161–5. PMID: 31053349. 10.1016/j.jpeds.2019.03.032 31053349
154 Langslet G, Breazna A, Drogari E. A 3-year study of atorvastatin in children and adolescents with heterozygous familial hypercholesterolemia. J Clin Lipidol. 2016;10(5):1153–62 e3. PMID: 27678432. 10.1016/j.jacl.2016.05.010 27678432
155 Carreau V, Girardet JP, Bruckert E. Long-term follow-up of statin treatment in a cohort of children with familial hypercholesterolemia: efficacy and tolerability. Paediatr Drugs. 2011;13(4):267–75. PMID: 21692550. 10.2165/11591650-000000000-00000 21692550
156 Kavey RW, Manlhiot C, Runeckles K, . Effectiveness and Safety of Statin Therapy in Children: A Real-World Clinical Practice Experience. CJC Open. 2020;2(6):473–82. PMID: 33305206. 10.1016/j.cjco.2020.06.002 33305206
157 Benekos T, Kosmeri C, Vlahos A, . Nine-year overview of dyslipidemia management in children with heterozygous familial hypercholesterolemia: a university hospital outpatient lipid clinic project in Northwestern Greece. J Pediatr Endocrinol Metab. 2020;33(4):533–8. PMID: 32084003. 10.1515/jpem-2019-0250 32084003
158 Humphries SE, Cooper J, Dale P, . The UK Paediatric Familial Hypercholesterolaemia Register: Statin-related safety and 1-year growth data. J. 2018;12(1):25–32. PMID: 29208363. 10.1016/j.jacl.2017.11.005 29208363
159 Zachariah JP, Chan J, Mendelson MM, . Adolescent Dyslipidemia and Standardized Lifestyle Modification: Benchmarking Real-World Practice. J Am Coll Cardiol. 2016;69(19):2122–3. PMID: 27810053. 10.1016/j.jacc.2016.08.041 27810053
160 Luirink IK, Wiegman A, Kusters DM, . 20-Year Follow-up of Statins in Children with Familial Hypercholesterolemia. N Engl J Med. 2019;381(16):1547–56. PMID: 31618540. 10.1056/NEJMoa1816454 31618540
161 Benuck I. Point: The rationale for universal lipid screening and treatment in children. J. 2015;9(5 Suppl):S93–S100. PMID: 26343217. 10.1016/j.jacl.2015.03.104 26343217
162 Radaelli G, Sausen G, Cesa CC, . Secondary Dyslipidemia In Obese Children - Is There Evidence For Pharmacological Treatment? Arq Bras Cardiol. 2018;111(3):356–61. PMID: 30156604. 10.5935/abc.20180155 30156604
163 Ference BA, Yoo W, Alesh I, . Effect of long-term exposure to lower low-density lipoprotein cholesterol beginning early in life on the risk of coronary heart disease: a Mendelian randomization analysis. J Am Coll Cardiol. 2012;60(25):2631–9. PMID: 23083789. 10.1016/j.jacc.2012.09.017 23083789
164 Clarke WR, Schrott HG, Leaverton PE, . Tracking of blood lipids and blood pressures in school age children: the Muscatine study. Circulation. 1978;58(4):626–34. PMID: 688572. 10.1161/01.cir.58.4.626 688572
165 Zhang Y, Vittinghoff E, Pletcher MJ, . Associations of Blood Pressure and Cholesterol Levels During Young Adulthood With Later Cardiovascular Events. J Am Coll Cardiol. 2019;74(3):330–41. PMID: 31319915. 10.1016/j.jacc.2019.03.529 31319915
166 Pool LR, Aguayo L, Brzezinski M, . Childhood Risk Factors and Adulthood Cardiovascular Disease: A Systematic Review. Journal of Pediatrics. 2021;232:118–26.e23. 10.1016/j.jpeds.2021.01.053 33516680
167 Cook S, Auinger P, Huang TT. Growth curves for cardio-metabolic risk factors in children and adolescents. J Pediatr. 2009;155(3):S6 e15–26. PMID: 19732566. 10.1016/j.jpeds.2009.04.051 19732566
168 Magnussen CG, Raitakari OT, Thomson R, . Utility of currently recommended pediatric dyslipidemia classifications in predicting dyslipidemia in adulthood: evidence from the Childhood Determinants of Adult Health (CDAH) study, Cardiovascular Risk in Young Finns Study, and Bogalusa Heart Study. Circulation. 2008;117(1):32–42. PMID: 18071074. 10.1161/CIRCULATIONAHA.107.718981 18071074
169 Adams C, Burke V, Beilin LJ. Cholesterol tracking from childhood to adult mid-life in children from the Busselton study. Acta Paediatr. 2005;94(3):275–80. PMID: 16028644. 10.1111/j.1651-2227.2005.tb03069.x 16028644
170 Kelder SH, Osganian SK, Feldman HA, . Tracking of physical and physiological risk variables among ethnic subgroups from third to eighth grade: the Child and Adolescent Trial for Cardiovascular Health cohort study. Prev Med. 2002;34(3):324–33. PMID: 11902849. 10.1006/pmed.2001.0990 11902849
171 Cholesterol Treatment Trialists C, Mihaylova B, Emberson J, . The effects of lowering LDL cholesterol with statin therapy in people at low risk of vascular disease: meta-analysis of individual data from 27 randomised trials. Lancet. 2012;380(9841):581–90. PMID: 22607822. 10.1016/S0140-6736(12)60367-5 22607822
172 Shapiro MD, Bhatt DL. “Cholesterol-Years” for ASCVD Risk Prediction and Treatment. J Am Coll Cardiol. 2020;76(13):1517–20. PMID: 32972527. 10.1016/j.jacc.2020.08.004 32972527
173 Zhang Y, Pletcher MJ, Vittinghoff E, . Association Between Cumulative Low-Density Lipoprotein Cholesterol Exposure During Young Adulthood and Middle Age and Risk of Cardiovascular Events. JAMA Cardiol. 2021. PMID: 34550307. 10.1001/jamacardio.2021.3508 34550307
174 Bahls M, Lorenz MW, Dorr M, . Progression of conventional cardiovascular risk factors and vascular disease risk in individuals: insights from the PROG-IMT consortium. Eur J Prev Cardiolog. 2020;27(3):234–43. PMID: 31619084. 10.1177/2047487319877078 31619084
175 Juonala M, Wu F, Sinaiko A, . Non-HDL Cholesterol Levels in Childhood and Carotid Intima-Media Thickness in Adulthood. Pediatrics. 2020;145(4). PMID: 32209701. 10.1542/peds.2019-2114 32209701
176 Lorenz MW, Markus HS, Bots ML, . Prediction of clinical cardiovascular events with carotid intima-media thickness: a systematic review and meta-analysis. Circulation. 2007;115(4):459–67. PMID: 17242284. 10.1161/CIRCULATIONAHA.106.628875 17242284
177 Lorenz MW, Polak JF, Kavousi M, . Carotid intima-media thickness progression to predict cardiovascular events in the general population (the PROG-IMT collaborative project): a meta-analysis of individual participant data. Lancet. 2012;379(9831):2053–62. PMID: 22541275. 10.1016/S0140-6736(12)60441-3 22541275
178 Willeit P, Tschiderer L, Allara E, . Carotid Intima-Media Thickness Progression as Surrogate Marker for Cardiovascular Risk: Meta-Analysis of 119 Clinical Trials Involving 100 667 Patients. Circulation. 2020;142(7):621–42. PMID: 32546049. 10.1161/CIRCULATIONAHA.120.046361 32546049
179 Azcui Aparicio RE, Ball J, Yiallourou S, . Imaging-guided evaluation of subclinical atherosclerosis to enhance cardiovascular risk prediction in asymptomatic low-to-intermediate risk individuals: A systematic review. Prev Med. 2021;153:106819. PMID: 34599926. 10.1016/j.ypmed.2021.106819 34599926
180 Narverud I, Retterstol K, Iversen PO, . Markers of atherosclerotic development in children with familial hypercholesterolemia: a literature review. Atherosclerosis. 2014;235(2):299–309. PMID: 24908240. 10.1016/j.atherosclerosis.2014.05.917 24908240
181 Braamskamp MJ, Hutten BA, Wiegman A. Early initiation of statin treatment in children with familial hypercholesterolaemia. Curr Opin Lipidol. 2015;26(3):236–9. PMID: 25943840. 10.1097/MOL.0000000000000177 25943840
182 Pyles LA, Lilly CL, Joseph A, . Cardiometabolic risk factors in siblings from a statewide screening program. J. 2020;14(6):762–71. PMID: 33067145. 10.1016/j.jacl.2020.09.003 33067145
183 Wald DS, Bestwick JP, Morris JK, . Child-Parent Familial Hypercholesterolemia Screening in Primary Care. New England Journal of Medicine. 2016;375(17):1628–37. PMID: 27783906. 10.1056/NEJMoa1602777 27783906
184 Wald DS, Bestwick JP. Reaching detection targets in familial hypercholesterolaemia: Comparison of identification strategies. Atherosclerosis. 2020;293:57–61. PMID: 31837509. 10.1016/j.atherosclerosis.2019.11.028 31837509
185 Wald DS, Wald NJ. Integration of child-parent screening and cascade testing for familial hypercholesterolaemia. J Med Screen. 2019;26(2):71–5. PMID: 30319009. 10.1177/0969141318796856 30319009
186 Doshi N, Perrin EM, Lazorick S, . Short-term change in body mass index in overweight adolescents following cholesterol screening. Arch Pediatr Adolesc Med. 2009;163(9):812–7. PMID: 19736334. 10.1001/archpediatrics.2009.152 19736334
187 Gregory EF, Miller JM, Wasserman RC, . Routine Cholesterol Tests and Subsequent Change in BMI Among Overweight and Obese Children. Acad Pediatr. 2019;19(7):773–9. PMID: 31152795. 10.1016/j.acap.2019.05.131 31152795
188 Futema M, Cooper JA, Charakida M, . Screening for familial hypercholesterolaemia in childhood: Avon Longitudinal Study of Parents and Children (ALSPAC). Atherosclerosis. 2017;260:47–55. PMID: 28349888. 10.1016/j.atherosclerosis.2017.03.007 28349888
189 Austin MA, Hutter CM, Zimmern RL, . Genetic causes of monogenic heterozygous familial hypercholesterolemia: a HuGE prevalence review. Am J Epidemiol. 2004;160(5):407–20. PMID: 15321837. 10.1093/aje/kwh236 15321837
190 Bellows BK, Khera AV, Zhang Y, . Estimated Yield of Screening for Heterozygous Familial Hypercholesterolemia With and Without Genetic Testing in US Adults. J Am Heart Assoc. 2022;11(11):e025192. PMID: 35583136. 10.1161/jaha.121.025192 35583136
191 Navar AM, Fine LJ, Ambrosius WT, . Earlier treatment in adults with high lifetime risk of cardiovascular diseases: What prevention trials are feasible and could change clinical practice? Report of a National Heart, Lung, and Blood Institute (NHLBI) Workshop. Am J Prev Cardiol. 2022;12:100430. PMID: 36439649. 10.1016/j.ajpc.2022.100430 36439649
192 Marks D, Thorogood M, Neil HAW, . A review on the diagnosis, natural history, and treatment of familial hypercholesterolaemia. Atherosclerosis. 2003;168(1):1–14. PMID: 12732381. 10.1016/S0021-9150(02)00330-1 12732381
193 Mach F, Baigent C, Catapano AL, . 2019 ESC/EAS Guidelines for the management of dyslipidaemias: lipid modification to reduce cardiovascular risk. Eur Heart J. 2020;41(1):111–88. PMID: 31504418. 10.1093/eurheartj/ehz455 31504418
194 UK National Screening Committee. Screening for hypercholesterolaemia in children. London, UK: UK NSC; 2020.
195 National Institute for Health and Care Excellence. Familial hypercholesterolaemia: identification and management: CG71 [Last updated 10/04/2019]. https://www.nice.org.uk/guidance/cg71. Accessed: Jan 22, 2021.
196 Ramaswami U, Humphries SE, Priestley-Barnham L, . Current management of children and young people with heterozygous familial hypercholesterolaemia - HEART UK statement of care. Atherosclerosis. 2019;290:1–8. PMID: 31536851. 10.1016/j.atherosclerosis.2019.09.005 31536851
197 Brunham LR, Ruel I, Aljenedil S, . Canadian Cardiovascular Society Position Statement on Familial Hypercholesterolemia: Update 2018. Can J Cardiol. 2018;34(12):1553–63. PMID: 30527143. 10.1016/j.cjca.2018.09.005 30527143
198 Hagan JF, Shaw JS, Duncan PM. Bright Futures: Guidelines for Health Supervision of Infants, Children, and Adolescents [pocket guide]. 4th ed. Elk Grove Village, IL: American Academy of Pediatrics; 2017.
199 Jellinger PS, Handelsman Y, Rosenblit PD, . American Association of Clinical Endoctrinologists and American College of Endocrinology Guidelines for Management of Dyslipidemia and Prevention of Cardiovascular Disease - Executive Summary. Endocr Pract. 2017;23(4):479–97. PMID: 28156151. 10.4158/EP171764.GL 28156151
200 Jellinger PS, Handelsman Y, Rosenblit PD, . American Association of Clinical Endocrinologists and American College of Endocrinology Guidelines for Management of Dyslipidemia and Prevention of Cardiovascular Disease. Endocr Pract. 2017;23(Suppl 2):1–87. PMID: 28437620. 10.4158/ep171764.appgl 28437620
201 American Academy of Family Physicians. Clinical Preventive Service Recommendation: Lipid Disorders. https://www.aafp.org/family-physician/patient-care/clinical-recommendations/all-clinical-recommendations/lipid-disorders.html. Accessed: 3/1/2021.
202 Watts GF, Gidding S, Wierzbicki AS, . Integrated guidance on the care of familial hypercholesterolaemia from the International FH Foundation. Eur J Prev Cardiol. 2015;22(7):849–54. PMID: 24776375. 10.1177/2047487314533218 24776375
203 Sawyer SM, Azzopardi PS, Wickremarathne D, . The age of adolescence. Lancet Child Adolesc Health. 2018;2(3):223–8. PMID: 30169257. 10.1016/s2352-4642(18)30022-1 30169257