# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Brandy Peaker, MD, MPH, and Tina Fan, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Stephen R. Daniels, MD, PhD; Juanita Redfield, MD; and Justin P.V. Zachariah MD, MPH, who provided expert review of the draft report; the Office of Genomics and Precision Public Health and the National Center for Chronic Disease Prevention and Health Promotion with the Centers for Disease Control, and the National Institutes of Health’s National Heart, Lung, and Blood Institute for providing federal partner review of the draft report; Jill Pope, BA, Melanie Davies, MAIS, and Elizabeth Webber, MS, for technical and editorial assistance at the Center for Health Research.