# Chapter 4 Discussion

## Summary of Evidence

We conducted a systematic review to support the USPSTF in updating its recommendation on lipid screening in children and adolescents. We have included seven new studies of diagnostic yield, 16 new treatment trials, and two new non-randomized studies of interventions. Despite the inclusion of new evidence, our conclusions are similar to those of the prior reviews^2,^ ^3^ (Tables 67–69). There is no direct evidence from population-based screening trials addressing the benefits and harms of pediatric lipid screening for intermediate, behavioral, or health outcomes. Our updated review shows that dyslipidemia is common in contemporary pediatric populations in the United States with a prevalence of 19.2 percent for any lipid abnormality and heterozygous FH prevalence (as defined by phenotype) estimated at 0.2 to 0.4 percent (1:250 to 1:500). The body of evidence on treatment benefit is strongest for statins in FH children and adolescents with pooled analysis showing beneficial effects on TC and LDL-C; these results were based on mostly small, short-term studies with the longest trial of 2 years. Most of the evidence for statin harms is from small, short-term studies. Limited longer-term evidence shows few withdrawals due to adverse events, slightly higher rates of liver and musculoskeletal lab elevations, and no significant differences in Tanner staging or hormonal adverse events between statin and placebo groups. These safety and efficacy findings are consistent with another recent systematic review^151^ and 1-to-20-year observational followup studies of children and adolescents on statins.^71,^ ^152–159^ The trials of bile acid sequestrants, fibrates and PCSK9 inhibitors in FH populations show reductions in one or more lipid parameters and are generally associated with low withdrawals due to adverse events. There is scant evidence on behavioral counseling interventions and supplements in FH; two small plant sterol supplement trials show improvement in TC and LDL-C at 4-8 weeks. The body of evidence on treatment of multifactorial dyslipidemia is sparse, being limited to two short term behavioral counseling interventions showing modest short-term benefits in lipid levels that did not persist with longer follow-up. These results are consistent with short-term quality improvement projects in specialty settings that have shown that clinician advice targeting lifestyle modifications have shown promising results especially for LDL-C reductions.^159^ Two supplement studies of flaxseed and fish oil showing no benefit in lipid levels. Supplement trials recruiting both FH and multifactorial dyslipidemia populations show mixed results on lipid outcomes for fiber supplements and data on other supplements were too limited to make conclusions. Fiber supplements were commonly associated with gastrointestinal side effects and limited evidence from other supplements reported no adverse events, no serious adverse events or no AEs leading to withdrawals.

Table 67 Familial Hypercholesterolemia: Summary of Evidence

Intervention | Number of included studies; K (n) | Summary of findings | Consistency and precision | Other limitations | Strength of evidence^*^ | Applicability
KQ1 (Screening Benefits)
Universal or Selective Screening | 0 | - | NA | - | INSUFFICIENT | -
KQ2 (Yield)
Universal or Selective Screening | 3 (N=395,465); New studies: 3 | Diagnostic yield:; No studies reported true diagnostic yield as there were no screening studies with genetic testing; Prevalence:; Using thresholds of LDL-C ≥190 mg/dL or TC ≥270 mg/dL, FH prevalence was 0.20 to 0.42% (1:250 to 1:500); Targeted screening based on family history would miss a substantial proportion of cases. | Diagnostic yield: NA; Prevalence:; Reasonably consistent; reasonably precise | No genetic or family history criteria; lipid values are used as a proxy for FH | INSUFFICIENT for diagnostic yield; LOW for prevalence | US children and adolescents with most evidence for ages 10 or older; applicability to various recruitment settings and geographic locations
KQ3 (Screening Harms)
Universal or Selective Screening | 0 | - | NA | - | INSUFFICIENT | -
KQ4 (Treatment Benefit)
Statin | 10 (n=1230); New studies: 1 | TC: k= 7, N=706, MD in change, −82.1 mg/dL (95% CI, −101.1 to −63.2, I^2^=83.0%); LDL-C: k= 8, N=742, MD in change, −81.3 mg/dL (95% CI, −97.6 to −65.0, I^2^=81.6%); TC and LDL-C effects appear dose related.; HDL-C: no difference; TG: mixed results; cIMT: 1 trial (N=214) reported statistically significant mean difference in change favoring IG at 2 years | Consistent; reasonably precise | Heterogeneity of statin drugs and intensity; Short-term followup: One 2-year trial but all other trials <6 months; No health outcomes.; Small sample sizes, ranging from 50 to 214 | MODERATE for benefit | Children and adolescents aged 6-18 years with FH defined using various diagnostic criteria
Bile acid sequestrants | 03 (n=332); New studies: 0 | TC: MD in change −22.1 to −40.6 mg/dL; LDL-C: MD in change −13.2 to −45.9 mg/dL; TG: no difference; HDL-C: mixed results; Variation in effect by dose. | Reasonably consistent; reasonably precise | Different formulations of bile acid sequestrants; Short duration 8 to 52 weeks; No health outcomes. | LOW for benefit | Children and adolescents age 6-17 years with FH
Ezetimibe | 1 (n=138); New studies: 0 | TC: MD in change, −64.0 mg/dL (95% CI, −81.1 to −46.9); LDL-C: MD in change, −63.0 mg/dL (95% CI, −79.5 to −46.5); HDL-C and TG: No difference; Non-HDL-C: MD in change; −65.0 mg/dL (95% CI, −82.2 to −47.8) | Consistency NA; reasonably precise | Short duration 12 weeks; No health outcomes. | LOW for benefit | Children 6-11 years with FH
Fibrate | 1 (n=14); New studies: 1 | TC: MD in change −84.9 mg/dL (95% CI, −126.2 to −43.6); HDL-C and TG: no difference | Consistency NA; imprecise | Very small trial size; Short duration 13 weeks; No health outcomes. | INSUFFICIENT | Children and adolescents 4-15 years with FH;; This drug is not available in the U.S and is not FDA approved in children. Currently, there are no fibrate drugs approved in children or adolescents.
PCSK9 inhibitor | 1 (n=158); New studies: 1 | LDL-C: MD in change, −68.6 mg/dL (95% CI, −83.1 to −54.0); Non-HDL-C: MD in % change, −35.1 (−412.0 to −28.2); cIMT: no difference | Consistency NA; reasonably precise | Short duration 24 weeks; No health outcomes. | LOW for benefit | Children and adolescents age 10-17 with FH
Drug combination (simvastatin+ ezetimibe) | 1 (n=248); New studies: 0 | (Compared to single drug); TC: MD in change, −40.1 mg/dL [95% CI, −51.1 to −29.2]); LDL-C: MD in change, −37.5 mg/dL (95% CI, −48.0 to −27.0); TG: −9.5 median difference in % change, p<0.01; Non-HDL-C: MD in change, −40.0 mg/dL (95% CI, −51.0 to −28.9) | Consistency NA; reasonably precise | Short duration 33 weeks; No health outcomes. | LOW for benefit | Children and adolescents 10-17 years with FH
Behavioral counseling | 1 (n=21); New studies: 1 | Lipids: no difference; Physical activity outcomes: overlapping CIs for IG v CG; Dietary outcomes: mixed results | Consistency NA; imprecise | Very small trial; Short duration 12 weeks; No health outcomes. | INSUFFICIENT | Low intensity diet and PA intervention for 10–18-year-olds with FH
Supplement (Plant sterols, omega-3 fatty acid, combination plant sterol/stanol and omega-3 fatty acid) | 4 (n=116); New studies:4 | Plant sterol spreads (k=2, n= 82): statistically significant MD in change: TC, −20.5 to −30.5 mg/dL and LDL-C, −22.4 to −30.1 mg/dL; Omega-3 fatty acids (k=1, n=20): no statistically significant difference in TC or LDL-C; Combination plant sterol/stanol and omega-3 fatty acid (k=1, n=14): no statistically significant difference in TC or LDL-C | Plant sterols: Reasonably consistent; imprecise; Omega 3 fatty acid and combination plant sterol-omega 3 fatty acid: consistency NA, imprecise | 1-2 trial for each intervention type; Short duration 4 to 8 weeks; No health outcomes. | Plant sterols: LOW for benefit; Omega 3 fatty acids: INSUFFICIENT; Combination plant sterol-omega 3 fatty acid: INSUFFICIENT | Long term adherence to food spread uncertain
KQ5 (Treatment Harms)
Statin | 12 (n=1476 in trials, 10,336 in NRSI harms-only studies); New studies: 3 (1 RCT, 2 NRSI) | Transaminitis >3 times ULN: 0-4.5% (IG) vs 0-1.9% (CG) but largest trial (N=214) with 2-year followup reported no cases in the statin group and only 2 cases of AST >3 times ULN in the control group. In the 10-year observational followup of this trial, transaminitis at this threshold was similarly rare (ALT: 1 case of >3 times elevation in the statin group; AST: 1 case of >3 times ULN each in the statin and control group).; CK ≥10x ULN: 0 in 2 trials and up to 4.5% (IG) vs 1.7% (CG) but one trial’s 10-year observational followup reported no instances of elevated CK.; 1 NRSI (n=943) reported ALT elevations of greater than 3 times the upper limit of normal with a frequency of 4.4% in the statin group and 1.5% in the control group over 3.5 years of observation; 1 NRSI (N=9393) showed no difference in new diabetes diagnoses over 9 years; 6 trials (n=931) and 1 NRSI (n=309) reported no significant differences between Tanner stages or other hormonal adverse events | Inconsistent; imprecise | Most trials were short term and small with few events leading to imprecise estimates; Clinical importance of transient elevations in these lab values in unknown | LOW for reversible liver and musculoskeletal laboratory abnormalities; INSUFFICIENT for new onset diabetes; LOW for no growth or hormonal harms | Short term harms
Bile acid sequestrants | 3 (n=332); New studies: 0 | Similar rates of total adverse events in IG and CG | Relatively consistent, imprecise | Different formulations, few events; Short 8- to 52-week duration | LOW for minimal harm | Children and adolescents age 6-17 years with FH
Ezetimibe | 1 (n=138); New studies: 0 | Similar rates of total adverse events in IG and CG | Consistency NA, imprecise | Single trial, short duration 12 weeks, few events | INSUFFICIENT | Children 6-11 years with FH
Fibrate | 1 (n=14); New studies: 1 | Transient ALT elevation: 1 event in IG; Alkaline phosphatase elevation: 1 event in IG | Consistency NA, imprecise | Single trial, short duration 13 weeks, few events | INSUFFICIENT | Children and adolescents 4-15 years with FH
PCSK9 inhibitor | 1 (n=158); New studies: 1 | Similar rates of total adverse events in IG and CG | Consistency NA, imprecise | Single trial, short duration 24 week, few events | INSUFFICIENT | Children and adolescents age 10-17 with FH
Drug combination (simvastatin + ezetimibe) | 1 (n=248); New studies: 0 | Similar rates of total adverse events in IG and CG | Consistency NA, imprecise | High total AEs in both IG and CG; Short 33-week duration | INSUFFICIENT | Children and adolescents 10-17 years with FH
Behavioral counseling | 0 | - | NA | - | INSUFFICIENT | -
Supplement (DHA, plant sterols) | 3 (n=102); New studies: 3 | All 3 trials reported that there were 0 adverse events | Consistency NA; imprecise | Small studies, short duration 6-16 weeks | INSUFFICIENT | Children and adolescents 6-18 years

* For our review-of-reviews method, we adopted the strength of the overall body of evidence assigned within the primary systematic review. In most cases, these grades were based on the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group definitions which consider study limitations, consistency of effect, imprecision, indirectness, and publication bias. Where strength of evidence grades were not available, we adapted the EPC approach to assign an overall strength of evidence grade based on consensus discussions involving at least two reviewers.

Abbreviations: AE = adverse event; ALT = alanine transaminase; AST = aspartate aminotransferase; CG = control group; CI = confidence interval; cIMT = carotid intima-media thickness test; FH = familial hypercholesterolemia; IG = intervention group; KQ = key question; LDL-C = low-density lipoprotein cholesterol; HDL-C = high-density lipoprotein cholesterol; MD = mean difference; mg/dL = milligram per deciliter; NA = not applicable; Non-HDL-C = non-high-density-lipoprotein cholesterol; NR = not reported; NRSI = nonrandomized controlled study of intervention; RCT = randomized controlled trial; TC = total cholesterol; TG = triglycerides; ULN = upper limit of normal

Table 68 Multifactorial Dyslipidemia: Summary of Evidence

Intervention | Number of included studies | Summary of findings | Consistency and precision | Other limitations | Strength of evidence^*^ | Applicability
KQ1 (Screening Benefits)
Universal or selective screening | 0 | - | NA | - | INSUFFICIENT | -
KQ2 (Yield)
Universal or selective screening | 5 (n=142,257); New studies: 5 | Diagnostic yield: No studies reported true diagnostic yield as there were no screening studies with confirmatory testing; Prevalence:; 1+ abnormal lipid value: 19.2% (NHANES, N=4,381); TC ≥200 mg/dL: 7.1% (NHANES) to 9.4% (PVHS) (3 studies, N=75,551); LDL-C ≥130 mg/dL: 6.4% (NHANES) to 7.4% (CARDIAC) (2 studies, N=56,824); HDL-C <40 mg/dL: 12.1% (NHANES) to 22.2% (PVHS) (4 studies, N=72, 320); TG ≥130 mg/dL: 10.2% (NHANES) (1 study, N=2,045); Non-HDL-C ≥145 mg/dL: 6.4% (NHANES) and 13.0% (PVHS) (2 studies, N=16,150) | Diagnostic yield: NA; Prevalence:; Consistent; reasonably precise for TC, LDL-C, but imprecise for other measures | No confirmatory testing; NHANES represents only national sample and included most recent years of 2016; fasting and nonfasting samples; Prevalence varies by population characteristics | INSUFFICIENT for diagnostic yield of screening tests; MODERATE that abnormal lipid values are common | US children and adolescents age 6-19 years; Overall prevalence lower in national dataset (NHANES) compared to other geographic-ally focused recruitment settings
KQ3 (Screening Harms)
Universal or selective screening | 0 | - | NA | - | INSUFFICIENT | -
KQ4 (Treatment Benefits)
Behavioral counseling | 2 (n=934); New studies: 1 | One high-intensity dietary intervention (DISC) 7-year trial showed statistically significant reductions in TC, LDL-C (MD in change −3.3 mg/dL for TC and LDL-C) at 3 years that were not sustained at 7-year followup.; One low intensity dietary 10-week intervention with up to 1-year followup: statistically significant reduction in LDL-C (MD in change −6.7 mg/dL) at 3 months not sustained at 1-year followup; HDL-C and TG: no difference; Both trials reported that interventions were associated with improved dietary intake outcomes which were attenuated at longer followup. | Consistent, reasonably precise | Heterogeneous dietary interventions with variable intensity, duration, and followup | LOW for no long-term benefit | Children ages 4-10 years
Supplement (flaxseed and fish oil) | 2 (n=74); New studies: 1 | Flaxseed: no difference in TC or LDL-C but worsening of TG and HDL-C in IG, no differences in BMI or total caloric intake.; Fish oil: no difference in TC or LDL-C | Consistency NA, imprecise | Small studies with single study for each supplement.; Short duration 4-8 weeks | INSUFFICIENT | Children and adolescents 8-18 years
KQ5 (Treatment Harms)
Behavioral counseling | 2 (n=934); New studies: 1 | No harmful effects identified in growth (BMI, weight, height), development (Tanner stage), nutritional (serum ferritin, red cell folate, zinc, albumin), or psychological (anxiety, depression, behavior) outcomes. One trial (DISC) reported better depression outcomes in the IG. | Consistent, reasonably precise | Heterogeneous dietary interventions with variable intensity, duration, and followup | LOW for no harms | Children 4-10 years
Supplement (flaxseed and fish oil) | 2 (n=74); New studies: 1 | Flaxseed trial (N= 32): no adverse events; Fish oil trial (N=42): GI symptoms, fishy taste and frequent nose bleeds more common in intervention group | Consistency NA, imprecise | Single small trial for each supplement.; Short duration 4-8 weeks | INSUFFICIENT | Children and adolescents 8-18 years

* For our review-of-reviews method, we adopted the strength of the overall body of evidence assigned within the primary systematic review. In most cases, these grades were based on the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group definitions which consider study limitations, consistency of effect, imprecision, indirectness, and publication bias. Where strength of evidence grades were not available, we adapted the EPC approach to assign an overall strength of evidence grade based on consensus discussions involving at least two reviewers.

Abbreviations: AE = adverse event; ALT = alanine transaminase; AST = aspartate aminotransferase; BMI = body mass index; CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CG = control group; CI = confidence interval; cIMT = carotid intima-media thickness test; DISC = Dietary Intervention Study in Children; FH = familial hypercholesterolemia; IG = intervention group; KQ = key question; LDL-C = low-density lipoprotein cholesterol; HDL-C = high-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; MD = mean difference; mg/dL = milligram per deciliter; NA = not applicable; NHANES = National Health and Nutrition Examination Survey; Non-HDL-C = non-high-density-lipoprotein cholesterol; NR = not reported; NRSI = nonrandomized controlled study of intervention; PVHS = The Poudre Valley Health System study; RCT = randomized controlled trial; TC = total cholesterol; TG = triglycerides; ULN = upper limit of normal

Table 69 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Summary of Evidence

Intervention | Number of included studies | Summary of findings | Consistency and precision | Other limitations | Strength of evidence^*^ | Applicability
KQ1 (Screening Benefits)
Universal and selective screening | 0 | - | NA | - | INSUFFICIENT | -
KQ2 (Yield)
Universal and selective screening | See above tables for yield of FH and MFD | - | - | - | - | -
KQ3 (Screening Harms)
Universal and selective screening | 0 | - | NA | - | INSUFFICIENT | -
KQ4 (Treatment Benefits)
Supplement (fiber, omega 3/6 fatty acids, hazelnut, probiotic) | 7 (n=288); New studies: 7 | Fiber: 1 trial (N= 36) of the glucomannan showed 10-11 mg/dL statistically significant improvement in TC, LDL-C; 2 other fiber trials showed no statistically significant improvements. One psyllium fiber trial showed 60.2 mg/dL reduction in TG, other fiber trials showed no difference.; Omega 3/6 fatty acids: No difference in any lipid parameter; Probiotics: No difference in any lipid parameter; Hazelnuts: No difference in any lipid parameter | Inconsistent, imprecise | 1 to 3 very small trials for each supplement type; Short term trials 5-16 weeks; No health outcomes. | INSUFFICIENT for any single supplement | Children and adolescents 5-18 years
KQ5 (Treatment Harms)
Supplement (fiber, omega 3/6 fatty acids, probiotic) | 5 (n=186); New studies: 5 | 2 trials reported 0 adverse events (1 fiber trial, 1 omega 3/6 trial); 2 fiber trials reported various GI side effects up to 5-22.2% and the probiotic trial reported few cases of abdominal pain (5.4% v 2.8%). | Consistent, imprecise | 1 to 3 small trials for each supplement category; Short term trials 5-16 weeks; Few events | Fiber: LOW for GI side effects; Other supplements: INSUFFICIENT | Children and adolescents 5-18 years

* For our review-of-reviews method, we adopted the strength of the overall body of evidence assigned within the primary systematic review. In most cases, these grades were based on the Grading of Recommendations Assessment, Development and Evaluation (GRADE) working group definitions which consider study limitations, consistency of effect, imprecision, indirectness, and publication bias. Where strength of evidence grades were not available, we adapted the EPC approach to assign an overall strength of evidence grade based on consensus discussions involving at least two reviewers.

Abbreviations: AE = adverse event; ALT = alanine transaminase; AST = aspartate aminotransferase; CG = control group; CI = confidence interval; FH = familial hypercholesterolemia; IG = intervention group; KQ = key question; LDL-C = low-density lipoprotein cholesterol; GI = gastrointestinal; HDL-C = high-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; MD = mean difference; mg/dL = milligram per deciliter; NA = not applicable; Non-HDL-C = non-high-density-lipoprotein cholesterol; NR = not reported; NRSI = nonrandomized controlled study of intervention; RCT = randomized controlled trial; TC = total cholesterol; TG = triglycerides

## Single Screening Test Identifies Distinct Conditions

Our review’s juxtaposition of the bodies of evidence for FH and multifactorial dyslipidemia highlights a few key points. First, the natural history of the two conditions varies dramatically. While a single screening lipid panel would identify both conditions, FH is far less common and more prognostically severe and multifactorial dyslipidemias are highly prevalent and less severe. Second, the strength of the bodies of treatment literature are quite distinct for different dyslipidemias. Some have argued that the rationale for universal lipid screening in childhood is solely or primarily to identify those with FH because identifying FH has more potential benefit in reducing premature CVD events and death. There is existing direct RCT evidence from our review that statin therapy in FH reduces lipid levels and slows progression of atherosclerosis; additional observational evidence shows treatment in childhood reduces CVD mortality compared to delayed treatment in adulthood.^160^ While the treatment evidence for multifactorial dyslipidemias is scant, some have suggested that early identification of any dyslipidemia could lead to earlier non-pharmacologic interventions or pharmacologic management for significantly elevated LDL-C and potentially improve health outcomes.^161^ However, screening would identify nearly one-fifth of children who would be labeled as having dyslipidemia based on having at least one abnormal lipid parameter. There is no direct evidence to suggest an effective intervention for this twenty percent of children and adolescents other than to recommend healthy lifestyle habits which should be recommended to all children and adolescents. As reported in this review, there is no trial evidence supporting that any intervention in children with multifactorial dyslipidemia leads to improved lipid levels. Further, a systematic review of statin treatment in children with dyslipidemia secondary to obesity identified no studies.^162^

More detailed evidence is discussed below about indirect pathways that have been proposed to link childhood screening and early treatment of both FH and multifactorial dyslipidemias to health outcomes.

## Indirect Linkages From Child Lipid Levels to Adult Health Outcomes

In the absence of direct evidence that lipid screening in childhood is associated with improved long term health outcomes, and because any health outcomes resulting from screening and treatment in childhood would require decades to realize, several indirect linkages have been proposed as suggested in the framework in Figure 41.

Figure 41 Indirect Linkages From Child Intermediate Outcomes to Adult Health Outcomes

This figures shows the indirect linkages from child intermediate outcomes to adult health outcomes

The association between elevated adult lipids and adult CVD events (Figure 41, line c) is well established and is founded upon a causal relationship between lipids and coronary atherosclerosis.^163^ If youth lipids independently predict CVD events (Figure 41, line a), then there may be grounds to initiate early treatment if the net benefit of treatment is positive. Similarly, if there is a strong persistence between youth and adult lipids (Figure 41, line b), then early measurement of cholesterol may identify individuals at risk for future CVD events.^164^ On the other hand, if abnormal lipids in youth are transient, then more caution in initiating treatment in the young may be warranted.

### Association Between Youth Lipid Levels and Adult Health Outcomes (Figure 41, line a)

Multiple robust streams of evidence suggest that abnormal lipids in childhood and young adulthood are highly associated with adult CVD events. In 2022, the i3C Consortium published a pooled analysis of seven prospective cohort studies (n=38,589) that followed participants who had cardiovascular risk factors measured in childhood over a mean of 35 years and evaluated the association of childhood measures with subsequent cardiovascular events in adulthood.^49^ In the context of loss to followup over long periods, outcome ascertainment for fatal events was more reliable than for nonfatal events because of the use of national death registries, so we focus on fatal events here. Levels of cardiovascular risk factors in childhood (ages 3 to 19 years) were highly associated with fatal cardiovascular events in adulthood.

Hazard ratios for a fatal CVD event in adulthood were 1.30 (95% CI, 1.14 to 1.47) per unit increase in the z-score for TC (which describes standard deviations from the mean). For log-transformed TG, this HR was 1.50 (95% CI, 1.33 to 1.70). When a combined score of multiple adult cardiovascular risk factors (smoking, BMI, SBP, TG, and TC) is considered in the analysis of the relationship of combined childhood risk factors to later fatal CVD events, the child risk factors are no longer statistically significant. This could suggest that childhood risk factors predict adult fatal CVD events largely because they track to adult risk factor levels. This control for adult risk factors is only available as a combined score for multiple risk factors and is not available for lipids alone. When adult risk factors are considered as a trajectory from childhood (change in combined risk score from childhood to adulthood), both child and adult measures are statistically significant, underscoring the importance of changes over time, but again this analysis is only for combined risk factors and not lipids exclusively. One broad limitation of these i3c analyses is that individual CVD risk factors are not examined independently. Analyses were adjusted for sex, race, cohort, mean age at year of child measurement, and parent education. Furthermore, the i3C cohorts remain relatively young (ages 40 years to early 50 years) so the analyses to date focus on early CVD.

In a pooled analysis of 36,030 participants from six US-based cohort studies, Zhang and colleagues investigated the independent association between exposure to high lipids in young adulthood (age 18 to 39 years) and later CVD events, taking into account exposure to elevated lipids in later adulthood (≥40 years).^165^ This analysis is unique in its focus on cumulative exposure to elevated lipids, with a mean of 5 measurements over time per person and a median followup period of 17 years. Exposure to LDL-C levels 100 mg/dL or above in young adulthood was associated with an adjusted hazard ratio of 1.64 (95% CI, 1.27 to 2.11) for CHD, defined as myocardial infarction or CHD death, compared with LDL <100 mg/dL in young adulthood. This hazard ratio controls for later exposure to elevated lipids as well as other cardiometabolic risk factors and clinical characteristics and underscores the prognostic value of early adulthood lipid levels. Reinforcing this cumulative exposure hypothesis are data showing that adults with FH have increased CVD risk compared with adults without FH with similar lipid profiles.^11^

Limited evidence from the i3C and Zhang et al analyses suggest no differences in the associations between childhood lipids and adulthood CVD outcomes by race and ethnicity (limited to Black and White individuals), however robust evidence is lacking.^49,^ ^165^

Another analysis method using a Mendelian randomization study came to similar conclusions. In a meta-analysis of nine single nucleotide polymorphisms (SNPs) in six different genes that are associated with lower LDL-C but not competing CVD risk factors, Mendelian randomization analyses suggested that lower LDL-C levels throughout the lifespan are associated with substantially lower CHD in adulthood compared to the current practice of initiating treatment for lipid-lowering later in life.^163^ This analysis suggests that the cumulative long-term LDL-C levels plays a critical role in the natural history of atherosclerotic heart disease.

Additionally, a 2021 systematic review by Pool and colleagues^166^ identified three publications from one cohort study, the Princeton Followup Study, that reported significant associations between TG in childhood and adult CVD events with HRs ranging from 5.4 to 6.1.

### Tracking of Youth Lipid Levels to Adult Lipid Levels (Figure 41, line b)

There is no standardized measure for reporting “tracking,” so reporting among studies is variable and no single pooled measure can summarize the persistence of elevated lipids between youth and adulthood. Taken together, however, evidence suggests that tracking of TC or LDL-C from young childhood to adolescence and then to adulthood is moderate, but much less strong for TG. These tracking data should be considered in the context of known growth and maturation-related variations in children. Lipid levels are very low in cord blood at birth, increase slowly in the first 2 years of life, peak prior to puberty, and decrease during adolescence before rising again during late adolescence and young adulthood.^30,^ ^167^ Males experience a decrease in HDL-C levels during late puberty, whereas HDL-C levels remain stable in females until menopause.^21^ Because of this variation in lipid levels over the life course, and the associated limitations with fixed cutpoints that are not age- and sex-specific, assessing the persistence of elevated lipid values is likely sensitive to the ages and intervals at which measurements are occurring.

The most comprehensive analysis of lipid levels beginning in childhood is from the i3C consortium, which is a combined analysis of seven prospective cohort studies (n=38,589) that followed participants over a mean of 35 years and reported Pearson correlations for TC and TG between young childhood (3-11 years) and adolescence (12-19 years), and between childhood (3-19 years) and adulthood (≥20 years).^49^ In analyses of TC, the correlation between young childhood and adolescence was 0.74 and was 0.58 between childhood and adulthood. In analyses of TG, the correlation between young childhood and adolescence was 0.40 and was 0.44 between childhood and adulthood. In a study reporting sensitivity and specificity measures, the sensitivity and specificity of LDL-C ≥130 mg/dL in adolescence (12-18 years) were 65 percent and 75 percent for LDL-C ≥160 mg/dL in adulthood after 20.2 years of followup; the diagnostic performance was similar for TC.^168^ Persistence of elevated values can also be assessed by the proportion of a population remaining in the highest quintile of the distribution after followup. In studies reporting this measure, which had followup ranging from 4 to 27 years, between 40 and 60 percent of participants age 5-18 years at initial measurement remained in the highest quintile after followup for various lipid measures (TC, HDL-C, TG).^164,^ ^169,^ ^170^ Unsurprisingly, these studies found that shorter followup intervals and higher childhood age better tracked with adult lipid values. An analysis by Kelder and colleagues found that 79 percent of 3^rd^ graders remained within plus or minus one quintile of their initial quintile after 6 years followup for TC and HDL-C.^170^ These studies were conducted in the general population so are less relevant to the FH population for whom there is a more extensive genetic component.

### Linkage of Adult Lipid Levels to CVD Events (Figure 41, line c)

A robust literature base supports the association between elevated adult lipid levels and cardiovascular disease events both in the observational epidemiologic literature^45^ as well as the statin treatment trials.^171^ Most recently, scientists have introduced the concept of “cholesterol-years” similar to the paradigm of pack-years in tobacco exposure.^172^ Several recent analyses have focused on cumulative LDL-C exposure as an important risk factor for incident CVD. A 2021 meta-analysis of four U.S. cohorts (Atherosclerosis Risk in Communities study (ARIC), Multi-Ethnic Study of Atherosclerosis (MESA), Framingham Heart Study-Offspring (FHS-O), Coronary Artery Risk Development in Young Adults study (CARDIA) with 18,288 participants ages 18 to 60 years with data spanning 1971 to 2017 demonstrated that higher total cumulative LDL-C—as measured by cumulative levels, time-weighted average, and slope—during young adulthood and middle age—were associated with increased risk of incident CHD events (MI, CHD deaths).^173^ The point estimates for the HRs comparing the top to the bottom quartiles for these cumulative LDL-C variables ranged from 1.26 to 1.97. These findings remained significant even after adjusting for the most recent LDL-C during middle age, however, this association was not found for other CVD outcomes such as stroke or heart failure. One 2020 IPD meta-analysis of 13 international cohorts (n=34,072) similarly found that elevated mean LDL-C and lower mean HDL-C measures in adulthood (baseline ages mostly 40’s to 60’s) were associated with higher incident CVD events (MI, stroke or vascular death) but unlike the previous analyses, the annualized progression of these lipid values (slope) in individual participants was not associated with incident CVD events.^174^ Additional study designs supporting this concept of cumulative exposure are Mendelian randomization studies. One aforementioned meta-analysis of Mendelian randomization studies (n=312,321) showed that naturally random allocation to a lower LDL-C exposure, mediated by nine polymorphisms in six genes, was associated with a 54 percent CHD risk reduction for each 39 mg/dL lower LDL-C.^163^ This risk reduction is equivalent to a 3 times greater reduction in the risk of CHD per unit of lower LDL-C than statin treatment in adulthood.

### Association Between Youth Lipid Levels to Adult Subclinical CVD (cIMT) and Adult cIMT to CVD Events (Figure 41, line d)

Another pathway connecting youth lipids to health outcomes would be for youth lipids to be associated adult subclinical CVD (e.g., cIMT) and for adult subclinical CVD in turn to be associated with CVD events, or for youth cIMT to be associated with CVD events. Cohort data consistently show associations between child lipids levels and adult cIMT, and extended followup from a treatment trial initiated in childhood further reinforces this association. Further, single adult cIMT measurements appear to be associated with CVD events. Overall, the evidence base for indirect linkages associating cIMT to CVD events through the lifecourse is weaker than the evidence for the lipid pathway.

A 2020 publication from the i3C Consortium, which followed 4,582 youth ages 3 to 19 years from 4 prospective cohorts for a mean of 26 years, found that youth with dyslipidemia were at a markedly higher relative risk of having an elevated carotid artery intima-media thickness (cIMT) in adulthood compared to youth with normal lipid levels.^175^ An LDL-C ≥130 mg/dL in childhood or adolescence was associated with a 26 percent increase in cIMT ≥90^th^ percentile in adulthood (RR 1.26 [95% CI, 1.04 to 1.51]); estimates were adjusted for age, sex, BMI, SBP, cohort and length of followup. When analyzed by age groups, only LDL-C ≥130 mg/dL in youth 15-17 years was statistically significantly associated with cIMT ≥90^th^ percentile in adulthood, however this finding may be related to reduced power in age strata. The risk of cIMT ≥90^th^ percentile was attenuated and no longer statistically significant for individuals whose LDL-C was abnormal in youth and lowered to normal levels in adulthood (RR 1.16 [95% CI, 0.96 to 1.40]).

A 2021 systematic review by Pool and colleagues^166^ found longitudinal community-based population data showing a consistent association of higher childhood LDL-C and TC and thicker cIMT in adulthood, mixed findings for HDL-C, and no association between childhood TG and cIMT in adulthood. In studies stratifying cIMT findings by age, associations were present in adolescence but were not significant in early childhood.

Evidence from 20-year followup of statin therapy initiated in childhood (between 8 and 18 years, mean 14 years) is available from a small study of 214 children who were randomized between 1997 to 1999 to statins or placebo.^160^ Comparative data are available from 95 unaffected siblings and 156 parents with FH who did not receive statin treatment until much later in life (estimated mean age 32 years). This analysis showed that after 20 years, mean cIMT values converged in statin-treated children with FH and their unaffected siblings, with mean values falling from baseline in children with FH and rising in unaffected siblings.

Further, subclinical atherosclerotic changes appear early in children with FH which supports a link between lipids and cIMT. Data from an international study of 196 children with FH and 64 unaffected siblings found that statistically significant differences in cIMT were present between children with and without FH as early as 8 years of age.^40^ Another study also comparing children with FH and unaffected siblings further found that the progression of cIMT was 5 times greater in children with FH.^41^ By adulthood, atherosclerotic burden in individuals with FH has increased substantially because of continued exposure to high LDL-C.

Single cIMT measurements in adults have been shown to be associated with incident CVD, however, there is conflicting evidence about whether cIMT changes (progression or regression) over time are associated with CVD risk or if cIMT added to traditional risk calculation has added predictive value. This literature is limited by clinical heterogeneity in cIMT measurement methodology and reporting. One meta-analysis of eight observational studies in adults (n=37,197) showed a nonlinear relationship between a single CIMT measurement and MI or stroke.^176^ Based on five cohorts, the HR for MI per 1SD increase in common carotid artery IMT adjusted for age and sex was 1.26 (95% CI, 1.21 to 1.30) and the HR for stroke per 1 SD increase in common carotid artery IMT adjusted for age and sex was 1.32 (95% CI, 1.27 to 1.38). The PROG-IMT IPD meta-analysis of 16 cohorts (n=36,984) with a mean followup of 7 years showed that while mean cIMT from two ultrasound visits 2 to 7 years apart (median 4 y) was associated with CVD risk (adjusted HR 1.16 [ 95% CI 1.10 to 1.22]), the annual cIMT progression was not associated with the combined CVD endpoint (adjusted HR 0.98 [95% CI, 0.95 to 1.01]).^177^ On the other hand, a meta-analysis of 119 treatment trials (n=100,667) with a mean followup of 3.7 years showed that across all interventions, each 10 μm/year reduction of cIMT progression resulted in a relative risk for CVD of 0.91 (95% credible interval 0.87 to 0.94), with an additional relative risk for CVD of 0.92 (0.87-0.97) being achieved independent of cIMT progression.^178^ cIMT has also been evaluated as a nontraditional risk factor that may improve the predictive performance of traditional CVD risk scoring. A systematic review of 13 studies reported highly variable results for various model performance measures quantifying the incremental predictive value of cIMT. For example the change in the c-statistic from adding cIMT to traditional risk assessment was 0.007 to 0.035 and overall net reclassification index (NRI) values varied from 3.1 percent to 28.4 percent.^179^ Limitations of existing cIMT studies include heterogeneity of measurement method population, age, and followup time.

## Age to Initiate Statins in FH

There is no direct comparative effectiveness evidence to determine the exact age to start statin treatment for heterozygous FH, but earlier initiation is supported by indirect observational evidence. Net screening benefit depends on the indirect evidence that screening would correctly identify children with the condition and that earlier identification and treatment would result in improved outcomes compared to identification and treatment in adulthood. The screening benefits for those diagnosed with FH could be substantial as the condition’s natural history includes premature CVD with events occurring in the second or third decade of life.

Expert consensus guidelines recommend pharmacotherapy with statins for heterozygous FH at age 8 years or older. These recommendations for early initiation aim to reduce cumulative exposure to high LDL-C and are based on indirect evidence showing that markers of atherosclerosis are evident as early as age 8 years in children with FH compared to unaffected siblings or healthy controls; these subclinical atherosclerotic markers include higher cIMT and endothelial dysfunction (flow mediated dilation), and arterial stiffness (pulse wave velocity, arterial compliance).^40,^ ^41,^ ^180,^ ^181^ There is observational evidence supporting early treatment improvements in intermediate and health outcomes. At 10-20 year followup, cIMT progression rates converge in children with pathogenic variant-confirmed FH treated with statins and their unaffected siblings.^148,^ ^160^ One compelling observation from a 20-year followup from the statin trial by Wiegman and colleagues demonstrated that early initiation of statins in adolescence was associated with an improved cumulative CVD-free survival at 39 years of age.^160^ Those with pathogenic variant-confirmed FH who started statins in youth (mean statin initiation age of 14.0 +/− 3.1 years) had higher rates of CVD-free survival compared to their parents, for whom statins were not available until adulthood (99% v 74% CVD-free survival; HR 11.8 [95% CI, 3.0 to 107.0] adjusted for sex, smoking status).^160^ Currently, the FDA has approved seven statins in children as young as 8 to 10 years of age with heterozygous FH.

## Other Potential Benefits of Pediatric Lipid Screening

Some have argued that lipid screening can lead to additional benefits beyond identifying children with dyslipidemia. For example, universal lipid screening can lead to the discovery of secondary comorbid conditions (e.g., diabetes, hypothyroidism) through additional testing, whereby treatment of these comorbid disorders could lead to further improved health outcomes. Presumably, identification of dyslipidemia in children could also accelerate the identification of this condition in other family members via cascade testing (FH-mutation testing in relatives of someone with an FH mutation), with earlier diagnosis and treatment leading to additional benefits. However, there is limited direct evidence about additional benefits of screening beyond the child. For any type of dyslipidemia, there is a moderate correlation of abnormal lipids amongst siblings. For example, one analysis shows the sibling of a child with LDL-C ≥130 mg/dL has more than a five-fold chance of also having LDL-C above this level (OR 5.45 [95% CI, 4.31 to 6.90]).^182^ The remaining evidence on additional potential benefits to the family of screening come from the FH literature. One UK study (n=10,095) of children ages 1-2 years assessed the efficacy and feasibility of screening for cholesterol levels and testing for FH mutations during an immunization visit and found that for every 1,000 children screened 8 persons (4 children and 4 parents) were identified as having positive FH results.^183^ Using results from this original study, authors have published cost effectiveness analyses demonstrating that a combination of cascade testing (FH-mutation testing in relatives of someone with an FH mutation) and child-parent screening (testing children for cholesterol and FH mutations during 1-year immunization visits and parents of FH-positive children) was cost effective and the most rapid strategy for identifying FH in the UK population.^184,^ ^185^ The authors report that this combination strategy of cascade screening plus child-parent screening can identify one new FH individual for every 70 children screened. While soliciting family history of premature CVD or dyslipidemia has been suggested to make FH screening more efficient, family history has been shown to be inaccurate^68^ and a substantial number of FH children would be missed if screening was limited to those with family history of premature CVD.^69^

Others have surmised that screening and identification of dyslipidemia in children and adolescents with elevated BMI may make weight management interventions more effective; however, limited evidence does not support this hypothesis.^186,^ ^187^

## Limitations of Our Approach

We did not address ApoB, Lp(a), or VLDL outcomes in this review as we focused on lipids generally ordered in primary care for screening purposes. We did not systematically review the accuracy (sensitivity/specificity) of FH diagnostic criteria and our findings accepted FH as defined by study authors for all key questions. We recognize that FH is genetically heterogeneous and that the relationship between the FH genotype and FH phenotype as expressed by elevated LDL-C is not straightforward.^10,^ ^18,^ ^188,^ ^189^ We also did not include other less common monogenic or polygenic dyslipidemias, so our estimates of the positivity rates for screening may be an underestimate of familial dyslipidemias.

## Limitations of the Studies and Future Research Needs

No studies performed a confirmatory lipid or genetic test; thus, evidence for children and adolescents is limited to screen-positivity (prevalence) from a single lipid test rather than diagnostic yield of lipid screening for FH. A recent study in adults that used a regression model including genetic testing data from the UK Biobank to estimate FH prevalence in the US found a similar FH prevalence (0.38%) to what we found for children and adolescents in our review (0.2% to 0.4%).^190^ FH diagnostic criteria in yield studies were limited to lipid levels alone; this is inconsistent with treatment trial criteria which also included genetic, family, or clinical history components in addition to lipid levels. Treatment trials were generally small with relatively short followup, with most trial durations of less than 6 months. Only one statin trial had a followup as long as 2 years. With the exception of statins evaluated in the FH population, the bodies of evidence for any specific intervention in either the FH or multifactorial dyslipidemia population were extremely sparse, often consisting of just one to three studies. Behavioral counseling and supplement trials were generally small, with short term followup leading to uncertainty regarding long term adherence and benefit persistence. Outcomes for treatment trials were limited to intermediate outcomes with insufficient followup periods to assess long-term health effects or harms. Obtaining such health outcome data may be quite difficult. In order to report on health outcomes for CVD events occurring in adulthood, these trials would need to be conducted over a period of decades while maintaining adequate followup, and further may be difficult to interpret because of the contemporary relevance of the population studied. The feasibility concerns of such prevention trials are acknowledged by scholars.^191^ While one statin treatment trial and one trial of PCSK9 inhibitors reported cIMT as an intermediate outcome, no studies reported other measures of atherosclerosis such as coronary artery calcium scores. We did not identify any behavioral counseling trials in children with concurrent dyslipidemia and elevated BMI reporting lipid effects of such interventions.

We identified a few relevant US-based yield and registry studies that are following children with FH over time and intend to report long-term change in lipid levels, CVD outcomes, and/or adverse events (Appendix F). Additionally, we identified two ongoing relevant treatment studies: one trial of a PCSK9 inhibitor in children and adolescents with heterozygous FH and one trial of omega-3 treatment for dyslipidemia in children with obesity 10 to 18 years of age.

Future research needs include:

- Population-based trials evaluating the effectiveness of lipid screening in pediatric populations
- Consistency in the use of FH criteria between screening studies and treatment studies to facilitate more direct interpretation of evidence to clinical practice
- Additional placebo-controlled RCTs in FH populations would likely be considered unethical because of poor CVD prognosis in this population. Thus, additional observational cohort studies with long-term reporting of health outcomes and statin safety (including diabetes, transaminitis) in those with FH for whom statins were initiated at various timepoints in childhood and adolescence would provide additional data for long-term benefits and harms; siblings unaffected with FH could serve as appropriate controls.
- Behavioral counseling intervention trials in children with multifactorial dyslipidemia with and without elevated BMI and behavioral counseling as adjunct to pharmacotherapy in children with FH

## Conclusions

There is no direct evidence from population-based screening trials addressing the benefits and harms of pediatric lipid screening for intermediate, behavioral, or health outcomes. Dyslipidemia is common in contemporary pediatric populations, with nearly one in five children in the United States having any lipid abnormality. Heterozygous FH prevalence as defined by phenotype in U.S. pediatric cohorts is estimated at 0.2 to 0.4 percent (1:250 to 1:500). The body of evidence on treatment benefit is strongest for statins in FH children and adolescents based on pooled results showing beneficial effects on TC and LDL-C from mostly small, short-term studies, with the longest trial of 2 years and safety data from individual trials and non-randomized studies showing few withdrawals due to adverse events. There are fewer non-statin pharmacotherapy trials in FH populations showing reductions in one or more lipid parameters and generally low withdrawals due to adverse events. There is scant evidence on behavioral counseling interventions and supplements in FH. The body of evidence on treatment of multifactorial dyslipidemia is sparse, consisting of a few behavioral counseling interventions and supplements that did not reduce lipids at longest followup time point. Supplement trials recruiting both FH and multifactorial dyslipidemia populations were too few for any single supplement and insufficient to make conclusions about efficacy or safety.