# Chapter 3 Results

## Description of Included Studies

The results for this review will be presented by condition: familial hypercholesterolemia (FH) and multifactorial dyslipidemia. Within each condition, results are organized by KQ and intervention type.

We reviewed 7,058 abstracts and assessed 272 full-text articles for inclusion (Appendix B Figure 1). Overall, we included 43 studies (reported in 65 publications) across included conditions. Twenty-six studies were in children and adolescents with familial hypercholesterolemia (FH), 9 studies in children and adolescents with multifactorial dyslipidemia, and 9 studies in children and adolescents with FH or multifactorial dyslipidemia. One yield study reported on both populations. The full lists of included studies and excluded studies (with reasons for exclusion) are available in Appendix C and Appendix D, respectively.

There were no included studies for screening benefits and harms (KQ1 and KQ3). A total of seven studies were included for the diagnostic yield of serum lipid screening (KQ2), three for FH and five for multifactorial dyslipidemia (with one study reporting on both populations). A total of 33 RCTs were included for treatment benefits (KQ4): 22 RCTs in FH, four RCTs in multifactorial dyslipidemia, and seven RCTs were in a combination of FH and multifactorial dyslipidemia populations (Table 6). A total of 31 studies were included for treatment harms (KQ5): 22 studies in FH, four studies in multifactorial dyslipidemia, and five studies of populations with FH or multifactorial dyslipidemia (Table 7).

Table 6 Included Studies for Treatment Benefits, by Population and Intervention Category (Key Question 4), k=33

Intervention Category | Intervention Type | Conditions Included | Total Number of Studies (n) | Number of New Studies
Drug (k=21) | Statin (k=10) | FH | 10 (n=1,230) | 1
Drug (k=21) | Statin (k=10) | MFD | 0 | -
Drug (k=21) | Drug Combination^*^ (k=1) | FH | 1 (n=248) | 0
Drug (k=21) | Drug Combination^*^ (k=1) | MFD | 0 | -
Drug (k=21) | Bile acid sequestrants (k=3) | FH | 3 (n=332) | 0
Drug (k=21) | Bile acid sequestrants (k=3) | MFD | 0 | -
Drug (k=21) | PCSK9 inhibitor (k=1) | FH | 1 (n=158) | 1
Drug (k=21) | PCSK9 inhibitor (k=1) | MFD | 0 | -
Drug (k=21) | Ezetimibe (k=1) | FH | 1 (n=138) | 0
Drug (k=21) | Ezetimibe (k=1) | MFD | 0 | -
Drug (k=21) | Fibrate (k=1) | FH | 1 (n=14) | 1
Drug (k=21) | Fibrate (k=1) | MF | 0 | -
Behavioral (k=3) | Lifestyle counseling (k=3) | FH | 1 (n=21) | 1
Behavioral (k=3) | Lifestyle counseling (k=3) | MFD | 2 (n=934) | 1
Supplement (k=13) | Various^†^ | FH | 4 (n=116) | 4
Supplement (k=13) | Various^†^ | MFD | 2 (n=74) | 1
Supplement (k=13) | Various^†^ | FH / MFD | 7 (n=288) | 7
All intervention categories (k=33) | All intervention types | FH | 22 (n=2,257) | 8
All intervention categories (k=33) | All intervention types | MFD | 4 (n=1,008) | 2
All intervention categories (k=33) | All intervention types | FH / MFD | 7 (n=288) | 7

* Interventions included combinations of simvastatin + ezetimibe.

† Supplement interventions include DHA, DHA plus EPA, fish oil, flaxseed, glucomannan, hazelnuts (with or without skin), hempseed oil, plant sterols, probiotics, psyllium fiber, rapeseed margarine, and sistostanol esters.

Abbreviations: FH = familial hypercholesterolemia; MFD = multifactorial dyslipidemia; PCSK9 = proprotein convertase subtilisin/kexin type 9

Table 7 Included Studies for Treatment Harms, by Population and Intervention Category (Key Question 5), k=31

Intervention Category | Intervention Type | Conditions Included | Total Number of Studies (n) | Number of New Studies
Drug (k=19) | Statin (k=12) | FH | 12 (n=11,812) | 3
Drug (k=19) | Statin (k=12) | MFD | 0 | -
Drug (k=19) | Drug Combination^*^ (k=1) | FH | 1 (n=248) | 0
Drug (k=19) | Drug Combination^*^ (k=1) | MFD | 0 | -
Drug (k=19) | Bile acid sequestrants (k=3) | FH | 3 (n=332) | 0
Drug (k=19) | Bile acid sequestrants (k=3) | MFD | 0 | -
Drug (k=19) | PCSK9 inhibitor (k=1) | FH | 1 (n=158) | 1
Drug (k=19) | PCSK9 inhibitor (k=1) | MFD | 0 | -
Drug (k=19) | Ezetimibe (k=1) | FH | 1 (n=138) | 0
Drug (k=19) | Ezetimibe (k=1) | MFD | 0 | -
Drug (k=19) | Fibrate (k=1) | FH | 1 (n=14) | 1
Drug (k=19) | Fibrate (k=1) | MFD | 0 | -
Behavioral (k=2) | Lifestyle counseling (k=2) | FH | 0 | -
Behavioral (k=2) | Lifestyle counseling (k=2) | MFD | 2 (n=934) | 1
Supplement (k=10) | Various^†^ | FH | 3 (n=102) | 3
Supplement (k=10) | Various^†^ | MFD | 2 (n=74) | 1
Supplement (k=10) | Various^†^ | FH / MFD | 5 (n=186) | 5
All Interventions (k=31) | All intervention types | FH | 22 (n=12,804) | 8
All Interventions (k=31) | All intervention types | MFD | 4 (n=1,008) | 2
All Interventions (k=31) | All intervention types | FH / MFD | 5 (n=186) | 5

* Intervention included combinations of simvastatin + ezetimibe.

† Supplement interventions include DHA, DHA plus EPA, fish oil, flaxseed, glucomannan, hazelnuts (with or without skin), hempseed oil, plant sterols, probiotics, psyllium fiber, and rapeseed margarine.

Abbreviations: FH = familial hypercholesterolemia; MFD = multifactorial dyslipidemia; PCSK9 = proprotein convertase subtilisin/kexin type

## KQ1 Does Screening for FH or Multifactorial Dyslipidemia in Asymptomatic Children and Adolescents Delay or Reduce the Incidence of Health Outcomes (e.g., CVD Events or Mortality) or Improve Intermediate Outcomes (e.g., Serum Lipid Levels and Atherosclerotic Markers) in Children, Adolescents, or Adults?

### Summary of Findings

No studies meeting criteria were identified.

### FH

No studies meeting criteria were identified.

### Multifactorial Dyslipidemia

No studies meeting criteria were identified.

## KQ2 What Is the Diagnostic Yield of Serum Lipid Screening for FH or Multifactorial Dyslipidemia in Children and Adolescents?

### Summary of Findings

No studies performed a confirmatory lipid or genetic test; thus, evidence is limited to screen-positivity (prevalence) rather than diagnostic yield of lipid screening for identifying FH. We included three fair-quality U.S. studies (n=395,465) reporting prevalence of FH ranging from 0.2 to 0.4 percent (1:250 to 1:500) using diagnostic criteria exclusively based on lipid levels (LDL-C ≥190 mg/dL or TC ≥270 mg/dL). Targeted screening in those with a family history of hypercholesterolemia or premature CVD would miss many cases of children with LDL-C ≥160 mg/dL.

No studies performed a confirmatory lipid test; thus, evidence is limited to screen-positivity (prevalence) rather than diagnostic yield of lipid screening for identifying multifactorial dyslipidemia. We included five fair-quality studies (n=142,257) reporting prevalence of multifactorial dyslipidemia showing that lipid abnormalities are common, being generally more common for the parameters of HDL-C and TG. Prevalence ranged from 7.1 to 9.4 percent for elevated TC (≥200 mg/dL), 6.4 to 7.4 percent for elevated LDL-C (≥130 mg/dL), 12.1 to 22.2 percent for low HDL-C (<40 mg/dL), 8.0 to 17.3 percent for elevated TG (using various thresholds), and 6.4 to 13.0 percent for elevated non-HDL-C (≥145 mg/dL). Prevalence of any lipid abnormality in 6- to 19-year-olds was 19.2 percent based on NHANES data (2013-2016, n=4,381). Older age and higher BMI were associated with higher prevalence of multifactorial dyslipidemia. Conclusions for prevalence by race and ethnicity are limited by sparse reporting and inconsistent patterns among lipid parameters. Prevalence by sex was inconsistent across the cohorts and for different lipid measures. Overall, prevalence estimates from NHANES were generally lower than other geographically limited databases.

### FH

#### Study and Participant Characteristics

We identified no studies that performed a confirmatory lipid or genetic test; thus evidence is limited to screen-positivity (prevalence) rather than diagnostic yield of lipid screening for identifying FH. We included three fair-quality studies (in 4 articles) that reported prevalence of FH in child and adolescent populations in the United States (n=395,465) (Table 8; Appendix E Table 1).^69,^ ^70,^ ^108,^ ^109^

Table 8 Familial Hypercholesterolemia: Study Characteristics of US Cohorts Included for Key Question 2

Cohort name; Quality | N | Population | FH definition (mg/dL) | Years of data collection | Recruitment target | Recruitment methods | Brief screening details | Fasting?
NHANES^70^; Fair | 13,343 | Nonpregnant NHANES participants 12 to 19 years of age between years 1999-2012 | LDL-C ≥190 | 1999-2012 | National | NHANES participants; combined in-home interviews with mobile examinations and laboratory tests. | Mobile examination with laboratory test; lipid profiles measured from morning peripheral blood draws. | Yes^*^
Blood donors^108^; Fair | 321,718 | Youth and adults aged 16 years or older who voluntarily donated blood | MEDPED criteria:; TC ≥270 | 2002-2016 | Single state | Deidentified data were obtained from the Carter BloodCare database | Nonfasting TC measured from donors who voluntarily donated blood to Carter BloodCare between 2002-2016. | No
CARDIAC^109^; Fair | 60,404 | 5th grade students enrolled in West Virginia schools | Significant likelihood of FH:; LDL-C ≥190; Suggestive of FH:; LDL-C ≥160 | 1998-2015 | Single state | Universal screening in participating schools | Cardiovascular risk detection screening program including evaluation for obesity, dyslipidemia, hypertension, and prediabetes | Mixed^†^

* 97.6% reported fasting for ≥8 hours.

† Fasting until 1st semester 2012, thereafter, non-fasting lipids reported for abnormal lipids.

Abbreviations: CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; FH= familial hypercholesterolemia; LDL-C = low-density lipoprotein cholesterol; MEDPED = Make Early Diagnosis to Prevent Early Death Program; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey; TC = total cholesterol; US = United States

One publication used National Health and Nutrition Examination Survey (NHANES) data from nonpregnant participants 12 to 19 years of age from 1999-2012.^70^ The NHANES survey combines in-home interviews with mobile examinations and laboratory tests; about 98 percent of participants reported fasting for at least eight hours. FH was defined as LDL-C ≥190 mg/dL.

A second study aimed to estimate the prevalence of FH in a Texas blood donor program using data from all donors aged 16 years or older between January 2002 and December 2016.^108^ Authors used de-identified data from the Carter BloodCare database, with a sample of 321,718 blood donors aged 16 to 20 years. FH was defined as a nonfasting total cholesterol ≥270 mg/dL (MEDPED criteria).

A third study using a state-wide sample is the Coronary Artery Risk Detection in Appalachian Communities (CARDIAC) study,^109^ a cardiovascular risk detection screening program including evaluation for obesity, dyslipidemia, hypertension, and prediabetes. This study included fifth grade children enrolled in schools in West Virginia, who were screened between 1998 and 2015 (n=60,404). A total of 39 percent of eligible 5^th^ graders in the state participated. Serum sampling methods changed over the 17-year program and included fingerstick capillary sampling and venous serum specimens using fasting and nonfasting samples. Significant likelihood of FH was defined as LDL-C >190 mg/dL while “probable FH” was defined as LDL-C >160 mg/dL in this cohort. An earlier CARDIAC publication (n=20,266) investigated the prevalence of children with a fasting LDL-C ≥160 mg/dL and a positive family history of premature cardiovascular disease between years 2003 and 2008.^69^

Population characteristics were not reported in the adolescent age group for NHANES 1999-2012 or the Carter BloodCare donors (Table 9). The mean age of participants in the CARDIAC study was 11 years with approximately half female participants.^109^ The majority of participants were White (93%), 3 percent were Black, 1 percent Latino, 1 percent Asian, and 1 percent of “other” race. Nineteen percent of participants had a BMI in the 85-94.9^th^ percentile for BMI, and 28 percent had a BMI in the 95-98.9^th^ percentile. Approximately one-third of participants had a family history of heart disease or high total cholesterol.

Table 9 Familial Hypercholesterolemia: Population Characteristics of US Cohorts Included for Key Question 2

Cohort name | Mean age (range) | Female, % | Race/ethnicity, % | BMI | Smoking, % | % With family history of CVD and definition
NHANES, 1999-2012^70^ | NR^*^ (12-19) | NR | NR | NR | NR | NR
Blood donors, 2002-2016^108^ | NR^†^ (16-20) | NR | NR | NR | NR | NR
CARDIAC, 1998-2015^109^ | 11^‡^ (NR) | 53 | White: 93; Black: 3; Asian: 1; Native American: NR; Latino: 1; Other: 1 | 85th-94.9th percentile: 19; 95th-98.9th percentile: 28 | Smoking in the home: 33.7 | Heart disease, unspecified: 32; Family hx of high TC: 34

* Baseline population characteristics were not available for this age group.

† Baseline population characteristics only reported for overall cohort, which included adults (n=1,178,102 [3,038,420 donations]): Median age: 32 years; Female: 52.6%; Race/ethnicity, %: White: 64.8; Latino: 14.7; African American: 7.6; Asian: 2.7; Other: 1.6; Unknown: 8.6.

‡ Baseline population characteristics based on n=99,282 (1999-2016).

Abbreviations: BMI = body mass index; CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CVD = cardiovascular disease; hx = history; TC = total cholesterol; US = United States

#### Outcomes (Results)

No included studies used a second confirmatory or genetic test. Outcomes reported in these studies included only screen positivity from a single screen, therefore diagnostic yield cannot be calculated.

Results are reported in Table 10 and Figure 2. Overall prevalence ranged from 0.2 percent to 0.4 percent (1:250 to 1:500) in the three datasets using the cut point of LDL-C > or ≥190 mg/dL.

Table 10 Familial Hypercholesterolemia: Prevalence of FH in US Cohorts Included for Key Question 2 Lipid

Cohort name, Year | Fasting status | Definition (lipid values in mg/dL) | Population description | Time of screening | N analyzed | N screen positive | % screen positive
NHANES, 1999-2012^70^ | Fasting | LDL-C ≥190 | 12-19 yrs | 1999-2012 | 13,343 | NR | 0.42 (95% CI: 0.15 to 0.70)
Blood donors, 2002-2016^108^ | Nonfasting | MEDPED criteria for FH: TC ≥270 | <20 yrs | 2002-2016 | 321,718 | 1,001 | 0.31
CARDIAC, 1998-2015^69,^ ^109^ | Mixed | LDL-C >160 | 5th graders | 1998-2015 | 60,404 | 637 | 1.1
CARDIAC, 1998-2015^69,^ ^109^ | Mixed | LDL-C >175 | 5th graders | 1998-2015 | 60,404 | 248 | 0.4
CARDIAC, 1998-2015^69,^ ^109^ | Mixed | LDL-C >190 | 5th graders | 1998-2015 | 60,404 | 122 | 0.2
CARDIAC, 1998-2015^69,^ ^109^ | Fasting^69^ | LDL-C ≥160 | 5th graders with a family history of premature CVD^*^,^69^ | 2003-2008 | 14,468 | 170 | 1.2
CARDIAC, 1998-2015^69,^ ^109^ | Fasting^69^ | LDL-C ≥160 | 5th graders without a family history of premature CVD^*^,^69^ | 2003-2008 | 5,798 | 98 | 1.7

* Positive family history based on NCEP criteria: parents or grandparents with documented coronary artery disease before age of 55 years. Premature CHD was defined as coronary disease that occurred before age 55, evidenced by (1) a myocardial infarction (“heart attack”) that required hospitalization, (2) coronary bypass surgery, (3) coronary angioplasty and/or stent placement, (4) or death that resulted from CHD event.

Abbreviations: CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; FH= familial hypercholesterolemia; LDL-C = low-density lipoprotein cholesterol; MEDPED = Make Early Diagnosis to Prevent Early Death Program; mg/dL = milligrams per deciliter; NCEP = National Cholesterol Education Program; NHANES = National Health and Nutrition Examination Survey; TC = total cholesterol

Figure 2 Familial Hypercholesterolemia (FH): Prevalence of FH in US Cohorts Included for Key Question 2

Abbreviations: CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; hx = history; LDL-C = low-density lipoprotein-cholesterol; Neg = negative; NHANES = National Health and Nutrition Examination Survey; TC = total cholesterol; US = United States; yrs = years

This figure shows the prevalence of Familial hypercholesterolemia in US cohorts included for Key Question 2

In the 321,718 screened donors aged 16-20 years from the Carter BloodCare dataset, 0.3 percent (or 1:321) screened positive for FH using MEDPED criteria TC ≥270 mg/dL.^108^

In the fifth-grade cohort of the West Virginia CARDIAC program, 1.1 percent screened positive for “probable FH,” (LDL-C >160 mg/dL) and 0.2 percent screened positive for “significant likelihood of FH” (LDL-C >190 mg/dL).^109^ A separate CARDIAC publication from screening years 2003-2008 found that of 14,468 students with a positive family history of premature CVD, 1.2 percent had a fasting LDL-C ≥ 160 mg/dL.^69^ A total of 1.7 percent of 5798 students without a family history of premature CVD had a fasting LDL-C ≥ 160 mg/dL.^69^

### Multifactorial Dyslipidemia

#### Study and Participant Characteristics

No studies performed a confirmatory lipid test; thus evidence is limited to screen-positivity (prevalence) rather than diagnostic yield of lipid screening for identifying multifactorial dyslipidemia. We included five fair-quality studies (in 8 articles) that reported the prevalence of multifactorial dyslipidemia in child and adolescent populations in the United States (n=142,257) (Tables 11 and 12; Appendix E Table 2).^52,^ ^69,^ ^109–114^ The primary NHANES publication (n=26,047) included a nationally representative sample of children and adolescents aged 6-19 years screened from 1999-2016; however, only subsets of this population sample are available for the outcomes discussed below.^52,^ ^111,^ ^113^ The NHANES survey combines in-home interviews with mobile examinations and laboratory tests; the overall examination response rate was 81 percent. The threshold for abnormal lipids, using both fasting and nonfasting lipids were TC ≥200 mg/dL, LDL-C ≥130 mg/dL, HDL-C <40 mg/dL, TG ≥130 mg/dL, and non-HDL-C ≥145 mg/dL. Fasting values were only obtained for adolescents aged 12-19 years who had morning exams.^52^

Table 11 Multifactorial Dyslipidemia: Study Characteristics of US Cohorts Included for Key Question 2

Cohort name; Quality | N | Population | MFD definition (mg/dL) | Years of data collection | Recruitment target | Recruitment methods | Brief screening details | Fasting?
NHANES^52^; Fair | 26,047 | Youths ages 6-19 years who participated in an NHANES examination from 1999 to 2016 | TC ≥200; LDL-C ≥130; HDL-C <40; TG ≥130; Non-HDL-C ≥145 | 1999-2000 through 2015-2016 | National | Random, population-based selection | Home interviews, mobile examinations and laboratory tests in youths aged 6 to 19 years; fasting TG and apo-B in a subset of adolescents aged 12 to 19 years | Mixed^*^
HEALTHY study^110^; Fair | 6,097 | Middle school students aged 10-13 at increased risk for type 2 diabetes | TC ≥200; LDL-C ≥130; HDL-C ≤40; TG ≥130 | 2006-2009 | Multi-center | Middle schools with student populations at increased risk for type 2 diabetes, defined by authors as ≥50% eligible for free or reduced-price lunch or belonging to a racial or ethnic minority group. 6th graders invited to health screenings in fall 2006 | Fasting blood draw to assess cardiovascular risk factors | Fasting
Study of Latinos (SOL) Youth study^114^; Fair | 1,137 | Participants ages 10-16 whose parents/legal guardians participated in the Hispanic Community Health Study/Study of Latinos (HCHS/SOL) | Multiple thresholds:; NCEP ATP III:; HDL-C <40; TG ≥110; WHO:; HDL-C <35; TG ≥150; IDF (ages 10-15):; HDL-C <50 (10-15 y) HDL-C <40 (16+ y); TG ≥150 | 2012-2014 | Multi-state | All eligible children in households from the Hispanic Community Health Study/Study of Latinos from four cities (Bronx, Chicago, Miami, and San Diego). | Blood specimens taken after overnight fast | Fasting
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^; Fair | 9,694 | 4th grade students who received a cardiovascular screening | TC ≥200; HDL-C <40; non-HDL-C ≥145 | 1992-2013 | Single state | Schools were selected based on willingness to participate. | Nonfasting cholesterol screening data collected every year 1992-2013 (except 1997 and 1999). | Non-fasting
CARDIAC^109^; Fair | 99,282 | 5th grade students enrolled in West Virginia schools | LDL-C ≥130; HDL-C <40 | 1999-2016 | Single state | 5th grade students enrolled in West Virginia schools | Cardiovascular risk detection screening program including evaluation for obesity, dyslipidemia, hypertension, and prediabetes | Mixed^†^

* Fasting values only obtained for adolescents aged 12-19 who had morning examinations.

† Fasting till 1st semester 2012, thereafter, non-fasting lipids reported for abnormal lipids.

Abbreviations: CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; HDL-C = high-density lipoprotein cholesterol; IDF = International Diabetes Federation; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NCEP ATP III = National Cholesterol Education Program Adult Treatment Panel III; NHANES = National Health and Nutrition Examination Survey; TC = total cholesterol; TG = triglycerides; Trig = triglycerides; US = United States; WHO = World Health Organization

Table 12 Multifactorial Dyslipidemia: Population Characteristics of Included US Cohorts for Key Question 2

Cohort name, Year | Mean age (range) | Female, % | Race/ethnicity, % | BMI | Smoking, % | % With family history of CVD and definition | Other BL characteristic
NHANES, 1999-2016^52^ | 12^*^; (6-19) | 51 | NR | NR | NR | NR | NR
Study of Latinos (SOL) Youth study, 2012-2014^114^ | 13; (10-16) | 50 | Latino: 100; 49% Mexican,; 14% Dominican,; 10% Mixed Hispanic,; 10% Puerto Rican,; 6% Central American,; 6% Cuban; 4% South American,; 1.9% Other | NR | NR | NR
HEALTHY study, 2006-2009^110^ | 11; (10-13) | 52 | White: 19; Black: 20; Asian: NR; Native American: NR; Latino: 53; Other: 8 | Overweight, BMI percentile 85-94: 20; Obese, BMI percentile ≥95: 30 | NR | NR | Tanner stage:; 1: 10%; 2: 26%; 3: 40%; 4: 22%; 5: 2%; Metabolic risk factors:; ≥1: 46%; ≥2: 19%; ≥3: 7%
The Poudre Valley Health System (PVHS), Healthy Hearts Club, 1992-2013^112^ | 10; (NR) | 50 | Middle school student populations with ≥50% of students belonging to a racial or ethnic minority group | Overweight, BMI percentile 85-94: 13; Obese, BMI percentile ≥95: 8 | NR | NR | Middle school student populations with ≥50% of students eligible for free or reduced-price lunch
CARDIAC, 1999-2016^109^ | 11; (NR) | 53 | White: 93; Black: 3; Asian: 1; Native American: NR; Latino: 1; Other: 1 | 85-94.9 percentile: 19; 95-98.9 percentile: 28 | Smoking in the home: 34 | Heart disease, unspecified: 32; Family hx of high TC: 34 | NR

* Sample sizes and characteristics varied between cycles according to sampling strategy (e.g., intentional oversampling of adolescents in 1999-2006 and of non-Hispanic Asians in 2011-2016); n=26,047.

Abbreviations: BL = baseline; BMI = body mass index; CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CVD = cardiovascular disease; MFD = multifactorial dyslipidemia; NHANES = National Health and Nutrition Examination Survey; TC = total cholesterol

The HEALTHY study (n=6,097) recruited middle schools from seven different geographic areas with student populations at increased risk for type 2 diabetes, defined by authors as having at least 50 percent of students eligible for free or reduced-price lunch or belonging to a racial or ethnic minority group.^110^ Sixth-grade students in each school were invited to health screenings from 2006-2009, and 58 percent of all eligible students participated in screening. Abnormal fasting lipid levels were defined by the “high” cut points as described by the Expert Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents Summary Report: TC ≥200 mg/dL, LDL-C ≥130 mg/dL, TG ≥130 mg/dL, and HDL-C ≤40 mg/dL. The aim of this study was to investigate the utility of BMI to identify cardiometabolic risk and reports prevalence only by BMI strata.

The Study of Latinos (SOL)–Youth Study (n=1,137) included participants ages 10-16 years, whose parents or legal guardians previously participated in the Hispanic Community Health Study/Study of Latinos.^114^ The sample included Latino youth from four cities including New York City, Chicago, Miami, and San Diego. Data were collected between 2012 and 2014. This study explored various thresholds for abnormal lipids, with thresholds defined by the World Health Organization (WHO), the Adult Treatment Panel III report (ATP III) and the International Diabetes Federation (IDF).

The remaining two studies, The Poudre Valley Health System (PVHS) Healthy Hearts Club and CARDIAC, recruited from schools within a single state.^109,^ ^112^ The PVHS Healthy Hearts Club study (n=9,694) provided cardiovascular screening to 4^th^ grade students who attended a participating school in one of six Northern Colorado school districts from years 1992-2013.^112^ These students received nonfasting lipid screening, and authors defined thresholds for acceptable TC <170 mg/dL; borderline TC ≥170–199 mg/dL; high TC ≥200 mg/dL; low HDL-C <40 mg/dL; and high non-HDL-C ≥145 mg/dL.

CARDIAC (n=99,282) is discussed above in the FH section. Abnormal lipid values relevant for multifactorial dyslipidemia were LDL-C >130 mg/dL and HDL-C <40 mg/dL.

Participant characteristics were variably reported among these studies (Table 12). The mean ages ranged from 10 to 16 years, and approximately half were female in these cohorts. The SOL youth study was conducted in 100 percent Latino youth by design, reporting specific ethnicities as 49 percent Mexican, 14 percent Dominican, 10 percent Mixed Hispanic, 10 percent Puerto Rican, 6 percent Central American, 6 percent Cuban, and 4 percent South American.^112^ HEALTHY reported about half of participants were Latino (53%), followed by Black students (19%), White students (19%), and other race/ethnicity (8%). CARDIAC reported the majority of participants were White (93%), 3 percent were Black, 0.8 percent Latino, 0.5 percent Asian, and 0.5 percent other.^109^ BMI characteristics were reported in four studies^109,^ ^110,^ ^112^; the percent overweight (BMI 85-94^th^ percentile) ranged from 13 to 20, and the percent obese (BMI ≥95^th^ percentile) ranged from 8 to 30. HEALTHY reported that most students were in Tanner stage 3 at screening (40%), and approximately 46 percent of students had one or more cardiometabolic risk factors.^110^

#### Outcomes (Results)

No included studies used a confirmatory test, therefore diagnostic yield cannot be calculated. Outcomes reported in these studies included only screen positivity from a single screen. Furthermore, while the vast majority of individuals with abnormal lipids have multifactorial dyslipidemia, a very small proportion may have FH as there were no upper thresholds to the lipid levels.

##### High TC

Three studies reported the percentage of participants who had a TC ≥200 mg/dL and prevalence ranged from 7.1 percent to 9.4 percent (Table 13; Figure 3). Higher prevalence of abnormal TC was seen in higher BMI populations; results were mixed about differences in prevalence by sex (Figures 4–6). NHANES (2009-2016; n=10,661; mean age: 12 years) reported that 7.1 percent (95% CI, 6.4% to 7.8%) had high TC (fasting or nonfasting).^52^ In an overlapping NHANES cohort analysis (2011-2014; n=4358), adolescents ages 16-19 years had a higher prevalence of elevated TC compared to younger children ages 6-8 years (8.9% [95% CI, 7.2% to 10.5%] vs 6.0% [95% CI, 4.5% to 7.5%], p<0.05).^113^ In the same years (n=4361), the percentage of females having high TC was significantly higher than males (8.9% [95% CI, 7.6% to 10.1%] vs 5.9% [95% CI, 4.9% to 6.8%]; p<0.05).^113^ The NHANES 2009-2016 cohort analysis found that among youths aged 6-19 years, non-Hispanic Black youths had the highest prevalence of high TC (8.3% [95% CI, 7.2% to 9.3%]), followed by White (7.5% [95% CI, 6.3% to 8.7%]), and Mexican participants (6.9% [95% CI, 5.7% to 8.1%]).^52^ A smaller NHANES sample from 2011-2014 was the only publication with separate reporting for Asian populations, and found that non-Hispanic Asian youths had the highest prevalence of high TC (10.9% [95% CI, 8.0% to 13.8%]), followed by Black (9.6% [95% CI, 7.9% to 11.3%]), White (7.3% [95% CI, 5.8% to 8.9 %]), and Hispanic (6.3% [95% CI, 5.0% to 7.6%]) youths aged 6-19 years.^113^ The prevalence of high TC in Asians was significantly different (p<0.05) from both White and Hispanic participants, while the prevalence in Black youths was found to be significantly different (p<0.05) from Hispanic participants.^113^ However, these results should be interpreted with caution due to the small sample size of Asian youth. In subgroup analyses by BMI status, in 2009-2016 (n=8268), NHANES reported that children aged 6-19 years in the ≥95^th^ percentile for BMI had a higher percentage of participants with TCs ≥200 mg/dL (10.7% [95% CI, 9.0 to 12.4%]), compared with BMI percentiles 5^th^-85^th^ and 85^th^-94^th^ (5.5% [95% CI, 4.8% to 6.3%] and 7.0% [95% CI, 5.5% to 8.5%] respectively).^52,^ ^113^

Table 13 Multifactorial Dyslipidemia: Prevalence of High Total Cholesterol (TC ≥200 mg/dL)

Cohort name | Fasting status | Group | Subgroups | Time of screening | N analyzed | N screen positive | % screen positive (95% CI)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | All participants | - | 2009-2016 | 10,661 | 757 | 7.1 (6.4, 7.8)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 6-8 | 2011-2014 | 999 | 60 | 6.0 (4.5, 7.5)^‡^
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 9-11 | 2011-2014 | 1029 | 75 | 7.3 (5.7, 8.9)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 12-15 | 2011-2014 | 1182 | 80 | 6.8 (5.4, 8.2)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 16-19 | 2011-2014 | 1148 | 102 | 8.9 (7.2, 10.5)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | BMI | 5th-85th percentile | 2009-2016 | 4978 | 274 | 5.5 (4.8-6.3)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | BMI | 85th-94th percentile | 2009-2016 | 1458 | 102 | 7.0 (5.5-8.5)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | BMI | ≥95th percentile | 2009-2016 | 1832 | 196 | 10.7 (9.0-12.4)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Sex | Males | 2011-2014 | 2232 | 132 | 5.9 (4.9, 6.8)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Sex | Females | 2011-2014 | 2129 | 189 | 8.9 (7.6, 10.1)^§^
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Ethnicity/Race | Non-Hispanic White | 2009-2016 | 2299 | 172 | 7.5 (6.3, 8.7)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Ethnicity/Race | Non-Hispanic Black | 2009-2016 | 1003 | 83 | 8.3 (7.2, 9.3)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Ethnicity/Race | Mexican | 2009-2016 | 2097 | 145 | 6.9 (5.7, 8.1)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Ethnicity/Race | Non-Hispanic White | 2011-2014 | 1080 | 79 | 7.3 (5.8, 8.9)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Ethnicity/Race | Non-Hispanic Black | 2011-2014 | 1175 | 113 | 9.6 (7.9, 11.3)^¶^
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Ethnicity/Race | Non-Hispanic Asian | 2011-2014 | 435 | 47 | 10.9 (8.0, 13.8)^¶^,^#^
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Ethnicity/Race | Hispanic | 2011-2014 | 1419 | 89 | 6.3 (5.0, 7.6)
CARDIAC^109^ | Mixed^**^ | All participants | - | 1999-2016 | 55,198 | 4747 | 8.6 (8.4, 8.8)
CARDIAC^109^ | Mixed^**^ | BMI | ≤85th percentile | 1999-2016 | 28,951 | 1,766 | 6.1 (5.8, 6.4)^††^
CARDIAC^109^ | Mixed^**^ | BMI | 85th-94th percentile | 1999-2016 | 10,500 | 966 | 9.2 (8.6, 9.8)^††^
CARDIAC^109^ | Mixed^**^ | BMI | 95th-99th percentile | 1999-2016 | 12,131 | 1,577 | 13.0 (12.4, 13.6)^‡‡^
CARDIAC^109^ | Mixed^**^ | BMI | >99th percentile | 1999-2016 | 3590 | 438 | 12.2 (11.1, 13.3)^‡‡^
HEALTHY study^110^ | Fasting | BMI | <5th percentile | 2006-2009 | 91 | 6 | 6.5 (1.5, 11.7)
HEALTHY study^110^ | Fasting | BMI | 5th-79th percentile | 2006-2009 | NR | NR | 4.5 (NR)
HEALTHY study^110^ | Fasting | BMI | 80th-84th percentile | 2006-2009 | NR | NR | 5.0 (NR)
HEALTHY study^110^ | Fasting | BMI | 85th-89th percentile | 2006-2009 | NR | NR | 6.3 (NR)
HEALTHY study^110^ | Fasting | BMI | 90th-94th percentile | 2006-2009 | NR | NR | 7.5 (NR)
HEALTHY study^110^ | Fasting | BMI | ≥95th percentile | 2006-2009 | 1801 | 167 | 9.3 (8.0, 10.6)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | All participants | - | 1992-2013 | 9694 | 911 | 9.4 (8.8, 10.1)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | BMI | ≤85th percentile | 1992-2013 | 7645 | 619 | 8.1 (7.5, 8.7)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | BMI | 85th-94th percentile | 1992-2013 | 1263 | 169 | 13.4 (11.5, 15.3)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | BMI | ≥95^th^ percentile | 1992-2013 | 786 | 119 | 15.1 (12.6, 17.6)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Sex | Males | 1992-2013 | 4851 | 456 | 9.4 (8.6, 10.2)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Sex | Females | 1992-2013 | 4843 | 455 | 9.4 (8.6, 10.2)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Borderline TC ≥170–199 mg/dL | All participants | 1992-2013 | 9694 | 2545 | 26.3 (25.4, 27.2)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Borderline TC ≥170–199 mg/dL | BMI ≤85th percentile | 1992-2013 | 7645 | 1949 | 25.5 (24.5, 26.5
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Borderline TC ≥170–199 mg/dL | BMI 85th-94th percentile | 1992-2013 | 1263 | 357 | 28.3 (25.8, 30.8)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Borderline TC ≥170–199 mg/dL | BMI ≥95th percentile | 1992-2013 | 786 | 242 | 30.8 (27.6, 34.0)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Borderline TC ≥170–199 mg/dL | Males | 1992-2013 | 4851 | 1286 | 26.5 (25.2, 27.7)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Borderline TC ≥170–199 mg/dL | Females | 1992-2013 | 4843 | 1259 | 26.0 (24.8, 27.2)

* Per study authors, NHANES (1999-2016) maximal sample size was reported. N estimate was based on population-weighted data from the National Health and Nutrition Examination Survey (1999-2016).

† Fasting values only obtained for adolescents aged 12-19 who had morning examinations.

‡ FN: Significantly different from ages 16-19 (p <0.05).

§ Significantly different from boys (p <0.05).

¶ Significantly different from Hispanic (p <0.05).

# Significantly different from non-Hispanic white (p < 0.05).

** Fasting till 1st semester 2012, thereafter, non-fasting lipids reported for abnormal lipids.

†† Significantly different from other BMI subgroups, p <0.05: prevalence less than BMI 85th-94th, BMI 95th-99th and BMI >99th percentiles.

‡‡ Not significantly different from subgroup BMI >99th percentile; and significantly different from the other subgroups, p <0.05: prevalence more than BMI <85th and BMI 85th-94th percentiles.

Abbreviations: BMI = body mass index; CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CI = confidence interval; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey; TC = total cholesterol

Figure 3 Multifactorial Dyslipidemia (MFD): Prevalence of MFD in US Cohorts Included for Key Question 2

Abbreviations: CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CI = confidence interval; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey; PVHS = The Poudre Valley Health System; SOL = Study of Latinos; TC = total cholesterol; TG = triglycerides; US = United States; yrs = years

This figure shows the prevalence of Multifactorial dyslipidemia in US cohorts included for Key Question 2

Figure 4 Multifactorial Dyslipidemia (MFD): Prevalence of MFD in US Cohorts Included for Key Question 2, by Sex

Abbreviations: CI = confidence interval; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey; PVHS = The Poudre Valley Health System; SOL = Study of Latinos; TC = total cholesterol; TG = triglycerides; US = United States; yrs = years

This figure shows the prevalence of Multifactorial dyslipidemia in US cohorts included for Key Question 2, by sex

Figure 5 Multifactorial Dyslipidemia (MFD): Prevalence of MFD in US Cohorts Included for Key Question 2, by Race/Ethnicity

Abbreviations: HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey; SOL = Study of Latinos; TC = total cholesterol; TG = triglycerides; US = United States

This figure shows the prevalence of Multifactorial dyslipidemia in US cohorts included for Key Question 2, by race/ethnicity

Figure 6 Multifactorial Dyslipidemia (MFD): Prevalence of High Total Cholesterol and Low-Density Lipoprotein Cholesterol Levels in US Cohorts Included for Key Question 2, by BMI

Abbreviations: BMI = body mass index; CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CI = confidence interval; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey; PVHS = The Poudre Valley Health System; TC = total cholesterol; US = United States; yrs = years

This figure shows among the studies included for Multifactorial dyslipidemia, the prevalence of high total cholesterol and low-density lipoprotein cholesterol levels in US cohorts included for Key Question 2, by BMI

The West Virginia CARDIAC program (1999-2016) reported that a total of 4747 (8.6% [95% CI, 8.4% to 8.8%]) students had high TC.^109^ They also reported that prevalence of elevated TC (fasting or nonfasting) was greater in higher BMI categories and found that children in the ≥95^th^-99^th^ percentile had the highest prevalence of abnormal TC (13.0% [95% CI, 12.4% to 13.6%]), compared with BMI percentiles ≤85^th^, 85^th^-95^th^ and >99^th^ (6.1, 9.2, and 12.2 percent, respectively).

For the HEALTHY study (n=6097; mean age: 11 years) data are only available by BMI strata.^110^ The prevalence of high TC increased progressively with higher BMI strata, with the highest prevalence in those with BMI ≥95^th^ percentile (9.3% [95% CI, 8.0% to 10.6%]).

PVHS (n=9,694 fourth-grade students; mean age: 10 years) had an estimated prevalence of 9.4 percent (95% CI, 8.8% to 10.1%) of high, nonfasting TC in their screened cohort.^112^ Prevalence was the same (9.4% [95% CI, 8.6% to 10.2%]) in both females and males in this cohort and was highest amongst students with BMI ≥95^th^ percentile (15.1% [ 95% CI, 12.6% to 17.6%]).^112^

##### High LDL-C

Two studies reported the prevalence of high LDL-C, using a threshold of ≥130 mg/dL; these ranged from 6.4 to 7.4 percent with higher prevalence in higher BMI categories (Table 14; Figure 3). The CARDIAC cohort reported that 7.4 percent (95% CI, 7.2% to 7.6%) of 54,784 students screened in years 1999-2016 had a high LDL-C (fasting or nonfasting).^109^ More recent data from students who were screened with a nonfasting lipid profile in 2016-2017 (n=3648), showed that 3.8 percent (95% CI, 3.2% to 4.4%) had a high LDL-C.^111^ Using screening data from 1999-2016, CARDIAC explored prevalence by BMI category, and found that youth in each of the higher BMI categories had a significantly higher prevalence of high LDL-C compared to those in lower BMI categories^109^ (BMI 95^th^-99^th^ percentile: 11.4% [95% CI, 10.8% to 12.0%]; BMI >99^th^ percentile: 11.0% [95% CI, 10.0% to 12.0%] vs. BMI ≤85^th^ percentile: 4.8% [95% CI, 4.6% to 5.0%] and BMI 85^th^ −94^th^ percentile: 8.5% [95% CI, 8.0% to 9.0%], respectively) (Figure 6).^109^

Table 14 Multifactorial Dyslipidemia: Prevalence of High Low-Density Lipoprotein Cholesterol (LDL-C ≥130 mg/dL)

Cohort name | Fasting | Group | Subgroup | Time of screening | N analyzed | N screen positive | % screen positive (95% CI)
NHANES^*^,^52^ | Mixed^†^ | Age | Ages 12-19 | 2007-2014 | 2,042 | 131 | 6.4 (4.9, 7.8)
NHANES^*^,^52^ | Mixed^†^ | BMI | 5th-<85th percentile | 2007-2014 | 1,191 | 61 | 5.1 (3.5-6.6)
NHANES^*^,^52^ | Mixed^†^ | BMI | 85th-94th percentile | 2007-2014 | 332 | 23 | 6.8 (3.6-10.0)
NHANES^*^,^52^ | Mixed^†^ | BMI | ≥95th percentile | 2007-2014 | 410 | 41 | 10.0 (6.4-13.6)
NHANES^*^,^52^ | Mixed^†^ | Race | Non-Hispanic Black, ages 12-19 | 2007-2014 | 506 | 41 | 8.2 (5.9-10.6)
NHANES^*^,^52^ | Mixed^†^ | Race | Mexican, ages 12-19 | 2007-2014 | 491 | 21 | 4.3 (2.2-6.4)
NHANES^*^,^52^ | Mixed^†^ | Race | Non-Hispanic White, ages 12-19 | 2007-2014 | 594 | 46 | 7.8 (5.6-10.1)
HEALTHY^110^ | Fasting | BMI | <5th percentile | 2006-2009 | 91 | 2 | 2.2 (0.0, 5.2)
HEALTHY^110^ | Fasting | BMI | 5th-79th percentile | 2006-2009 | NR | NR | 2.8 (NR)
HEALTHY^110^ | Fasting | BMI | 80th-84th percentile | 2006-2009 | NR | NR | 3.1 (NR)
HEALTHY^110^ | Fasting | BMI | 85th-89th percentile | 2006-2009 | NR | NR | 4.4 (NR)
HEALTHY^110^ | Fasting | BMI | 90th-94th percentile | 2006-2009 | NR | NR | 5.8 (NR)
HEALTHY^110^ | Fasting | BMI | ≥95th percentile | 2006-2009 | 1,801 | 122 | 6.8 (5.6, 7.9)
CARDIAC^109,^ ^111^ | Mixed^‡^ | All participants | - | 1999-2016 | 54,784 | 4,054 | 7.4 (7.2, 7.6)
CARDIAC^109,^ ^111^ | Mixed^‡^ | All participants | - | 2016-2017 | 3,648 | 128 | 3.8 (3.2, 4.4)
CARDIAC^109,^ ^111^ | Mixed^‡^ | BMI | ≤85th percentile | 1999-2016 | 29,313 | 1,407 | 4.8 (4.6, 5.0)^§^
CARDIAC^109,^ ^111^ | Mixed^‡^ | BMI | 85th-94th percentile | 1999-2016 | 10,412 | 885 | 8.5 (8.0, 9.0)^§^
CARDIAC^109,^ ^111^ | Mixed^‡^ | BMI | 95th-99th percentile | 1999-2016 | 12,018 | 1,370 | 11.4 (10.8, 12.0)^¶^
CARDIAC^109,^ ^111^ | Mixed^‡^ | BMI | >99th percentile | 1999-2016 | 3,564 | 392 | 11.0 (10.0, 12.0)^¶^

* Per study authors, NHANES (1999-2016) maximal sample size was reported. N estimate was based on population-weighted data from the National Health and Nutrition Examination Survey (1999-2016).

† Fasting values only obtained for adolescents aged 12-19 who had morning examinations.

‡ Fasting till 1st semester 2012, thereafter, non-fasting lipids reported for abnormal lipids.

§ Significantly different than the other BMI subgroups, p <0.05: prevalence less than BMI 85th-94th, BMI 95th-99th, and BMI >99th percentiles.

¶ Not significantly different from subgroup BMI 95th-99th percentile; significantly different from the other subgroups, p <0.05: prevalence more than BMI <85th and BMI 85th-94th percentiles.

Abbreviations: BMI = body mass index; CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CI = confidence interval; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey

NHANES reported that the prevalence of high fasting or nonfasting LDL-C in youths aged 12-19 years, screened in 2007-2014 (n=2042), was 6.4 percent (95% CI, 4.9% to 7.8%).^52^ In the same years, the prevalence of high LDL-C was highest among Black youths of the same age range (8.2% [95% CI: 5.9% to 10.6%]), followed by White youths (7.8% [95% CI, 5.6% to 10.1%], and Mexican youths (4.3 % [95% CI, 2.2% to 6.4%]) (Figure 5). NHANES also found that those in the ≥95^th^ percentile for BMI had a higher percentage of participants with high LDL-C (10.0%), compared with BMI percentiles 5^th^-85^th^ and 85^th^-94^th^ (5.1% [95% CI, 3.5% to 6.6%] and 6.8% [95% CI, 3.6% to 10.0%], respectively) (Figure 6).^52^

For the HEALTHY study, prevalence is only available by BMI strata.^110^ The prevalence of high LDL-C among participants increased progressively with higher BMI. For youth in the in the ≥95^th^ percentile for BMI, the prevalence of high LDL-C was 6.8 percent (95% CI, 5.6% to 7.9%) (Figure 6).^110^

##### Abnormal HDL-C

Four studies reported the prevalence of low HDL-C levels, defined as HDL-C <40 mg/dL, and reported prevalence ranging from 12.1 to 22.2 percent, again with higher prevalence in older age groups, higher BMI categories, and in Hispanic children. (Table 15; Figures 3–5, 7). NHANES (2013-2016; n=6457) reported a 12.1% prevalence rate for low, nonfasting HDL-C (95% CI, 10.4% to 13.7%).^52^ The prevalence of abnormal HDL-C increased with age in those screened in years 2011-2014 (n=4358), estimated as 7.7 percent (95% CI, 6.0% to 9.4%) in ages 6-8 years, 10.3% (95% CI, 8.4% to 12.2%) in ages 9-11 years, 14% (95% CI, 12.0% to 16.0%) in ages 12-15 years, and 18.4% (95% CI, 16.1% to 20.6%) in ages 16-19 years.^113^ Over the same time period, the percentage of females having low HDL-C was significantly lower (p<0.05) than the percentage among males (12.0% [95% CI, 10.6% to 13.4%] vs. 14.8% [95% CI, 13.3% to 16.2%], respectively).^113^ The NHANES 2013-2016 analysis found the highest prevalence of low HDL-C among Mexican youths (14.8% [95% CI, 12.3% to 17.3%]), followed by White youths (12.5% [95% CI, 9.9% to 15.0%]), and Black youths (6.5% [95% CI, 4.9% to 8.0%]) ages 6 to 19 years.^52^ An analysis of 2011-2014 NHANES data, which provided separate reporting of Asian youths of the same age group, found that Hispanic youths had the highest prevalence for abnormal HDL-C (15.6% [95% CI, 13.7% to 17.5%]), followed by White youths (14.4% [95% CI, 12.3% to 16.5%]), Asian youths (8.2% [95% CI, 5.6% to 10.8%]), and Black youths (7.4 [95% CI, 5.9% to 8.9%]).^113^ The prevalence of abnormal HDL-C for Black and Asian youths within this sample was found to be significantly different from both White and Hispanic (p <0.05).^113^ However, these results should be interpreted with caution due to the small sample size of Asian youth. In 2013-2016 (n=4205), NHANES found those in the ≥95^th^ percentile for BMI had a higher percentage of participants with low HDL-C (29.3% [95% CI, 26.3% to 32.4%]), compared with those in the 5^th^-85^th^ percentiles for BMI and the 85^th^-94^th^ percentiles (5.7% [95% CI, 4.0% to 7.3%] and 11.5% [95% CI, 8.2% to 14.9%], respectively).^52^

Table 15 Multifactorial Dyslipidemia: Prevalence of Abnormal High-Density Lipoprotein Cholesterol Results (HDL-C <40 mg/dL)

Cohort name | Fasting status | Group | Subgroup | Time of screening | N analyzed | N screen positive | % screen positive (95% CI)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | All participants | - | 2013-2016 | 6457 | 781 | 12.1 (10.4, 13.7)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 6-8 | 2011-2014 | 999 | 77 | 7.7 (6.0, 9.4)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 9-11 | 2011-2014 | 1029 | 106 | 10.3 (8.4, 12.2)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 12-15 | 2011-2014 | 1182 | 165 | 14.0 (12.0, 16.0)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 16-19 | 2011-2014 | 1148 | 211 | 18.4 (16.1, 20.6)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Sex | Males | 2011-2014 | 2232 | 330 | 14.8 (13.3, 16.2)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Sex | Females | 2011-2014 | 2129 | 255 | 12.0 (10.6, 13.4)^‡^
NHANES^*^,^52,^ ^113^ | Mixed^†^ | BMI | 5th-<85th percentile | 2013-2016 | 2485 | 142 | 5.7 (4.0-7.3)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | BMI | 85th-94th percentile | 2013-2016 | 783 | 90 | 11.5 (8.2-14.9)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | BMI | ≥95th percentile | 2013-2016 | 937 | 275 | 29.3 (26.3-32.4)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic White | 2013-2016 | 1152 | 144 | 12.5 (9.9-15.0)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic Black | 2013-2016 | 1003 | 65 | 6.5 (4.9-8.0)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Mexican | 2013-2016 | 1049 | 155 | 14.8 (12.3-17.3)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic White | 2011-2014 | 1080 | 156 | 14.4 (12.3, 16.5)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic Black | 2011-2014 | 1175 | 87 | 7.4 (5.9, 8.9)^§^
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic Asian | 2011-2014 | 435 | 36 | 8.2 (5.6, 10.8)^§^
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Hispanic | 2011-2014 | 1419 | 221 | 15.6 (13.7, 17.5)
HEALTHY study^110^ | Fasting | BMI | <5th percentile | 2006-2009 | 91 | 2 | 2.2 (0.0, 5.2)
HEALTHY study^110^ | Fasting | BMI | 5th-79th percentile | 2006-2009 | NR | NR | 5.8 (NR)
HEALTHY study^110^ | Fasting | BMI | 80th-84th percentile | 2006-2009 | NR | NR | 9.7 (NR)
HEALTHY study^110^ | Fasting | BMI | 85th-89th percentile | 2006-2009 | NR | NR | 14.0 (NR)
HEALTHY study^110^ | Fasting | BMI | 90th-94th percentile | 2006-2009 | NR | NR | 16.0 (NR)
HEALTHY study^110^ | Fasting | BMI | ≥95th percentile | 2006-2009 | 1801 | 580 | 32.2 (30.0, 34.4)
Study of Latinos (SOL) Youth study^114^ | Fasting | <40 mg/dL | All participants | 2012-2014 | 1137 | 143 | 12.6 (10.7, 14.5)
Study of Latinos (SOL) Youth study^114^ | Fasting | <40 mg/dL | Males | 2012-2014 | 570 | 76 | 13.4 (10.6, 16.2)
Study of Latinos (SOL) Youth study^114^ | Fasting | <40 mg/dL | Females | 2012-2014 | 567 | 67 | 11.8 (9.1, 14.4)
Study of Latinos (SOL) Youth study^114^ | Fasting | <35 mg/dL | All participants | 2012-2014 | 1137 | 38 | 3.3 (2.3, 4.3)
Study of Latinos (SOL) Youth study^114^ | Fasting | <35 mg/dL | Males | 2012-2014 | 570 | 20 | 3.6 (2.1, 5.1)
Study of Latinos (SOL) Youth study^114^ | Fasting | <35 mg/dL | Females | 2012-2014 | 567 | 18 | 3.1 (1.7, 4.5)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | All participants | - | 1992-2013 | 9694 | 2152 | 22.2 (21.4, 23.0)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Sex | Males | 1992-2013 | 4851 | 1028 | 21.2 (20.0, 22.4)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Sex | Females | 1992-2013 | 4851 | 1124 | 23.2 (22.0, 24.4)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | BMI | ≤85th percentile | 1992-2013 | 7645 | 1361 | 17.8 (16.9, 18.7)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | BMI | 85th-94th percentile | 1992-2013 | 1263 | 416 | 32.9 (30.3, 35.5)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | BMI | ≥95th percentile | 1992-2013 | 786 | 373 | 47.5 (44.0, 51.0)
CARDIAC^109,^ ^111^ | Mixed^¶^ | All participants | - | 1999-2016 | 55,034 | 9851 | 17.9 (17.2, 18.6)
CARDIAC^109,^ ^111^ | Mixed^¶^ | All participants | - | 2016-2017 | 3,648 | 548 | 16.0 (14.8, 17.2)
CARDIAC^109,^ ^111^ | Mixed^¶^ | BMI | ≤85th percentile | 1999-2016 | 29,156 | 2,624 | 9.0 (8.7, 9.3)^#^
CARDIAC^109,^ ^111^ | Mixed^¶^ | BMI | 85th-94th percentile | 1999-2016 | 10,425 | 1,866 | 17.9 (17.2, 18.6)
CARDIAC^109,^ ^111^ | Mixed^¶^ | BMI | 95th-99th percentile | 1999-2016 | 12,093 | 3,761 | 31.1 (30.3, 32.0)
CARDIAC^109,^ ^111^ | Mixed^¶^ | BMI | >99th percentile | 1999-2016 | 3579 | 1,600 | 44.7 (43.1, 46.3)

* Per study authors, NHANES (1999-2016) maximal sample size was reported. N estimate was based on population-weighted data from the National Health and Nutrition Examination Survey (1999-2016).

† Fasting values only obtained for adolescents aged 12-19 who had morning examinations.

‡ Significantly different from boys (p <0.05).

§ Significantly different from Hispanic (p <0.05) and significantly different from non-Hispanic white (p < 0.05).

¶ Fasting till 1st semester 2012, thereafter, non-fasting lipids reported for abnormal lipids.

# Significantly different from other BMI subgroups, p <0.05: prevalence less than BMI 85th-94th, BMI 95th-99th and BMI >99th percentiles.

Abbreviations: BMI = body mass index; CARDIAC = Artery Risk Detection in Appalachian Communities; CI = confidence interval; HDL-C = high-density lipoprotein cholesterol; IDF = International Diabetes Federation; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NCEP ATP III = National Cholesterol Education Program Adult Treatment Panel III; NHANES = National Health and Nutrition Examination Survey; WHO = World Health Organization

Figure 7 Multifactorial Dyslipidemia (MFD): Prevalence of Abnormal High-Density Lipoprotein Cholesterol and High Triglyceride Levels in US Cohorts Included for Key Question 2, by BMI

Abbreviations: BMI = body mass index; CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CI = confidence interval; HDL-C = high-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey; PVHS = The Poudre Valley Health System; TG = triglycerides; US = United States; yrs = years

This figure shows among the studies included for Multifactorial dyslipidemia, the prevalence of abnormal high-density lipoprotein cholesterol and high triglyceride levels in US Cohorts included for Key Question 2, by BMI

CARDIAC reported that a total of 9,851 out of 55,034 students screened in years 1999-2016 had low HDL-C (17.9% [95% CI, 17.2% to 18.6%]).^109^ In their 2016-2017 cohort (n=3648), prevalence was slightly lower at 16 percent (95% CI% 14.8% to 17.2%) (548 of 3,648 students).^111^ Using screening data from 1999-2016, CARDIAC explored prevalence by BMI category, and found that students with BMI ≥99^th^ percentile have the highest prevalence: 44.7% (95% CI: 43.1% to 46.3%), followed by 31.1 percent (95% CI, 30.3% to 32.0%) among students in the BMI 95^th^-99^th^ percentile, 17.9 percent (95% CI, 17.2% to 18.6%) among students with BMI in the 85^th^-94^th^ percentile, and 9 percent (95% CI, 8.7% to 9.3%) among students with BMI ≤85^th^ percentile.^109^

The HEALTHY study screened 6,097 students in the years 2006-2009 (mean age: 11 years) and reported the prevalence of low, fasting HDL-C only by BMI strata.^110^ The prevalence of low fasting HDL-C increased progressively by BMI strata and was 32.2 percent (95% CI, 30.0% to 34.4%)in those in the ≥95^th^ percentile.^110^

The SOL Youth study (2012-2014; n=1137; mean age: 13 years) reported the prevalence of fasting low HDL-C using various cutoffs among Latino youth in years 2012-2014.^114^ Using the cutoff of HDL-C <40 mg/dL, the prevalence of low HDL-C was estimated to be 12.6 percent (95% CI, 10.7% to 14.5%). Prevalence was similar in males and females with overlapping confidence intervals (males: 13.4% [95% CI, 10.6 to 16.2], females: 11.8% [95% CI, 9.1 to 14.4]). . At a cutoff of <35 mg/dL, prevalence was 3.3 percent overall (95% CI, 2.3 to 4.3) and similar in males and females (males: 3.6% [95% CI, 2.1 to 5.1], females: 3.1% [1.7 to 4.5]).^114^

The PVHS study had an estimated 22.2 percent (95% CI, 21.4% to 23.0%) prevalence of nonfasting, low HDL-C in students screened from 1992-2013 (n=9694; mean age: 10 years).^112^ The study found the prevalence of low-HDL-C among males and females to be 21.2 percent (95% CI, 20.0% to 22.4%) and 23.2 percent (95% CI, 22.0% to 24.4%), respectively. Additionally, the study found prevalence to be highest among those in ≥95^th^ percentile for BMI (47.5% [95% CI, 44.0% to 51.0%]), followed by 32.9 percent (95% CI, 30.3% to 35.5%) in the 85^th^ – 94^th^ percentile, and 17.8 percent (95% CI, 16.9% to 18.7%) in those in ≤85th percentile for BMI.^112^

##### High TG

Four studies reported the prevalence of high TG levels; two studies defined this as TG ≥130 mg/dL, two studies used TG ≥150 mg/dL, and one study used TG ≥110 mg/dL with prevalence ranges 8.0 to 17.3 percent (Table 16; Figures 3–5, 7).

Table 16 Multifactorial Dyslipidemia: Prevalence of High Triglyceride Level Results (Various Thresholds)

TG Threshold | Cohort | Fasting | Group | Subgroup | Time of screening | N analyzed | N screen positive | % screen positive (95% CI)
≥130 mg/dL; (k=2) | NHANES^*^,^52^ | Mixed^†^ | Age | 12-19 yrs | 2007-2014 | 2045 | 209 | 10.2 (8.3, 12.1)
≥130 mg/dL; (k=2) | NHANES^*^,^52^ | Mixed^†^ | BMI | 5th-<85th percentile | 2007-2014 | 1193 | 70 | 5.9 (4.1-7.8)
≥130 mg/dL; (k=2) | NHANES^*^,^52^ | Mixed^†^ | BMI | 85th-94th percentile | 2007-2014 | 333 | 48 | 14.5 (9.8-19.2)
≥130 mg/dL; (k=2) | NHANES^*^,^52^ | Mixed^†^ | BMI | ≥95th percentile | 2007-2014 | 410 | 91 | 22.3 (17.1-27.5)
≥130 mg/dL; (k=2) | NHANES^*^,^52^ | Mixed^†^ | Race/Ethnicity | Mexican, ages 12-19 | 2007-2014 | 491 | 78 | 15.8 (12.2-19.3)
≥130 mg/dL; (k=2) | NHANES^*^,^52^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic White, ages 12-19 | 2007-2014 | 594 | 71 | 11.9 (9.6-14.3)
≥130 mg/dL; (k=2) | NHANES^*^,^52^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic Black, ages 12-19 | 2007-2014 | 506 | 24 | 4.8 (3.2-6.4)
≥130 mg/dL; (k=2) | HEALTHY study^110^ | Fasting | BMI | <5th percentile | 2006-2009 | 91 | 2 | 2.2 (0, 5.2)
≥130 mg/dL; (k=2) | HEALTHY study^110^ | Fasting | BMI | 5th-79th percentile | 2006-2009 | NR | NR | 4.8 (NR)
≥130 mg/dL; (k=2) | HEALTHY study^110^ | Fasting | BMI | 80th-84th percentile | 2006-2009 | NR | NR | 12.6 (NR)
≥130 mg/dL; (k=2) | HEALTHY study^110^ | Fasting | BMI | 85th-89th percentile | 2006-2009 | NR | NR | 12.0 (NR)
≥130 mg/dL; (k=2) | HEALTHY study^110^ | Fasting | BMI | 90th-94th percentile | 2006-2009 | NR | NR | 19.2 (NR)
≥130 mg/dL; (k=2) | HEALTHY study^110^ | Fasting | BMI | ≥95th percentile | 2006-2009 | 1801 | 524 | 29.1 (27.0, 31.2)
Elevated TG ≥150 mg/dL; (k=2) | Study of Latinos (SOL) Youth study^114^ | Fasting | All participants | - | 2012-2014 | 1137 | 91 | 8.0 (6.4, 9.6)
Elevated TG ≥150 mg/dL; (k=2) | Study of Latinos (SOL) Youth study^114^ | Fasting | Sex | Males | 2012-2014 | 570 | 54 | 9.5 (7.1, 11.9)
Elevated TG ≥150 mg/dL; (k=2) | Study of Latinos (SOL) Youth study^114^ | Fasting | Sex | Females | 2012-2014 | 567 | 36 | 6.4 (4.4, 8.4)
Elevated TG ≥150 mg/dL; (k=2) | CARDIAC^109^ | Mixed^‡^ | All participants | - | 1999-2016 | 55,034 | 6384 | 11.6 (11.3, 11.9)
Elevated TG ≥150 mg/dL; (k=2) | CARDIAC^109^ | Mixed^‡^ | BMI | ≤85th percentile | 1999-2016 | 28,780 | 1,180 | 4.1 (3.9, 4.3)
Elevated TG ≥150 mg/dL; (k=2) | CARDIAC^109^ | Mixed^‡^ | BMI | 85th-94th percentile | 1999-2016 | 10,443 | 1,274 | 12.2 (11.6, 12.8)
Elevated TG ≥150 mg/dL; (k=2) | CARDIAC^109^ | Mixed^‡^ | BMI | 95th-99th percentile | 1999-2016 | 12,090 | 2,817 | 23.3 (22.5, 24.1)
Elevated TG ≥150 mg/dL; (k=2) | CARDIAC^109^ | Mixed^‡^ | BMI | >99th percentile | 1999-2016 | 3579 | 1,113 | 31.1 (29.6, 32.6)
≥110 mg/dL; (k=1) | Study of Latinos (SOL) Youth study^114^ | Fasting | All participants | - | 2012-2014 | 1137 | 197 | 17.3 (15.1, 19.5)
≥110 mg/dL; (k=1) | Study of Latinos (SOL) Youth study^114^ | Fasting | Sex | Males | 2012-2014 | 570 | 101 | 17.7 (14.6, 20.8)
≥110 mg/dL; (k=1) | Study of Latinos (SOL) Youth study^114^ | Fasting | Sex | Females | 2012-2014 | 567 | 96 | 16.9 (13.8, 20.0)

* Per study authors, NHANES (1999-2016) maximal sample size was reported. N estimate was based on population-weighted data from the National Health and Nutrition Examination Survey (1999-2016).

† Fasting values only obtained for adolescents aged 12-19 who had morning examinations.

‡ Fasting till 1st semester 2012, thereafter, non-fasting lipids reported for abnormal lipids.

Abbreviations: BMI = body mass index; CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CI = confidence interval; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey; TG = triglycerides

TG ≥130 mg/dL. NHANES 2007-2014 (n=2045) reported the prevalence of high TG (fasting and nonfasting) in youths aged 12-19 years as 10.2 percent (95% CI, 8.3% to 12.1%).^52^ From the same cohort, prevalence of high TG was highest among Mexican youths (15.8% [95% CI, 12.2% to 19.3%), followed by 11.9 percent (95% CI, 9.6% to 14.3%) in White youths, and 4.8 percent (95% CI, 3.2% to 6.4%) in Black youths. NHANES also found that those in the ≥95^th^ percentile for BMI had a higher percentage of participants with high TG (22.3% [95% CI, 17.1% to 27.5%]), compared with BMI percentiles 5^th^-85^th^ and 85^th^-94^th^ (5.9% [95% CI, 4.1% to 7.8%] and 14.5% [95% CI, 9.8% to 19.2%], respectively).^52^

The HEALTHY study of 6,097 youths (mean age: 11 years) screened in years 2006-2009 reports the prevalence of high fasting TG only by BMI strata.^110^ The study reported progressively higher prevalence with increasing BMI strata with a prevalence of 29.1 percent (95% CI, 27.0% to 31.2%) for those in the ≥95^th^ percentile for BMI.^110^

TG ≥150 mg/dL. CARDIAC (1999-2016) reported that 6384 of 55,034 students (11.6% [95% CI, 11.3% to 11.9%]) had high TG.^109^ In the same cohort, CARDIAC explored prevalence by BMI category, and found students in the BMI ≥99^th^ percentile had the highest prevalence (31.1% [95% CI, 29.6% to 32.6%]), followed by 23.3 percent (95% CI, 22.5% to 24.1%) among students in the BMI 95^th^-99^th^ percentile, 12.2 percent (95% CI, 11.6% to 12.8%) among students in the BMI 85^th^-94^th^ percentile, and 4.1 percent (95% CI, 3.9% to 4.3%) for students in the BMI ≤85^th^ percentile.^109^

The SOL Youth study had an estimated 8.0 percent prevalence (95% CI, 6.4% to 9.6%) of high, nonfasting TG among Latino youths in years 2012-2014 (n=1137; mean age: 13 years).^114^ The prevalence point estimate was higher for males than females, but confidence intervals overlapped (males: 9.5% [95% CI, 7.1 to 11.9]; females: 6.4% [95% CI, 6.4 to 8.4]).^114^

TG ≥110 mg/dL. The SOL Youth study had an estimated 17.3 percent prevalence (95% CI, 15.1% to 19.5%) of high, nonfasting TG among Latino youths in years 2012-2014 (n=1137; mean age: 13 years) using a lower threshold of ≥110 mg/dL.^114^ Prevalence was similar in males and females with overlapping confidence intervals (males: 17.7% [95% CI, 14.6 to 20.8]; females: 16.9 [95% CI: 13.8 to 20.0])..^114^

##### Abnormal Non-HDL-C

Two studies reported abnormal non-HDL-C lipid levels, defined as ≥145 mg/dL; the prevalence was 6.4 percent and 13.0 percent, with higher prevalence associated with increasing age, and higher BMI categories (Table 17; Figures 3–5). NHANES (2013-2016, n=6456) reported the prevalence of nonfasting high non-HDL-C as 6.4 (95% CI, 5.6% to 7.3%).^52^ The prevalence of high non-HDL-C increased with age in those screened in years 2011-2014 (n=4358), ranging from 6.3 percent (95% CI, 4.8% to 7.8%) in ages 6-8 through 12.0 percent (95% CI, 10.1% to 13.9%) in ages 16-19; the prevalence of non-HDL-C in the oldest age group was found to be significantly different from ages 6-8 years, 9-11 years, and 12-15 years (p <0.05).^113^ In the cohort (n=4361), the percent of females having high non-HDL-C was significantly higher (p<0.05) than in males (9.4% [95% CI, 8.1% to 10.6%] vs. 7.5% [95% CI, 6.4% to 8.6%], respectively.^113^ An analysis of 2013-2016 NHANES data found the highest prevalence among Mexican youths (7.4% [95% CI, 6.4% to 8.3%]), followed closely by White youths (7.1% [95% CI, 5.7% to 8.5%]), and Black youths (5.6% [95% CI, 3.7% to 7.4%]).^52^ A separate NHANES analysis of 2011-2014 cohort data that had separate reporting on Asian youths, found that Asian youths had the highest prevalence of non-HDL-C abnormalities (10.4% [95% CI, 7.5% to 13.3%]), followed by Hispanic (8.7% [95% CI, 7.2% to 10.2%]), White (8.5% [95% CI, 6.8% to 10.2%]), and Black youths (8.2% [95% CI, 6.6% to 9.8%]).^113^ However, these results should be interpreted with caution due to the small sample size of Asian youth. In 2013-2016 (n=4205), NHANES found those in the ≥95^th^ percentile for BMI had a higher percentage of participants with high non-HDL-C (14.1% [95% CI, 11.7% to 16.5%]), compared with 5^th^-85^th^ and 85^th^-94^th^ BMI percentiles (2.8% [95% CI, 2.0% to 3.6%] and 8.9% [95% CI, 6.7% to 11.1%], respectively).^52^

Table 17 Multifactorial Dyslipidemia: Prevalence of Abnormal Non-High-Density Lipoprotein Results (Non-HDL-C ≥145 mg/dL)

Cohort | Fasting | Group | Subgroup | Time of screening | N analyzed | N screen positive | % screen positive (95% CI)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | All participants | - | 2013-2016 | 6456 | 413 | 6.4 (5.6, 7.3)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 6-8 | 2011-2014 | 999 | 63 | 6.3 (4.8, 7.8)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 9-11 | 2011-2014 | 1029 | 73 | 7.1 (5.5, 8.7)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 12-15 | 2011-2014 | 1182 | 83 | 7.0 (5.5, 8.4)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Age | Ages 16-19 | 2011-2014 | 1148 | 138 | 12.0 (10.1, 13.9)^‡^
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Sex | Males | 2011-2014 | 2232 | 167 | 7.5 (6.4, 8.6)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Sex | Females | 2011-2014 | 2129 | 200 | 9.4 (8.1, 10.6)^§^
NHANES^*^,^52,^ ^113^ | Mixed^†^ | BMI | 5th-<85th percentile | 2013-2016 | 2485 | 70 | 2.8 (2.0-3.6)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | BMI | 85th-94th percentile | 2013-2016 | 783 | 70 | 8.9 (6.7-11.1)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | BMI | ≥95th percentile | 2013-2016 | 937 | 132 | 14.1 (11.7-16.5)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic White | 2013-2016 | 1152 | 82 | 7.1 (5.7, 8.5)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic Black | 2013-2016 | 1003 | 56 | 5.6 (3.7, 7.4)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Mexican | 2013-2016 | 1049 | 78 | 7.4 (6.4, 8.3)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic White | 2011-2014 | 1080 | 92 | 8.5 (6.8, 10.2)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic Black | 2011-2014 | 1175 | 96 | 8.2 (6.6, 9.8)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Non-Hispanic Asian | 2011-2014 | 435 | 45 | 10.4 (7.5, 13.3)
NHANES^*^,^52,^ ^113^ | Mixed^†^ | Race/Ethnicity | Hispanic | 2011-2014 | 1419 | 123 | 8.7 (7.2, 10.2)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | All participants | - | 1992-2013 | 9694 | 1255 | 13.0 (12.3, 13.7)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Sex | Males | 1992-2013 | 4851 | 630 | 13 (12.0, 13.9)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | Sex | Females | 1992-2013 | 4843 | 625 | 12.9 (12.0, 13.8)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | BMI | 5th-<85th percentile | 1992-2013 | 7645 | 795 | 10.4 (9.7, 11.1)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | BMI | 85th-94th percentile | 1992-2013 | 1263 | 248 | 19.6 (17.4, 21.8)
The Poudre Valley Health System (PVHS), Healthy Hearts Club^112^ | Nonfasting | BMI | ≥95th percentile | 1992-2013 | 7645 | 212 | 27.0 (23.9, 30.1)

* Per study authors, NHANES (1999-2016) maximal sample size was reported. N estimate was based on population-weighted data from the National Health and Nutrition Examination Survey (1999-2016).

† Fasting values only obtained for adolescents aged 12-19 who had morning examinations.

‡ Significantly different from ages 6-8, 9-11, and 12-15 (p <0.05).

§ Significantly different from boys (p <0.05).

Abbreviations: BMI = body mass index; CI = confidence interval; HDL-C = high-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey

The PVHS study had an estimated 13.0 percent prevalence (95% CI, 12.3% to 13.7%] of high nonfasting non-HDL-C among participants screened in years 1992-2013 (n=9694; mean age: 10 years).^112^ The prevalence of high non-HDL-C was almost the same between males and females (13% [95% CI, 12.0% to 13.9%] vs. 12.9% [95% CI, 12.0% to 13.8%], respectively). Additionally, these authors found prevalence to be highest among those in ≥95^th^ percentile for BMI (27.0% [95% CI, 23.9% to 30.1%]), followed by 19.6 percent (95% CI: 17.4% to 21.8%) in the 85^th^ – 94^th^ percentile, and 10.4 percent (95% CI, 9.7% to 11.1%) in those in ≤85th percentile for BMI.^112^

##### Any Abnormal Lipid Value

One study reported that 19.2 percent of participants had one or more abnormal lipid levels in TC, HDL-C, or non-HDL-C; this study included children of different ages and variable thresholds for abnormal lipids (Table 18). NHANES (2013-2016; n=4381; age range 6-19 years) reported that 19.2 percent (95% CI, 17.6% to 20.8%) of all participants screened positive for abnormal fasting or nonfasting lipid values, which they defined as TC ≥200 mg/dL, HDL-C <40 mg/dL, or non-HDL ≥145 mg/dL.^52^ Within this sample, NHANES found that older children, ages 12-19 years, had a higher percentage of abnormal lipid levels compared with children ages 6-11 years (21.8% [95% CI, 19.6% to 24.0%] vs 15.2% [95% CI, 13.1% to 17.3%] respectively).

Table 18 Multifactorial Dyslipidemia: Prevalence of Any Abnormal Lipid Level and Combination of Abnormal Lipid Values

Definition; (lipid values in mg/dL) | Cohort | Fasting | Group | Subgroup | Time of screening | N analyzed | N screen positive | % Screen positive (95% CI)
Abnormal HDL-C, non-HDL-C, or TC; TC ≥200; HDL-C <40; Non-HDL-C ≥145 | NHANES^*^,^52^ | Mixed | All participants | - | 2013-2016 | 4381 | 841 | 19.2 (17.6, 20.8)
Abnormal HDL-C, non-HDL-C, or TC; TC ≥200; HDL-C <40; Non-HDL-C ≥145 | NHANES^*^,^52^ | Mixed | Age | 6-11 yrs | 2013-2016 | 2041 | 310 | 15.2 (13.1, 17.3)
Abnormal HDL-C, non-HDL-C, or TC; TC ≥200; HDL-C <40; Non-HDL-C ≥145 | NHANES^*^,^52^ | Mixed | Age | 12-19 yrs | 2013-2016 | 2340 | 510 | 21.8 (19.6, 24.0)
Abnormal LDL-C and HDL-C; LDL-C >130; HDL-C <40 | CARDIAC^109^ | Mixed | All participants | - | 1999-2016 | 99,282 | 24,821 | 25.0 (24.7, 25.3)

* Per study authors, NHANES (1999-2016) maximal sample size was reported. N estimate was based on population-weighted data from the National Health and Nutrition Examination Survey (1999-2016).

Abbreviations: CARDIAC = Coronary Artery Risk Detection in Appalachian Communities; CI = confidence interval; HDL-C = high-density cholesterol; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NHANES = National Health and Nutrition Examination Survey; TC = total cholesterol

##### Combination of Abnormal Lipid Values

One study reported a threshold of a combination of abnormal LDL-C and HDL-C (Table 18). The West Virginia CARDIAC program (1999-2016; n=99,282; mean age 11 years) reported that 25.0 percent (95% CI, 24.7% to 25.3%) of all fifth grade participants screened positive for abnormal, fasting or nonfasting lipid values defined as a combination of an LDL-C >130 mg/dL and HDL-C <40 mg/dL.^109^

## KQ3 What Are the Harms of Screening for FH or Multifactorial Dyslipidemia in Children and Adolescents?

### Summary of Findings

No studies meeting criteria were identified.

### FH

No studies meeting criteria were identified.

### Multifactorial Dyslipidemia

No studies meeting criteria were identified.

## KQ4 Does Treatment of FH or Multifactorial Dyslipidemia With Behavioral Interventions, Lipid-Lowering Medications, or Both in Children and Adolescents Delay or Reduce the Incidence of Health Outcomes (e.g., CVD Events or Mortality) or Improve Intermediate Outcomes (e.g., Serum Lipid Levels and Atherosclerotic Markers) in Children, Adults, or Both?

### Summary of Findings

#### FH

No treatment trials reported long-term health outcomes. We included 22 fair- to good-quality trials (n=2257) examining the effectiveness of various lipid lowering treatments for FH including pharmacotherapy, behavioral counseling, and dietary supplements. Overall, this evidence body demonstrated that pharmacotherapy appears beneficial for TC and LDL-C outcomes with variable and mixed results for TG and HDL-C, with the largest evidence available for statins; behavioral counseling was not effective; and supplements showed mixed results with the best evidence supporting plant sterol spreads. Treatment trials in FH populations represented a heterogeneous set of interventions with differing doses, formulations, and intensities. Trials were generally small, short-term, and none reported health outcomes. Nearly all drug trials were industry funded.

Ten fair- to good-quality randomized, controlled trials (RCTs) (n=1230) of statins comprised the largest body of evidence addressing FH treatment with followup for up to 2 years, but only one trial is new in this update. Pooled analyses demonstrated that statins were associated with an 81-82 mg/dL greater mean difference in TC and LDL-C compared to placebo at up to 2 years followup (TC: k= 7, n=706, mean difference (MD) in change −82.1 mg/dL [95% CI −101.1 to −63.2], I^2^ 83.0%; LDL-C: k= 8, n=742, MD in change −81.3 mg/dL [95% CI, −97.6 to −65.0, I^2^ 81.6%]). Within-trial comparisons demonstrated that higher doses were generally associated with greater reductions in TC and LDL-C compared to lower doses, but confidence intervals overlapped. Pooled analysis showed no statistically significant difference in HDL-C (k=6, n=643, MD in change 1.6 mg/dL [95% CI −0.2 to 3.4], I^2^ 0%]). We included one good- and two fair-quality bile acid sequestrant trials (n=332) (none newly identified) that demonstrated that this drug was generally associated with a significantly greater reduction in TC compared to placebo ranging from −22.1 to −40.6 mg/dL and LDL-C ranging from −13.2 to −45.9 mg/dL at 8 weeks. Bile acid sequestrants were not associated with statistically significant reductions in TG and results were mixed for HDL-C, with some variation in effect by dose. We included one good-quality ezetimibe trial (n=138) showing a statistically significant reduction in TC (MD in change-64.0 mg/dL [95% CI, −81.1 to −46.9]), LDL-C (MD in change −63.0 mg/dL [95% CI, −79.5 to −46.5]), and non-HDL-C (MD in change −65.0 mg/dL [95% CI, −82.2 to −47.8]). Changes in HDL-C and TG were not significant.

We included one very small newly included fair-quality fibrate trial (n=14) reporting a statistically significant improvement in TC (MD in change −84.9 mg/dL [95% CI, −126.2 to −43.6]) but not HDL-C or TG at 13 weeks; however, this drug is not available in the U.S and not FDA-approved in children. One new good-quality PCSK9 inhibitor trial (n=158) demonstrated that evolocumab was associated with a statistically significant reduction in LDL-C as measured by percent change (−38.3% [95% CI, −45.5% to −31.1%]) and absolute mean change (−68.6 mg/dL [95% CI, −83.1 to −54.0]) with greater achievement of goal LDL-C <100 mg/dL (62.5% vs 2.3%, ARD 60.2% [95% CI, 49.6 to 70.9]) at 24 weeks. We included one previously included trial of combination drug therapy of a statin plus ezetimibe compared to a statin alone (n=248) showing that the two drug intervention was associated with a greater reduction in TC (MD in change −40.1 mg/dL [95% CI, −51.1 to −29.2]), LDL-C (MD in change −37.5 mg/dL [95% CI, −48.0 to −27.0]), TG (−9.5 median difference in percent change, p<0.01), and non-HDL-C (MD −40.0 mg/dL [95% CI, −51.0 to −28.9]) compared to the single-drug intervention control group at 33 weeks.

We included one very small, fair-quality behavioral counseling trial in an FH population (n=21) which was newly identified that reported no statistically significant improvement in lipid levels, overlapping confidence intervals for physical activity outcomes, and mixed results for dietary outcomes at 12 weeks.

We included four fair-quality randomized crossover supplement trials (n=116) in FH populations; all were newly identified trials. The two trials of plant sterol food spreads demonstrated statistically significant reductions of 20.5 to 30.5 mg/dL in TC and 22.4 to 30.1 mg/dL in LDL-C at 4 to 8 weeks. The 2 trials of omega-3 fatty acids did not show a statistically significant difference in lipid level changes between the intervention and control groups.

#### Multifactorial Dyslipidemia

No treatment trials reported long-term health outcomes. We included four fair- to good-quality trials (n=1,008) examining the effectiveness of various lipid lowering treatments for multifactorial dyslipidemia. Overall, this body of evidence showed that behavioral counseling interventions were associated with non-sustained, short-term TC and LDL-C reductions with some improvements in dietary intake. Dietary interventions were heterogenous with variable intensity, duration, and followup; supplements did not improve lipid outcomes based on small, short-term studies.

There were no included trials of drug interventions in child and adolescent populations with multifactorial dyslipidemia. We included two behavioral counseling trials (n=934), including one fair-quality newly identified trial and one good-quality previously included trial. The trials represented heterogeneous dietary interventions with variable intensity, duration and followup. These trials demonstrated 3-6 mg/dL short-term statistically significant greater reductions in TC and LDL-C and improvements in dietary intake outcomes in the intervention group compared to the control group, but findings did not persist at longer followup. The trial with the more intensive intervention reported significantly greater reductions in TC and LDL-C at 3 years compared to the control group (TC: MD −3.3 mg/dL [95% CI, −6.4 to −0.2]; LDL-C: MD −3.3 mg/dL [95% CI, −6.0 to −0.6]) but not at 7.4 years (TC: MD −1.1 [95% CI −5.0 to 2.8]; LDL-C: MD −1.9 [95% CI −4.7 to 0.9)]). The trial with the less intensive, home-based intervention reported statistically significant LDL-C reduction compared to the control group at 3 months (MD −6.7 mg/dL (CIs not available), p<0.05), however, differences were no longer significant at 1 year.

We included two small, fair-quality supplement intervention trials (n=74) examining flaxseed and fish oil in populations with multifactorial dyslipidemia; one of these trials was newly identified. Both studies had short duration of 4 to 8 weeks. These trials reported no statistically significant difference in TC or LDL-C, and flaxseed was associated with a statistically significant worsening of TG and HDL-C in the intervention group. There were no differences in BMI or total caloric intake.

#### Multifactorial Dyslipidemia/FH

We included seven fair- to good-quality supplement trials (n=288) in populations of children and adolescents with FH or multifactorial dyslipidemia which evaluated a wide range of supplement interventions. Overall, there was insufficient evidence to make conclusions about the effectiveness of supplements to improve lipid or other outcomes with one to three trials for each supplement type and short duration trials of 5 to 16 weeks.

All studies were newly identified. Only one trial, which evaluated the fiber glucomannan, showed a statistically significant improvement in TC, LDL-C, and non-HDL-C (−10 to −11 mg/dL). Two other fiber trials, however, showed no statistically significant improvements in TC or LDL-C. One psyllium fiber trial showed a 60.2 mg/dL reduction in TG while other fiber trials showed no difference in TG. A hempseed trial showed no statistically significant reductions in any lipid parameter.

### FH

#### Drug Therapy Intervention: Statins

##### Trial and Participant Characteristics

We identified eight fair-^115–122^ and two good-^123,^ ^124^ quality trials (n=1,230) that examined the effectiveness of statin treatment in children and adolescents with FH. One trial was newly identified in this update.^115^ Overall, the evidence is relatively dated. When data collection years were reported they ranged from 1990 to 2014; trials that did not report data collection years were published between 1998 and 2003. Five trials were multinational,^115,^ ^117–119,^ ^121^ one was conducted in the US,^124^ three in the Netherlands,^116,^ ^122,^ ^123^ and one in Canada.^120^ Trial sizes were generally small, ranging from 50^122^ to 214.^123^ FH criteria varied and included a combination of one or more genetic, serum lipid, or family history criteria (Figure 8; Table 19). Most trials did not report recruitment setting or method; one trial reported recruitment from a lipid clinic^120^ and one trial reported recruitment of a consecutive sample of treatment-naïve patients from an academic center.^123^

Figure 8 Familial Hypercholesterolemia (FH): Statin Intervention Trials—FH Criteria Reported (Key Question 4)

Abbreviations: CAD = coronary artery disease; CVD = cardiovascular disease; FH = familial hypercholesterolemia; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; TC = total cholesterol

This figure shows the criteria for Familial hypercholesterolemia among included statin intervention trials (key question 4)

Table 19 Familial Hypercholesterolemia: Statin Intervention Trials—Study Characteristics (Key Question 4)

Prior Include | Author, Year; Study Name; Quality | Brief Population Description^*^ | FH Criteria | Country | Years of Data Collection | N
X | Avis, 2010^119^; PLUTO; Fair | Adolescents aged 10-17 years in Tanner stage ≥II | Genetic test; fasting LDL-C ≥190 mg/dL; or LDL-C >160 mg/dL if there was a family history of premature CVD or if the patient had ≥2 other risk factors for CVD | Multinational | 2006-2008 | 177
| Braamskamp, 2015^115^; PASCAL; Fair | Children and adolescents aged 6-17 years with LDL-C ≥160 mg/dL, or ≥130 mg/dL with ≥1 risk factor | Genetic testing; non-FH children eligible if LDL-C ≥160 mg/dL or ≥130 mg/dL with ≥1 risk factors^†^ | Multinational | 2012-2014 | 106
X | Clauss, 2005^124^; Good | Postmenarchal adolescent females aged 10-17 years | 1 parent with FH; LDL-C 160-400 mg/dL and TG <350 mg/dL | US | 1999-2000 | 54
X | Couture, 1998^120^; Fair | Children and adolescents aged 8-17 years | Plasma LDL-C >95th percentile for age and sex while on lipid-lowering diet; all had genetic confirmation | Canada | NR | 63
X | de Jongh, 2002a^121^; Fair | Children and adolescents aged 10 to 17 years | LDL-C 158-398 mg/dL and 1 parent with confirmed diagnosis of heFH | Multinational | NR | 175
X | de Jongh, 2002b^122^; Fair | Children and adolescents aged 9-18 years | LDL-C >95th percentile for age and sex; documented family history of hyperlipidemia with LDL-C >95th percentile for age and gender before treatment, or a personal diagnosis of FH by genetic test | Netherlands | NR | 50
X | Knipscheer, 1996^116^; Fair | Children and adolescents aged 8-16 | Plasma LDL-C >95th percentile for age and sex during lipid-lowering diet and hypercholesterolemia present in siblings, parents, or grandparents, or clinical manifestations of premature atherosclerosis <50 y in 1st or 2nd degree relatives. | Netherlands | NR | 72
X | McCrindle, 2003^118^; Fair | Adolescents aged 10-17 years with FH or severe hypercholesterolemia and Tanner stage ≥2 | Known FH or severe hypercholesterolemia and plasma LDL-C ≥190 mg/dL or plasma LDL-C concentrations ≥160 mg/dL and a positive family history of FH or documented premature CV disease in a 1st or 2nd degree relative; TG levels ≤400 mg/dL^‡^ | Multinational | NR | 187
X | Stein, 1999^117^; Fair | Adolescent males aged 10-17 years | LDL-C ≥189 to 503 mg/dL after ≥4 months AHA diet and ≥1 parent had LDL-C value of ≥189 mg/dL not associated with a disorder known to cause secondary LDL-C elevation, or if LDL-C values were ≥220 to 503 mg/dL and a parent had died of CAD with no available lipid values | Multinational | 1990-1994 | 132
X | Wiegman, 2004^123^; Good | Children and adolescents aged 8-18 years | 1 parent with definite clinical or molecular diagnosis of FH; 2 fasting samples with LDL-C levels ≥155 mg/dL and TG levels <350 mg/dL after 3 months on fat-restricted diet | Netherlands | 1997-2001 | 214

* Defining adolescent as age 10-19 years based on WHO, however some have argued for broader definition.^203^

† 97.2% of study population had FH and results were not stratified by FH/MF, so this study is categorized as FH.

‡ Distribution of FH vs. MFD NR; assuming primarily FH based on baseline LDL-C 221.5 mg/dL.

Abbreviations: AHA = American Heart Association; CAD = coronary artery disease; CV = cardiovascular; CVD = cardiovascular disease; FH= familial hypercholesterolemia; heFH = heterozygous familial hypercholesterolemia; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; RCTs = randomized controlled trials; TG = triglycerides; US = United States

Mean age ranged from 11^115^ to 15^122,^ ^124^ years and the total age range of eligible participants was 6 to 18 years (Figure 9; Table 20).^122,^ ^124^ One trial had all female participants^124^ and one was exclusively male^117^; percent female ranged from 31^118^ to 55^115^ in the remaining trials. The five trials^116–119,^ ^124^ reporting race and ethnicity indicated that the vast majority of participants were White, ranging from 80^124^ to 93 percent.^119^ In the three trials reporting smoking history-^117,^ ^122,^ ^123^ smoking ranged from 0^122^ to 11 percent.^123^ Where reported,^117,^ ^119,^ ^123^ family history of premature CAD/CVD was common, ranging from 34^123^ to 89^119^ percent. Two trials reported baseline Tanner staging showing a wide range in sexual maturity of participants in the study. All trials reported baseline fasting lipid values. Ranges of mean fasting lipid values were: TC 274^121,^ ^122^ to 316^117^; LDL-C 208^121,^ ^122^ to 250^117^; HDL-C 44^117^ to 52^115^ and TG 62^116^ to 111^117^ (Figure 10).

Figure 9 Familial Hypercholesterolemia: All Treatment Intervention Trials—Mean Age and Age Ranges, by Intervention (Key Question 4)

Abbreviations: DHA = Docosahexaenoic acid; PCSK9 = Proprotein convertase subtilisin/kexin type 9

For Familial hypercholesterolemia, this figure shows the mean age and age ranges, by intervention (Key Question 4) in all treatment intervention trials.

Table 20 Familial Hypercholesterolemia: Statin Intervention Trials—Population Characteristics (Key Question 4)

Author, Year | Mean age, years (age range) | % Female | Race/ethnicity | % Smoking | % With family history of CVD and definition | Mean fasting TC (mg/dL) | Mean fasting LDL-C (mg/dL) | Mean fasting HDL-C (mg/dL) | Mean fasting TG (mg/dL)
Avis, 2010^119^; PLUTO | 14 (10-17) | 45 | White: 93; Black: NR; Asian: NR; Native American: NR; Latino: NR; Other: NR | NR | 89% family hx of premature CVD | 298 | 233 | 47 | 81^*^
Braamskamp, 2015^115^; PASCAL | 11 (6-17) | 55 | NR | NR | NR | 303 | 234 | 52 | 76^*^
Clauss, 2005^124^ | 15 (10-18) | 100 | White: 80; Black: NR; Asian: NR; Native American: NR; Latino: NR; Other: NR | NR | NR | 282 | 211 | 48 | 105
Couture, 1998^120^ | 13 (8-17) | 41 | NR | NR | NR | 287 | 223 | 45 | 98
de Jongh, 2002a^121^ | 14 (10-17) | 43 | NR | NR | NR | 274 | 208 | 46 | 80^†^
de Jongh, 2002b^122^ | 15 (9-18) | 48 | NR | 0 | NR | 274 | 208 | 50 | NR^‡^
Knipscheer, 1996^116^ | 12 (8-16) | 35 | White: 92; Black: 7; Asian: 1; Native American: 0; Latino: 0; Other: 0 | NR | NR | 301 | 247 | 46 | 62
McCrindle, 2003^118^ | 14 (10-17) | 31 | White: 92; Black: 2; Asian: 2; Native American: NR; Latino: NR; Other: 5 | NR | NR | 288 | 222 | 46 | 104
Stein, 1999^117^ | 13 (10-17) | 0 | White: 93; Black: NR; Asian: NR; Native American: NR; Latino: NR; Other: NR | 3 | Evidence of CAD: 37; 37% family history of evidence of CAD | 316 | 250 | 44 | 111
Wiegman, 2004^123^ | 13 (8-18) | 53 | NR | 11 | 34% family hx of premature CVD | 301 | 238 | 48 | 67^*^

* Calculated as a mean of IG and CG medians (this calculation was only made if sample sizes were >100).

† Median.

‡ Median (IQR) in IG: 70 (44–161) mg/dL; CG: 95 (30–159) mg/dL. Cannot calculate overall mean due to sample size.

Abbreviations: BL = baseline; CAD = coronary artery disease; CVD = cardiovascular disease; FH= familial hypercholesterolemia; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; RCTs = randomized controlled trials; TC = total cholesterol; TG = triglycerides

Figure 10 Familial Hypercholesterolemia (FH): Statin Intervention Trials—Baseline Lipid Levels (Key Question 4)

Note: Each circle corresponds to the mean lipid level at baseline for an individual study.

Abbreviations: HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; TC = total cholesterol; TG = triglycerides

For Familial hypercholesterolemia, this figure shows the baseline lipid levels for statin intervention trials (Key Question 4)

##### Intervention Characteristics

The trials administered various statin types and doses including Atorvastatin 10-20 mg,^118^ Lovastatin 10-40 mg,^117,^ ^124^ Pravastatin 5-40 mg,^116,^ ^123^ Pitavastatin 1-4 mg,^115^ Rosuvastatin 5-20 mg,^115^ and Simvastatin 10-40 mg (Figure 11; Table 21).^120–122^ Three trials had multiple intervention arms with different statin doses in addition to the placebo arm.^115,^ ^116,^ ^119^ Drug intensity, as defined by AHA/ACC guidelines for adults,^31^ was low to moderate in these trials, with the exception of one high-intensity arm in the trial by Avis and colleagues (Rosuvastatin 20 mg).^119^ Five trials had drug titration protocols.^117,^ ^118,^ ^121,^ ^122,^ ^124^ All trials had 4-12 week run-in diets which were typically followed the fat-restricted, NCEP Step 1 diet guidelines (Appendix A Table 4). Some trials specifically advised that all participants maintain the diet during the trial period.^117,^ ^118,^ ^120,^ ^123,^ ^124^ Followup measures occurred immediately following the completion of the treatment and ranged from 6^120^ to 104 weeks^123^ (Figure 12). LDL-C treatment goals were established in only four trials and varied: LDL-C <110 mg/dL,^115,^ ^119^ ≤130 mg/dL,^118^ and <95^th^ percentile for age and sex.^116^ The control groups received placebo in all trials. Adherence to treatment was high in the three reporting trials. Even the longest 104-week trial reported that overall, 87 percent of pills were taken^123^; the second trial reported an overall 93 percent adherence at 12-week followup^116^ and the third trial reported that 88 to 91 percent of participants in the three intervention arms took ≥80% of pills at 12-week followup.^119^

Figure 11 Familial Hypercholesterolemia: Statin Intervention Trials—Daily Dose in Each Trial (Key Question 4)

Abbreviation: mg = milligram

For Familial hypercholesterolemia, this figure show the Daily dose in each statin intervention trial (Key Question 4)

Table 21 Familial Hypercholesterolemia: Statin Interventions—Intervention Characteristics (Key Question 4)

Author, Year; Study Name | IG n | IG Brief Description | Intensity^*^ | Run-in; Background Diet/PA | Duration and Longest FU, wks | Tx Goals | CG n | CG Description
McCrindle, 2003^118^ | 140 | Atorvastatin 10-20 mg/day | Moderate | 4-wk NCEP step 1 diet run-in; Step 1 diet | 26 | Dose titrated to 20 mg/day at week 4 in patients not achieving LDL-C ≤130 mg/dL | 47 | Placebo
Stein, 1999^117^ | 67 | Lovastatin 10-40 mg/day | Moderate | 8 wk diet run-in with AHA pediatric diet (similar to NCEP Step 1) and 4 wk placebo run-in | 48 | NR | 65 | Placebo
Clauss, 2005^124^ | 35 | Lovastatin 20-40 mg/day | Moderate | 4-wk diet and placebo run in; Step I or similar diet | 24 | NR | 19 | Placebo
Braamskamp, 2015^115^; PASCAL | 26 | Pitavastatin 4 mg/d | Moderate | 5 wk diet run-in; NR | 12 | Minimal LDL-C goal 130 mg/dL; ideal goal 110 mg/dL | 27 | Placebo
Braamskamp, 2015^115^; PASCAL | 27 | Pitavastatin 2 mg/d | Moderate | 5 wk diet run-in; NR | 12 | Minimal LDL-C goal 130 mg/dL; ideal goal 110 mg/dL | 27 | Placebo
Braamskamp, 2015^115^; PASCAL | 26 | Pitavastatin 1 mg/d | Moderate | 5 wk diet run-in; NR | 12 | Minimal LDL-C goal 130 mg/dL; ideal goal 110 mg/dL | 27 | Placebo
Knipscheer, 1996^116^ | 18 | Pravastatin 20 mg | Low | 8 wk diet and placebo run-in. Run-in diet 50% carbohydrate energy, 20% protein 20%, 30% fat 30%, with unsaturated:saturated ratio of 2:1 and daily intake cholesterol <300 mg | 12 | LDL-C <95th percentile for sex and age | 18 | Placebo
Knipscheer, 1996^116^ | 18 | Pravastatin 10 mg | Low | 8 wk diet and placebo run-in. Run-in diet 50% carbohydrate energy, 20% protein 20%, 30% fat 30%, with unsaturated:saturated ratio of 2:1 and daily intake cholesterol <300 mg | 12 | LDL-C <95^th^ percentile for sex and age | 18 | Placebo
Knipscheer, 1996^116^ | 18 | Pravastatin 5 mg | <Low | 8 wk diet and placebo run-in. Run-in diet 50% carbohydrate energy, 20% protein 20%, 30% fat 30%, with unsaturated:saturated ratio of 2:1 and daily intake cholesterol <300 mg | 12 | LDL-C <95the percentile for sex and age | 18 | Placebo
Wiegman, 2004^123^ | 106 | Pravastatin 20-40 mg/day | Low to moderate depending on age | 12 wk fat-restricted diet; Fat-restricted diet and maintenance of habitual physical activity. Recommended intake of total fat 30% and 10% as saturated fat. | 104 | NR | 108 | Placebo.
Avis, 2010^119^; PLUTO | 44 | Rosuvastatin 20 mg/day | High | 6-wk diet-only run-in; NR | 12 | LDL-C <110 mg/dL | 46 | Placebo
Avis, 2010^119^; PLUTO | 44 | Rosuvastatin 10 mg/day | Moderate | 6-wk diet-only run-in; NR | 12 | LDL-C <110 mg/dL | 46 | Placebo
Avis, 2010^119^; PLUTO | 42 | Rosuvastatin 5 mg/day | Moderate | 6-wk diet-only run-in; NR | 12 | LDL-C <110 mg/dL | 46 | Placebo
Couture, 1998^120^ | NR | Simvastatin 20 mg/day | Moderate | 4 wk placebo run-in. All lipid lowering medications discontinued 6 wk prior to run-in; AHA Phase I diet with focus on unrestricted daily caloric intake depending on age and physical activity | 6 | NR | NR | Placebo
de Jongh, 2002a^121^ | 106 | Simvastatin 10-40 mg/d | Moderate | 4 wk diet and placebo run-in; NR | 48 | NR | 69 | Placebo
de Jongh, 2002b^122^ | 28 | Simvastatin 10-40 mg/day | Moderate | NR | 28 | NR | 22 | Placebo

* Statin intensity was categorized based on 2018 guidelines for the management of cholesterol in adults.^31^ When the statin was titrated, intensity was categorized as the maximum dose of the titration. Intensity categorizations are not established for pediatric populations.

Abbreviations: AHA = American Heart Association; CG = control group; Descr = description; FH = familial hypercholesterolemia; FU = follow up; IG = intervention group; LDL-C = low-density lipoprotein cholesterol; mg/d = milligrams per day; mg/dL = milligrams per deciliter; NCEP = National Cholesterol Education Program; PA = physical activity; RCTs = randomized controlled trials; TX = treatment

Figure 12 Familial Hypercholesterolemia (FH), Multifactorial Dyslipidemia (MFD), and MFD/FH: All Treatment Intervention Trials—Study Duration, by Condition (Key Question 4)

Abbreviations: DHA = Docosahexaenoic acid; EPA = Eicosapentaenoic acid; FH = familial hypercholesterolemia; MFD = multifactorial dyslipidemia; PCSK9 = Proprotein convertase subtilisin/kexin type 9

For Familial hypercholesterolemia (FH), Multifactorial dyslipidemia (MFD), & MFD/FH, this figure shows the study duration, by condition for all treatment intervention trials (Key Question 4)

##### Outcomes (Results)

In pooled analyses, statins were associated with an 81-82 mg/dL greater mean difference in TC and LDL-C compared to placebo at up to 104 weeks followup (TC: k= 7, n=706, MD in change −82.1 mg/dL [95% CI −101.1 to −63.2], I^2^ 83.0%; LDL-C: k= 8, n=742, MD in change −81.3 mg/dL [95% CI, −97.6 to −65.0, I^2^ 81.6%]) (Figures 13–15; Tables 22 and 23). The only trial using a high-intensity statin^119^—Rosuvastatin 20 mg/day—showed the highest reduction in TC and LDL-C (TC: MD in change −119.0 [95% CI, −139.1 to −98.9]; LDL-C: MD in change −118.0 [95% CI, −136.4 to −99.6]); however, confidence intervals overlapped with trials using moderate- and low-intensity statins. In terms of percent change, statins were associated with a 25 to 33 percent greater reduction in TC and LDL-C, respectively, at up to 48 weeks (k=5, n=526, MD in % change TC: −25.3% [95% CI, −33.0 to −17.5]; LDL-C: k=6, n=577, MD in % change −33.4% [95% CI −42.0 to −24.8]) (Figures 13, 16, and 17; Tables 24 and 25). There was no difference in change in HDL-C between the groups (k=6, n=643, MD in change 1.6 mg/dL [95% CI −0.2 to 3.4], I^2^ 0%]) (Figure 18). Studies that could not be included in pooled analyses showed consistent results (Table 26).^115,^ ^116,^ ^119,^ ^121^ There were insufficient data to pool TG because values were most often reported as medians (Figure 19). Results for TG were mixed and significant in 3 of 9 reporting trials, with mean between-group differences ranging from −8.0 to −12.4 mg/dL where reported in trials showing benefit (Table 27).^118,^ ^121,^ ^122^ Four trials reported the proportion of participants meeting LDL-C goals (Table 28).^115,^ ^116,^ ^118,^ ^119^ In the highest-dose statin arms in each trial, 11.1 to 60.0 percent of participants met study-specified LDL-C goals, with no control group participants meeting goals (Figure 20). Three studies included multiple intervention groups evaluating different statin doses.^115,^ ^116,^ ^119^ Point estimates for reductions in TC and LDL-C were consistently greater in higher-dose arms within a trial, but confidence intervals also consistently overlapped.

Figure 13 Familial Hypercholesterolemia: Statin Intervention Trials—Meta Plot of Total Cholesterol, Low-Density Lipoprotein, and High-Density Lipoprotein Results (Key Question 4)

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; HDL-C = high-density lipoprotein cholesterol; IG = intervention group; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; TC = total cholesterol; TG = triglycerides

For Familial hypercholesterolemia, this figure show a Meta plot of total cholesterol, low-density lipoprotein, and high-density lipoprotein results for statin intervention trials (Key Question 4)

Figure 14 Familial Hypercholesterolemia: Statin Intervention Trials—Pooled Analysis of Mean Difference in Change in Total Cholesterol (mg/dL) of Highest Statin Intensity in Intervention Arm Compared With Placebo (k=7, n=706) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; H = high intensity statin; IG = intervention group; L = low intensity statin; M = moderate intensity statin; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; TC = total cholesterol; wks = weeks

For Familial hypercholesterolemia, this figure shows a pooled analysis of mean difference in change in total cholesterol (mg/dL) of highest statin intensity in intervention arm compared with placebo (k=7, n=706) for statin intervention trials (Key Question 4)

Figure 15 Familial Hypercholesterolemia: Statin Intervention Trials—Pooled Analysis of Mean Difference in Change in Low-Density Lipoprotein Cholesterol (mg/dL) of Highest Statin Intensity in Intervention Arm Compared With Placebo (k=8, n=742) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; H = high intensity statin; IG = intervention group; L = low intensity statin; LDL-C = low-density lipoprotein cholesterol; M = moderate intensity statin; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; wks = weeks

For Familial hypercholesterolemia, this figure shows a pooled analysis of mean difference in change in low-density lipoprotein cholesterol (mg/dL) of highest statin intensity in intervention arm compared with placebo (k=8, n=742) for statin intervention trials (Key Question 4)

Table 22 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Mean Difference in Change in Total Cholesterol (mg/dL) (Key Question 4)

Author, Year | Statin | Daily Dose (mg) | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Avis, 2010^119^ | Rosuvastatin | 20 | 12 | 44 | 46 | −119.00 (−132.20 to −105.80) | 0.00 (−15.06 to 15.06) | −119.00 (−139.10 to −98.90), <0.001
Avis, 2010^119^ | Rosuvastatin | 10 | 12 | 44 | 46 | −102.00 (−115.80 to −88.20) | 0.00 (−15.06 to 15.06) | −102.00 (−122.48 to −81.52), <0.001
Avis, 2010^119^ | Rosuvastatin | 5 | 12 | 42 | 46 | −93.00 (−108.86 to −77.14) | 0.00 (−15.06 to 15.06) | −93.00 (−114.86 to −71.14), <0.001
Braamskamp, 2015^115^ | Pitavastatin | 4 | 12 | 24 | 27 | −98.50 (−118.57 to −78.43) | −1.20 (−25.33 to 22.93) | −97.30 (−129.14 to −65.46), <0.0001
Braamskamp, 2015^115^ | Pitavastatin | 2 | 12 | 26 | 27 | −70.40 (−86.13 to −54.67) | −1.20 (−25.33 to 22.93) | −69.20 (−98.24 to −40.16), <0.0001
Braamskamp, 2015^115^ | Pitavastatin | 1 | 12 | 26 | 27 | −54.60 (−70.98 to −38.22) | −1.20 (−25.33 to 22.93) | −53.40 (−82.78 to −24.02), <0.0001
Clauss, 2005^124^ | Lovastatin | 20-40 | 24 | 35 | 19 | −65.60 (−81.61 to −49.59) | 9.10 (−10.60 to 28.80) | −74.70 (−100.85 to −48.55), <0.001
Couture, 1998^120^ | Simvastatin | 20 | 6 | 47 | 16 | −83.70 (−88.37 to −79.03) | −15.80 (−26.62 to −4.98) | −67.90 (−78.07 to −57.73), <0.0001
de Jongh, 2002b^122^ | Simvastatin | 10-40 | 28 | 28 | 22 | −83.40 (−98.27 to −68.52) | −1.93 (−20.81 to 16.95) | −81.47 (−105.16 to −57.78), 0.0001
McCrindle, 2003^118^ | Atorvastatin | 10-20 | 26 | 140 | 47 | −91.00 (−97.87 to −84.13) | −4.30 (−20.43 to 11.83) | −86.70 (−101.78 to −71.62), <0.001
Wiegman, 2004^123^ | Pravastatin | 20-40 | 104 | 106 | 108 | −56.00 (−64.26 to −47.74) | 2.00 (−5.39 to 9.39) | −58.00 (−69.07 to −46.93), <0.001

Abbreviations: BL = baseline; CI = confidence interval; CG = control group; FU = follow up; IG = intervention group; MD = mean difference; mg = milligram; NR = not reported; wks = weeks

Table 23 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Mean Difference in Change in Low-Density Lipoprotein Cholesterol (mg/dL) (Key Question 4)

Author, Year | Statin | Daily Dose (mg) | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Avis, 2010^119^ | Rosuvastatin | 20 | 12 | 44 | 46 | −120.00 (−132.57 to −107.43) | −2.00 (−15.38 to 11.38) | −118.00 (−136.39 to −99.61), <0.001
Avis, 2010^119^ | Rosuvastatin | 10 | 12 | 44 | 46 | −101.00 (−113.62 to −88.38) | −2.00 (−15.38 to 11.38) | −99.00 (−117.43 to −80.57), <0.001
Avis, 2010^119^ | Rosuvastatin | 5 | 12 | 42 | 46 | −95.00 (−109.44 to −80.56) | −2.00 (−15.38 to 11.38) | −93.00 (−112.66 to −73.34), <0.001
Braamskamp, 2015^115^ | Pitavastatin | 4 | 12 | 24 | 27 | −96.30 (−115.90 to −76.70) | −1.30 (−25.97 to 23.37) | −95.00 (−127.05 to −62.95), <0.0001
Braamskamp, 2015^115^ | Pitavastatin | 2 | 12 | 26 | 27 | −66.30 (−80.65 to −51.95) | −1.30 (−25.97 to 23.37) | −65.00 (−93.82 to −36.18), <0.0001
Braamskamp, 2015^115^ | Pitavastatin | 1 | 12 | 26 | 27 | −55.10 (−70.91 to −39.29) | −1.30 (−25.97 to 23.37) | −53.80 (−83.35 to −24.25), <0.0001
Clauss, 2005^124^ | Lovastatin | 20-40 | 24 | 35 | 19 | −62.00 (−77.70 to −46.30) | 6.80 (−12.25 to 25.85) | −68.80 (−94.33 to −43.27), <0.001
Couture, 1998^120^ | Simvastatin | 20 | 6 | 47 | 16 | −81.80 (−86.47 to −77.13) | −11.90 (−21.15 to −2.65) | −69.90 (−79.54 to −60.26), <0.0001
de Jongh, 2002b^122^ | Simvastatin | 10-40 | 28 | 28 | 22 | −82.24 (−96.40 to −68.08) | −1.93 (−19.03 to 15.17) | −80.31 (−102.33 to −58.29), 0.0001
Knipscheer, 1996^116^ | Pravastatin | 20 | 12 | 18 | 18 | −95.70 (−124.03 to −67.37) | −11.60 (−35.89 to 12.69) | −84.10 (−121.42 to −46.78), <0.05
Knipscheer, 1996^116^ | Pravastatin | 10 | 12 | 18 | 18 | −50.90 (−72.43 to −29.37) | −11.60 (−35.89 to 12.69) | −39.30 (−71.90 to −6.70), <0.05
Knipscheer, 1996^116^ | Pravastatin | 5 | 12 | 18 | 18 | −49.40 (−65.30 to −33.50) | −11.60 (−35.89 to 12.69) | −37.80 (−66.83 to −8.77), <0.05
McCrindle, 2003^118^ | Atorvastatin | 10-20 | 26 | 140 | 47 | −87.90 (−94.32 to −81.48) | −1.50 (−16.22 to 13.22) | −86.40 (−100.37 to −72.43), <0.001
Wiegman, 2004^123^ | Pravastatin | 20-40 | 104 | 106 | 108 | −57.00 (−64.69 to −49.31) | 0.00 (−6.82 to 6.82) | −57.00 (−67.26 to −46.74), <0.001

Abbreviations: BL = baseline; CI = confidence interval; CG = control group; FU = follow up; IG = intervention group; MD = mean difference; mg = milligram; NR = not reported; wks = weeks

Figure 16 Familial Hypercholesterolemia: Statin Intervention Trials—Pooled Analysis of Mean Difference in Percent Change in Total Cholesterol of Highest Statin Intensity in Intervention Arm Compared With Placebo (k=5; n=526) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; H = high intensity statin; IG = intervention group; L = low intensity statin; M = moderate intensity statin; MD = mean difference; mg/dL = milligrams per deciliter; Mn%Chg = mean percent change; TC = total cholesterol; wks = weeks

For Familial hypercholesterolemia, this figures shows a pooled analysis of mean difference in percent change in total cholesterol of highest statin intensity in intervention arm compared with placebo (k=5; n=526) for statin intervention trials (Key Question 4)

Figure 17 Familial Hypercholesterolemia: Statin Intervention Trials—Pooled Analysis of Mean Difference in Percent Change in Low-Density Lipoprotein Cholesterol of Highest Statin Intensity in Intervention Arm Compared With Placebo (k=6, n=577) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; H = high intensity statin; IG = intervention group; L = low intensity statin; LDL-C = low-density lipoprotein cholesterol; M = moderate intensity statin; MD = mean difference; mg/dL = milligrams per deciliter; Mn%Chg = mean percent change; wks = weeks

For Familial hypercholesterolemia, this figure shows a pooled analysis of mean difference in percent change in low-density lipoprotein cholesterol of highest statin intensity in intervention arm compared with placebo (k=6, n=577) for statin intervention trials (Key Question 4)

Table 24 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Mean Difference in Percent Change in Total Cholesterol (Key Question 4)

Author, Year | Statin | Daily Dose (mg) | FU, wks | IG n | CG n | IG Mean % Change From BL (95% CI) | CG Mean % Change From BL (95% CI) | MD in % Change (95% CI), p-Value
Avis, 2010^119^ | Rosuvastatin | 20 | 12 | 44 | 46 | −39.0 (NR) | 0.0 (NR) | −39.0 (NR), <0.001
Avis, 2010^119^ | Rosuvastatin | 10 | 12 | 44 | 46 | −34.0 (NR) | 0.0 (NR) | −34.0 (NR), <0.001
Avis, 2010^119^ | Rosuvastatin | 5 | 12 | 42 | 46 | −30.0 (NR) | 0.0 (NR) | −30.0 (NR), <0.001
Braamskamp, 2015^115^ | Pitavastatin | 4 | 12 | 24 | 27 | −31.3 (NR) | 0.9 (NR) | −32.2 (NR), <0.0001
Braamskamp, 2015^115^ | Pitavastatin | 2 | 12 | 26 | 27 | −24.2 (NR) | 0.9 (NR) | −25.1 (NR), <0.0001
Braamskamp, 2015^115^ | Pitavastatin | 1 | 12 | 26 | 27 | −17.8 (NR) | 0.9 (NR) | −18.7 (NR), <0.0001
Clauss, 2005^124^ | Lovastatin | 20-40 | 24 | 35 | 19 | −21.8 (−26.7 to −16.9) | 4.5 (−1.2 to 10.2) | −26.3 (−34.2, −18.4)
de Jongh, 2002a^121^ | Simvastatin | 10-40 | 48 | 106 | 69 | −30.90 (−33.37 to −28.43) | 0.80 (−1.71 to 3.31) | −31.70 (−35.35 to −28.05), <0.001
Knipscheer, 1996^116^ | Pravastatin | 20 | 12 | 18 | 18 | −24.60 (−28.10 to −21.00) | −2.30 (−6.70 to 2.40) | −22.30 (−28.07 to −16.53), <0.05
Knipscheer, 1996^116^ | Pravastatin | 10 | 12 | 17 | 18 | −17.20 (−21.10 to −13.10) | −2.30 (−6.70 to 2.40) | −14.90 (−20.99 to −8.81), <0.05
Knipscheer, 1996^116^ | Pravastatin | 5 | 12 | 18 | 18 | −18.20 (−21.90 to −14.20) | −2.30 (−6.70 to 2.40) | −15.90 (−21.86 to −9.94), <0.05
McCrindle, 2003^118^ | Atorvastatin | 10-20 | 26 | 140 | 47 | −32.3 (−37.6 to −27.0) | −2.0 (−8.1 to 4.1) | −30.3 (−40.1, −20.5)
Stein, 1999^117^ | Lovastatin | 10-40 | 48 | 67 | 65 | −20.00 (−23.92 to −16.08) | −3.00 (−4.96 to −1.04) | −17.00 (−21.72 to −12.28), <0.001

Abbreviations: BL = baseline; CI = confidence interval; CG = control group; FU = follow up; IG = intervention group; MD = mean difference; mg = milligram; NR = not reported; wks = weeks

Table 25 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Mean Difference in Percent Change in Low-Density Lipoprotein Cholesterol (Key Question 4)

Author, Year | Statin | Daily Dose (mg) | FU, wks | IG n | CG n | IG Mean % Change From BL (95% CI) | CG Mean % Change From BL (95% CI) | MD in % Change (95% CI), p-Value
Avis, 2010^119^ | Rosuvastatin | 20 | 12 | 44 | 46 | −50.0 (NR) | −1.0 (NR) | −51.0 (NR), <0.001
Avis, 2010^119^ | Rosuvastatin | 10 | 12 | 44 | 46 | −45.0 (NR) | −1.0 (NR) | −46.0 (NR), <0.001
Avis, 2010^119^ | Rosuvastatin | 5 | 12 | 42 | 46 | −38.0 (NR) | −1.0 (NR) | −39.0 (NR), <0.001
Braamskamp, 2015^115^ | Pitavastatin | 4 | 12 | 24 | 27 | −39.3 (−43.6 to −35.0) | 1.0 (−3.0 to 5.0) | −40.3 (−46.2, −34.4), <0.0001
Braamskamp, 2015^115^ | Pitavastatin | 2 | 12 | 26 | 27 | −30.1 (−34.2 to −26.0) | 1.0 (−3.0 to 5.0) | −31.1 (−36.9, −25.3), <0.0001
Braamskamp, 2015^115^ | Pitavastatin | 1 | 12 | 26 | 27 | −23.5 (−27.6 to −19.4) | 1.0 (−3.0 to 5.0) | −24.5 (−30.3, −18.7), <0.0001
Clauss, 2005^124^ | Lovastatin | 20-40 | 24 | 35 | 19 | −26.8 (−33.5 to −20.1) | 5.2 (−2.4 to 12.8) | −32.0 (−42.7, −21.3)
de Jongh, 2002a^121^ | Simvastatin | 10-40 | 48 | 106 | 69 | −40.70 (−49.13 to −32.27) | 0.30 (−2.40 to 3.00) | −41.00 (−51.51 to −30.49), <0.001
Knipscheer, 1996^116^ | Pravastatin | 20 | 12 | 18 | 18 | −32.9 (−37.0 to −28.6) | −3.2 (−9.0 to 3.0) | −29.7 (−37.0, −22.4), <0.05
Knipscheer, 1996^116^ | Pravastatin | 10 | 12 | 18 | 18 | −23.8 (−28.5 to −18.8) | −3.2 (−9.0 to 3.0) | −20.6 (−28.4, −12.8), <0.05
Knipscheer, 1996^116^ | Pravastatin | 5 | 12 | 18 | 18 | −23.3 (−27.9 to −18.4) | −3.2 (−9.0 to 3.0) | −20.1 (−27.8, −12.4), <0.05
McCrindle, 2003^118^ | Atorvastatin | 10-20 | 26 | 140 | 47 | −40.0 (−46.5 to −33.5) | −0.4 (−7.7 to 6.9) | −39.6 (−51.5, −27.7)
Stein, 1999^117^ | Lovastatin | 10-40 | 48 | 67 | 65 | −25.00 (−28.92 to −21.08) | −4.00 (−7.92 to −0.08) | −21.00 (−26.61 to −15.39), <0.001

Abbreviations: BL = baseline; CI = confidence interval; CG = control group; FU = follow up; IG = intervention group; MD = mean difference; mg = milligram; NR = not reported; wks = weeks

Figure 18 Familial Hypercholesterolemia: Statin Intervention Trials—Pooled Analysis of Mean Difference in Change in High-Density Lipoprotein Cholesterol (mg/dL) of Highest Statin Intensity in Intervention Arm Compared With Placebo (k=6, n=643) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; H = high intensity statin; HDL-C = high-density lipoprotein cholesterol; IG = intervention group; L = low intensity statin; M = moderate intensity statin; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; wks = weeks

For Familial hypercholesterolemia, this figure shows a pooled analysis of mean difference in change in high-density lipoprotein cholesterol (mg/dL) of highest statin intensity in intervention arm compared with placebo (k=6, n=643) for statin intervention trials (Key Question 4)

Table 26 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Mean Difference in Change in High-Density Lipoprotein Cholesterol (mg/dL) (Key Question 4)

Author, Year | Statin | Daily Dose (mg) | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Avis, 2010^119^ | Rosuvastatin | 20 | 12 | 44 | 46 | 3.00 (−0.84 to 6.84) | 3.00 (−0.04 to 6.04) | 0.00 (−4.88 to 4.88), 0.5
Avis, 2010^119^ | Rosuvastatin | 10 | 12 | 44 | 46 | 5.00 (1.89 to 8.11) | 3.00 (−0.04 to 6.04) | 2.00 (−2.35 to 6.35), 0.2
Avis, 2010^119^ | Rosuvastatin | 5 | 12 | 42 | 46 | 2.00 (−1.63 to 5.63) | 3.00 (−0.04 to 6.04) | −1.00 (−5.71 to 3.71), 0.4
Braamskamp, 2015^115^ | Pitavastatin | 4 | 12 | 24 | 27 | −2.20 (−6.25 to 1.85) | −0.40 (−4.80 to 4.00) | −1.80 (−7.83 to 4.23), 0.25
Braamskamp, 2015^115^ | Pitavastatin | 2 | 12 | 26 | 27 | −1.80 (−6.19 to 2.59) | −0.40 (−4.80 to 4.00) | −1.40 (−7.62 to 4.82), 0.32
Braamskamp, 2015^115^ | Pitavastatin | 1 | 12 | 26 | 27 | 2.60 (−2.47 to 7.67) | −0.40 (−4.80 to 4.00) | 3.00 (−3.70 to 9.70), 0.16
Clauss, 2005^124^ | Lovastatin | 20-40 | 24 | 35 | 19 | 0.60 (−3.27 to 4.47) | 1.90 (−1.97 to 5.77) | −1.30 (−7.28 to 4.68), NSD
de Jongh, 2002a^121^ | Simvastatin | 10-40 | 48 | 106 | 69 | Mean % Chg: 3.30 (0.09 to 6.51) | Mean % Chg: −0.40 (−4.28 to 3.48) | MD in % Chg: 3.70 (−1.34 to 8.74), NSD
de Jongh, 2002b^122^ | Simvastatin | 10-40 | 28 | 28 | 22 | 1.93 (−0.50 to 4.36) | −1.93 (−5.48 to 1.62) | 3.86 (−0.31 to 8.03), 0.080
Knipscheer, 1996^116^ | Pravastatin | 20 | 12 | 18 | 18 | Mean % Chg: 10.80 (3.40 to 18.80) | Mean % Chg: 4.30 (−2.70 to 11.80) | MD in % Chg: 6.50 (−4.08 to 17.08), NSD
Knipscheer, 1996^116^ | Pravastatin | 10 | 12 | 18 | 18 | Mean % Chg: 5.50 (−1.70 to 13.20) | Mean % Chg: 4.30 (−2.70 to 11.80) | MD in % Chg: 1.20 (−9.20 to 11.60), NSD
Knipscheer, 1996^116^ | Pravastatin | 5 | 12 | 18 | 18 | Mean % Chg: 3.80 (−3.10 to 11.20) | Mean % Chg: 4.30 (−2.70 to 11.80) | MD in % Chg: −0.50 (−10.68 to 9.68), NSD
McCrindle, 2003^118^ | Atorvastatin | 10-20 | 26 | 140 | 47 | 0.90 (−0.77 to 2.57) | −1.30 (−4.24 to 1.64) | 2.20 (−1.15 to 5.55), NR^*^
McCrindle, 2003^118^ | Lovastatin | 10-40 | 48 | 67 | 65 | Mean % Chg: 1.00 (−2.92 to 4.92) | Mean % Chg:−1.00 (−4.92 to 2.92) | MD in % Chg: 2.00 (−3.61 to 7.61), NSD
Stein, 1999^117^ | Pravastatin | 20-40 | 104 | 106 | 108 | 3.00 (1.08 to 4.92) | 1.00 (−0.71 to 2.71) | 2.00 (−0.57 to 4.57), 0.09

* The imputed MD in change from BL (95% CI) are unadjusted compared to the study’s adjusted p-value of 0.02.

Abbreviations: BL = baseline; CG = control group; Chg = change; CI = confidence interval; FU = follow up; IG = intervention group; MD = mean difference; mg = milligram; NSD = no significant difference; NR = not reported; wks = weeks

Figure 19 Familial Hypercholesterolemia: Statin Intervention Trials—Mean Difference in Percent Change in Triglycerides Compared With Placebo, Sorted by Statin Intensity (k=4, n=387) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; H = high intensity statin; IG = intervention group; L = low intensity statin; M = moderate intensity statin; MD = mean difference; mg/dL = milligrams per deciliter; Mn%Chg = mean percent change; TG = triglycerides; wks = weeks

For Familial hypercholesterolemia, this figure shows the mean difference in percent change in triglycerides compared with placebo, sorted by statin intensity (k=4, n=387) for statin intervention trials (Key Question 4)

Table 27 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Mean Difference in Percent Change in Triglyceride Levels (Key Question 4)

Author, Year | Statin | Daily Dose (mg) | FU, wks | IG n | CG n | IG Mean % Change From BL (95% CI) | CG Mean % Change From BL (95% CI) | MD in % Change (95% CI), p-Value
Avis, 2010^119^ | Rosuvastatin | 20 | 12 | 44 | 46 | −16.00 (NR) | −7.00 (NR) | NR, 0.1
Avis, 2010^119^ | Rosuvastatin | 10 | 12 | 44 | 46 | −15.00 (NR) | −7.00 (NR) | NR, 0.1
Avis, 2010^119^ | Rosuvastatin | 5 | 12 | 42 | 46 | −13.00 (NR) | −7.00 (NR) | NR, 0.8
Braamskamp, 2015^115^ | Pitavastatin | 4 | 12 | 24 | 27 | 0.30 (NR) | 2.00 (NR) | NR, 0.85
Braamskamp, 2015^115^ | Pitavastatin | 2 | 12 | 26 | 27 | −5.90 (NR) | 2.00 (NR) | NR, 0.38
Braamskamp, 2015^115^ | Pitavastatin | 1 | 12 | 26 | 27 | −7.60 (NR) | 2.00 (NR) | NR, 0.28
Clauss, 2005^124^ | Lovastatin | 20-40 | 24 | 35 | 19 | −22.70 (−36.03 to −9.37) | −3.00 (−21.82 to 15.82) | −19.70 (−42.49 to 3.09), 0.067
de Jongh, 2002a^121^ | Simvastatin | 10-40 | 48 | 106 | 69 | Med % Chg (Range): −8.7 (−73.1 to −204.1) | Med % Chg (Range): −4.3 (−49.2 to −141.30) | NR, <0.05
de Jongh, 2002b^122^ | Simvastatin | 10-40 | 28 | 28 | 22 | Mean Chg (95% CI): −16.82 (−28.94 to −4.69) | Mean Chg (95% CI): −8.85 (−28.82 to 11.12) | MD in Chg (95% CI): −7.97 (−30.32 to 14.39), NR^*^
Knipscheer, 1996^116^ | Pravastatin | 20 | 12 | 18 | 18 | 3.30 (−14.30 to 24.50) | −11.70 (−26.60 to 6.10) | 15.00 (−10.37 to 40.37), NSD
Knipscheer, 1996^116^ | Pravastatin | 10 | 12 | 17 | 18 | 6.60 (−12.00 to 29.00) | −11.70 (−26.60 to 6.10) | 18.30 (−7.77 to 44.37), NSD
Knipscheer, 1996^116^ | Pravastatin | 5 | 12 | 18 | 18 | 1.70 (−15.40 to 22.20) | −11.70 (−26.60 to 6.10) | 13.40 (−11.51 to 38.31), NSD
McCrindle, 2003^118^ | Atorvastatin | 10-20 | 26 | 140 | 47 | −20.00 (−28.67 to −11.33) | −7.60 (−23.40 to 8.20) | −12.40 (−29.94 to 5.14), NR^†^
Stein, 1999^117^ | Lovastatin | 10-40 | 48 | 67 | 65 | 6.00 (−5.76 to 17.76) | 8.00 (−5.72 to 21.72) | −2.00 (−19.98 to 15.98), NSD
Wiegman, 2004^123^ | Pravastatin | 20-40 | 104 | 106 | 108 | Med Chg (IQR): −12 (−35 to 16) | Med Chg (IQR): 1 (−20 to 22) | NR, 0.21

* Study reported statistical significance between treatments (IG vs. CG, p=0.041) based on absolute values and log-transformation of TG, not accounting for MD in change from BL.

† The imputed MD in change from BL (95% CI) are unadjusted compared to the study’s adjusted p-value of 0.03.

Abbreviations: BL = baseline; CG = control group; Chg = change; CI = confidence interval; FU = follow up; IG = intervention group; IQR = interquartile range; Med = median; MD = mean difference; Med = median; mg = milligram; NR = not reported; NSD = no significant difference; wks = weeks

Table 28 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Proportion Achieving Low-Density Lipoprotein Cholesterol Goal (Absolute Risk Difference, %) (Key Question 4)

Author, Year | Statin | LDL-C Goal (mg/dL) | Daily Dose, mg | Statin Intensity | IG N | IG n/N (%) | CG N | CG n/N (%) | % ARD (95% CI)
Avis, 2010^119^ | Rosuvastatin | <110 | 20 | H | 44 | 18/44 (40.9) | 46 | 0/46 (0.0) | 40.91 (26.38 to 55.44)
Avis, 2010^119^ | Rosuvastatin | <110 | 10 | M | 44 | 18/44 (40.9) | 46 | 0/46 (0.0) | 40.91 (26.38 to 55.44)
Avis, 2010^119^ | Rosuvastatin | <110 | 5 | M | 42 | 5/42 (11.9) | 46 | 0/46 (0.0) | 11.90 (2.11 to 21.70)
Braamskamp, 2015^115^ | Pitavastatin | ≤110 | 4 | M | 24 | 4/24 (16.7) | 27 | 0/27 (0.0) | 16.67 (1.76 to 31.58)
Braamskamp, 2015^115^ | Pitavastatin | ≤130 | 4 | M | 24 | 9/24 (37.5) | 27 | 0/27 (0.0) | 37.50 (18.13 to 56.87)
Braamskamp, 2015^115^ | Pitavastatin | ≤110 | 2 | M | 26 | 2/26 (7.7) | 27 | 0/27 (0.0) | 7.69 (−2.55 to 17.93)
Braamskamp, 2015^115^ | Pitavastatin | ≤130 | 2 | M | 26 | 8/26 (30.8) | 27 | 0/27 (0.0) | 30.77 (13.03 to 48.51)
Braamskamp, 2015^115^ | Pitavastatin | ≤110 | 1 | L | 26 | 0/26 (0.0) | 27 | 0/27 (0.0) | 0.00 (0.00 to 0.00)
Braamskamp, 2015^115^ | Pitavastatin | ≤130 | 1 | L | 26 | 1/26 (3.8) | 27 | 0/27 (0.0) | 3.85 (−3.55 to 11.24)
Knipscheer, 1996^116^ | Pravastatin | <95th percentile for sex and age | 20 | L | 18 | 2/18 (11.1) | 18 | 0/18 (0.0) | 11.11 (−3.41 to 25.63)
Knipscheer, 1996^116^ | Pravastatin | <95th percentile for sex and age | 10 | L | 18 | 1/18 (5.6) | 18 | 0/18 (0.0) | 5.56 (−5.03 to 16.14)
Knipscheer, 1996^116^ | Pravastatin | <95th percentile for sex and age | 5 | L | 18 | 1/18 (5.6) | 18 | 0/18 (0.0) | 5.56 (−5.03 to 16.14)
McCrindle, 2003^118^ | Atorvastatin | <130 | 10-20 | L-M | 140 | 84/140 (60.0) | 47 | 0/47 (0.0) | 60.00 (51.88 to 68.12)

Abbreviations: ARD = absolute risk difference; CG = control group; CI = confidence interval; H = high intensity; IG = intervention group; L = low intensity; LDL-C = low-density lipoprotein cholesterol; M = moderate intensity; mg/dL = milligrams per deciliter

Figure 20 Familial Hypercholesterolemia: Statin Intervention Trials—Absolute Risk Difference (%) of Low-Density Lipoprotein Cholesterol at Goal, Sorted by Statin Intensity (k=4, n=364) (Key Question 4)

Abbreviations: ARD = absolute risk difference; CG = control group; CI = confidence interval; H = high intensity statin; IG = intervention group; L = low intensity statin; LDL-C = low-density lipoprotein cholesterol; M = moderate intensity statin; MD = mean difference; mg/d = milligrams per day; mg/dL = milligrams per deciliter; wks = weeks

For Familial hypercholesterolemia, this figure shows the absolute risk difference (%) of low-density lipoprotein cholesterol at goal, sorted by statin Intensity (k=4, n=364) for statin intervention trials (Key Question 4)

One statin trial reported cIMT outcomes. The 2-year trial by Wiegman and colleagues showed a statistically significant between-group mean difference in change in mean combined carotid IMT favoring the statin group (MD in change 0.01 mm [95% CI, 0.00 to 0.02]; p=0.03).^123^

#### Drug Therapy Intervention: Bile Acid Sequestrants

##### Trial and Participant Characteristics

We identified one good-quality^125^ and two fair-quality trials^126,^ ^127^ (n=332) examining the effectiveness of bile acid sequestrants to improve lipid levels in children with FH (Tables 29 and 30). All three trials were included in the prior review. One trial was multinational and recruited from 41 sites in Australia, Austria, Canada, the Czech Republic, Hungary, Israel, the Netherlands, New Zealand, Norway, Slovakia, South Africa and the United States and was conducted between 2005 and 2007.^125^ The other two trials were conducted in Norway.^126,^ ^127^ Participants were recruited from lipid clinics in the two trials reporting recruitment method.^126,^ ^127^ Two trials included adolescents with FH aged 10 to 16 or 17 years^125,^ ^127^ and the other trial included a younger age range—prepubescent females ages 6 to 10 years and males ages 6 to 11 years with FH.^126^ Definitions of FH varied in the trials. Mean age ranged from 8 years to 14 years (Figure 9) with 37 to 44 percent of trial participants female. Only the larger multinational trial reported race and ethnicity: 87 percent were White, 3 percent were Black, and 4 percent were Asian.^125^ At baseline, one trial reported that 24 percent of participants were on statin therapy^125^ and the other trials did not report baseline lipid lowering medication use. In the three trials, mean fasting TC ranged from 265^125^ to 320^126^ mg/dL, mean LDL-C ranged from 199^125^ to 245^127^ mg/dL, mean HDL-C ranged from 43^127^ to 47,^125^ and mean or median TG ranged from 76^126^ to 95^125^ mg/dL (Figure 21).

Table 29 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Study Characteristics, by Intervention (Key Questions 4 and 5)

Intervention | Author, Year; Quality | Brief Population Description^*^ | FH Criteria | Country | Years of Data Collection | N
Bile acid sequestrant | Tonstad, 1996^126^; Fair | Children aged 6 to 11 years with FH in Tanner’s stage 1 | TC >260 mg/dL and TG <200 mg/dL, if one parent had baseline TC ≥300 and TG <200, or tendon xanthoma, and if autosomally dominant inheritance of hypercholesterolemia was present in other members of the pedigree | Norway | NR | 72
Bile acid sequestrant | Tonstad, 1996b^127^; Fair | Adolescents aged 10 to 16 years with FH | TC ≥300 mg/dL and tendon xanthoma in one or both parents and in relatives in a manner compatible with autosomal dominant inheritance, or on the detection of an LDL-C receptor mutation. | Norway | NR | 66
Bile acid sequestrant | Stein, 2010^125^; Good | Children and adolescents aged 10-17 years with FH | LDL-C >160 mg/dL or >130 mg/dL on stable NCEP diet and stable statin therapy | Multinational; Conducted across 41 sites in Australia, Austria, Canada, the Czech Republic, Hungary, Israel, The Netherlands, New Zealand, Norway, Slovakia, South Africa, US | 2005-2007 | 194
Ezetimibe | Kusters, 2015^128^; Good | Children and adolescents aged 6-10 years with heterozygous FH or clinically important nonFH (LDL-C >160 mg/dL while on a lipid-lowering diet for ≥3 months); 91% FH; 9% MFD | Clinical criteria for heterozygous FH included LDL-C levels >189 to <400 mg/dL with a family history of hypercholesterolemia consistent with dominant autosomal transmission, or LDL-C >159 to <400 mg/dL and at least 1 of the following: (1) genotype confirmed heterozygous FH; (2) at least 1 biological parent with genotype-confirmed heterozygous FH and a historic untreated LDL-C of >159 mg/dL; (3) ≥1 biological parent with untreated LDL-C value ≥210 mg/dL not associated with a disorder known to elevate LDL-C; or (4) tendinous xanthomas not associated with a disorder known to elevate LDL-C. Clinical criteria for primary nonFH was an LDL-C >159 to <400 mg/dL and a clinical diagnosis of primary nonFH | Multinational; Conducted across 29 sites in Canada, Colombia, France. Greece, Israel, Italy, Norway, The Netherlands, US | 2009-2012 | 138
Fibrate | Wheeler, 1985^129^; Fair | Children and adolescents aged 4-15 years with FH | TC >269 mg/dL, heterozygous FH type IIa pattern on lipoprotein electrophoresis, and normal fasting TG (<1.5 mmol/L), with either similar lipoprotein abnormalities in one of the parents, or where a parent had died of premature CHD, a similar lipid abnormality in another close relative | UK | NR | 14
PCSK9 inhibitor | Santos, 2020^130^; Good | Patients 10-17 years with heterozygous FH who had received ≥4 wks of stable lipid-lowering therapy | Heterozygous FH diagnosed by genetic testing or applicable clinical diagnostic criteria (Simon Broome Register Group, the Dutch Lipid Clinic Network, or MEDPED) | Multinational; Conducted across 47 sites in North America, Latin America, Europe, and the Asia–Pacific region | 2016-2019 | 158
Combination drug therapy | van der Graaf, 2008^131^; Fair | Male and postmenarchal female adolescents 10-17 years and Tanner stage ≥2 | At least 1 of the following clinical criteria: Genotype-confirmed FH and LDL-C >159 mg/dL and <400 mg/dL; LDL-C >159 mg/dL and <400 mg/dL and at least 1 biological parent with genotype-confirmed FH and historical untreated LDL-C >159 mg/dL; LDL-C >159 mg/dL and <400 mg/dL and at least 1 biological parent with untreated LDL-C of at least 210 mg/dL in the absence of another condition associated with secondary elevated LDL-C; LDL-C >189 mg/dL and <400 mg/dL and a family history of hypercholesterolemia consistent with dominant autosomal transmission; LDL-C >159 mg/dL and <400 mg/dL and tendinous xanthomas, without another condition associated with secondary elevated LDL-C | Multinational | NR | 248

* Defining adolescent as age 10-19 years based on WHO; however, some have argued for broader definition.^203^

Abbreviations: CHD = coronary heart disease; FH= familial hypercholesterolemia; FH type IIa = familial hypercholesterolemia type IIa; FN = false negative; LDL-C = low-density lipoprotein-cholesterol; MEDPED = Make Early Diagnosis to Prevent Early Death Program; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NCEP = National Cholesterol Education Program; NR = not reported; PCSK9 = proprotein convertase subtilisin/kexin type 9; RCTs = randomized controlled trials; TC = total cholesterol; TG = triglycerides; UK = United Kingdom; US = Unites States

Table 30 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Population Characteristics, by Intervention (Key Questions 4 and 5)

Intervention | Author, Year | Mean Age, Years (Age Range) | % Female | Race & Ethnicity | % Smoking | % With Family Hx of CVD and Definition | Other BL Characteristic | Mean Fasting TC (mg/dL) | Mean Fasting LDL-C (mg/dL) | Mean Fasting HDL-C (mg/dL) | Mean Fasting TG (mg/dL)
Bile acid sequestrant | Tonstad, 1996^126^ | 8; (6-11) | 39 | NR | NR | NR | 100% Tanner Stage 1 | 320 | NR | 46 | 76
Bile acid sequestrant | Tonstad, 1996b^127^ | 13; (10-16) | 44 | NR | NR | NR | Mean Tanner Stage: 2.6 | 306 | 245 | 43 | 87
Bile acid sequestrant | Stein, 2010^125^ | 14; (10-17) | 37 | White: 87; Black: 3; Asian: 4; Native American: NR; Latino: NR; Other: 6 | NR | NR | BMI, kg/m^2^: 22.5; Statin therapy: 47% | 265 | 199 | 47 | Median: 95
Ezetimibe | Kusters, 2015^128^ | 8; (6-11) | 57 | White: 80; Black: 1; Asian: 3; Native American: NR; Latino: NR; Multiracial: 15 | NR | NR | NR | 293 | 227 | 50 | 85
Fibrate | Wheeler, 1985^129^ | 11; (4-15) | 57 | NR | NR | NR | NR | 359 | NR | 39 | 89
PCSK9 inhibitor | Santos, 2020^130^ | 14; (10-17) | 56 | White: 85; Black: NR; Asian: NR; Native American: NR; Latino: NR; Other: NR | NR | 1st-degree family history of premature atherosclerotic CVD: 33 | Overweight: ≥85th percentile to <95th percentile: 18%; Obese: ≥95th percentile: 16%; Genetic diagnosis of FH: 66%; Two or more risk factors for atherosclerotic CVD: 11%; Using high-intensity or moderate-intensity statins: 79%; Taking ezetimibe (in addition to statins): 13% | 250 | 184 | 47 | 84^*^
Combination drug therapy | van der Graaf, 2008^131^ | 14; (10-17) | 43 | White: 82; Black: 2; Asian: 4; Native American: NR; Latino: NR; Other: 13 | Cigarette smoking in previous month: 5 | CHD in male first-degree relative <55 years old or CHD in female first-degree relative <65 years old: 39 | NR | NR | 222 | NR | NR

* Calculated as a mean of IG and CG medians (this calculation was only made if sample sizes were >100).

Abbreviations: BL = baseline; CHD = coronary heart disease; CVD = cardiovascular disease; FH= familial hypercholesterolemia; FN = false negative; HDL-C = high-density lipoprotein cholesterol; Hx = history; LDL-C = low-density lipoprotein-cholesterol; MEDPED = Make Early Diagnosis to Prevent Early Death Program; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NR = not reported; PCSK9 = proprotein convertase subtilisin/kexin type 9; RCTs = randomized controlled trials; TC = total cholesterol; TG = triglycerides

Figure 21 Familial Hypercholesterolemia: Non-Statin Intervention Trials—Baseline Lipid Levels, by Intervention (Key Question 4)

NOTE: Each dot represents mean lipid level from a study.

Abbreviations: DHA = Docosahexaenoic acid; EPA = Eicosapentaenoic acid; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; PCSK9 = Proprotein convertase subtilisin/kexin type 9; TC = total cholesterol; TG = triglycerides

For Familial hypercholesterolemia, this figure show the baseline lipid levels, by intervention for non-statin intervention trials(Key Question 4)

##### Intervention Characteristics

Different bile acid sequestrant formulations were evaluated in the three trials, including cholestyramine 8 mg/day (after 1 week titration from 4 mg/d),^126^ colestipol 10 mg daily or 5g twice per day,^127^ or colesevelam 1.875 g/day and 3.75 g/day (Table 31).^125^ All participants were on a low fat or NCEP Step 1 diet (Appendix E Table 4) prior to and/or during the randomized drug period. Treatment duration and followup were 8 weeks in two trials^125^ and 52 weeks (1 year) in the other trial (Figure 12).^126^ The control groups received placebo in all trials. Overall adherence in the intervention groups was 68^127^ and 87^125^ percent in the 8-week trials. In the longer trial, 61 in the intervention group completed 1 year of therapy, having taken a median of 77 percent of all doses.^126^

Table 31 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Intervention Characteristics, by Intervention (Key Questions 4 and 5)

Intervention | Author, Year | IG | IG n | IG Brief Description | Run-In; Background Diet/PA | Duration and Longest FU, wks | Tx Goals | CG n | CG Description
Bile acid sequestrant | Tonstad, 1996^126^ | IG1 | 36 | Cholestryamine 8 mg/day | 1-week buildup phase of 4 mg/day; 1 yr of a low-fat and low-cholesterol diet; NCEP diet; dietitian reinforcing diet at each visit during randomized phase | 52 | NR | 36 | Placebo
Bile acid sequestrant | Tonstad, 1996b^127^ | IG1 | 33 | Colestipol 10 g QD or 5 g BID | 6-week stabilization phase after discontinuation of any bile acid binding resins and dietary instructions.; Diet containing ≤30% of energy from fat, <10% of energy from saturated fat, and <200 mg cholesterol/d | 8 | NR | 33 | Placebo
Bile acid sequestrant | Stein, 2010^125^ | IG1 | 64 | Colesevelam 3.75 g/d | Step 1 diet during run-in period.; NR | 8 | LDL-C <110 mg/dl | 65 | Placebo
Bile acid sequestrant | Stein, 2010^125^ | IG2 | 65 | Colesevelam 1.875 g/d | Same as above | Same as above | LDL-C <110 mg/dl | 65 | Placebo
Ezetimibe | Kusters, 2015^128^ | IG1 | 93 | Ezetimibe 10 mg/day | 5 wk placebo run-in with Step 2 diet stabilization; NR | 12 | NR | 45 | Placebo
Fibrate | Wheeler, 1985^129^ | IG1 | 14 | Bezafibrate10-20 mg/kg/day BID | NR | 13 | NR | 14 | Placebo
PCSK9 inhibitor | Santos, 2020^130^ | IG1 | 104 | Evolocumab (420 mg) by monthly subcutaneous injections | 4 wks stable lipid-lowering therapy; Per inclusion criteria, all subjects on low-fat diet (not otherwise specified). | 24 | NR | 53 | Monthly subcutaneous injections of placebo using prefilled AI-Pen.
Combination drug therapy | van der Graaf, 2008^131^ | IG1 | 126 | Simvastatin 10–40 mg/d simvastatin and ezetimibe 10-mg/d | NR | 33 | Acceptable LDL-C goal of <130 mg/dL; ideal goal of <110 mg/dL | 122 | Simvastatin 10-, 20-, or 40-mg/d simvastatin and placebo for 6 weeks, followed by 27 weeks of simvastatin 40-mg/d and placebo.

Abbreviations: AI = auto-injector; BID = two times per day (Latin); CG = control group; Descr = Description; FH = familial hypercholesterolemia; FU = follow up; IG = intervention group; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; NCEP = National Cholesterol Education Program; NR = not reported; PA = physical activity; PCSK9 = proprotein convertase subtilisin/kexin type 9; QD = every day (Latin); RCTs = randomized controlled trials; TX = treatment; wks = weeks

##### Outcomes (Results)

The three bile acid sequestrant trials demonstrated that this intervention was generally associated with a significantly greater reduction in TC and LDL-C, with some variation in effect by dose (Figures 22–25; Tables 32–37).^125–127^ For TC, statistically significant reductions ranged from −22.1 to −40.6 mg/dL; TC reduction for colesevelam was significant only in the higher dose trial.^125^ For LDL-C, reductions were statistically significant in all trials; two trials reported difference in mean values that ranged from −13.2 to −45.9 mg/dL at 8 weeks. Changes in HDL-C were only statistically significant in one trial, occurring in the intervention group randomized to the higher dose of colesevelam (3.75 g/day), showing a 2.9 mg/dL greater change (calculated 95% CI, −0.5 to 6.3; p=0.008 in adjusted analyses).^125^ There were no statistically significant reductions in TG in any of the trials.^125–127^ In the trial of colesevelam, more participants in the higher dose 3.75 g/day group achieved LDL-C goal (<100 mg/dL) (7.9% in the IG vs 0% in the CG; ARD 7.9% [95% CI, 1.3 to 14.6]). There was no statistically significant difference in the proportion achieving goal in the lower-dose 1.875 g/day group (3.2% in the IG vs 0% in the CG; ARD 3.2% [95% CI, −1.2 to 7.5]).^125^

Figure 22 Familial Hypercholesterolemia: Non-Statin Intervention Trials—Mean Difference in Change in Total Cholesterol Compared With Controls (k=10) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DHA = Docosahexaenoic acid; g = gram(s); IG = intervention group; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; TC = total cholesterol; wks = weeks

For Familial hypercholesterolemia, this figure shows the mean difference in change in total cholesterol compared with controls (k=10) for non-statin intervention trials (Key Question 4)

Figure 23 Familial Hypercholesterolemia: Non-Statin Intervention Trials—Mean Difference in Change in Low-Density Lipoprotein Cholesterol Compared With Controls (k=10) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DHA = Docosahexaenoic acid; g = gram(s); IG = intervention group; LDL-C = low-density lipoprotein cholesterol; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; wks = weeks

For Familial hypercholesterolemia, this figure shows the mean difference in change in low-density lipoprotein cholesterol compared with controls (k=10) for non-statin intervention trials (Key Question 4)

Figure 24 Familial Hypercholesterolemia: Non-Statin Intervention Trials—Mean Difference in Change in High-Density Lipoprotein Cholesterol Compared With Controls (k=10) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DHA = Docosahexaenoic acid; g = gram(s); HDL-C = high-density lipoprotein cholesterol; IG = intervention group; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; wks = weeks

For Familial hypercholesterolemia, this figure shows the mean difference in change in high-density lipoprotein cholesterol compared with controls (k=10) for non-statin intervention trials (Key Question 4)

Figure 25 Familial Hypercholesterolemia: Non-Statin Intervention Trials—Mean Difference in Change in Triglycerides Compared With Controls (k=7) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DHA = Docosahexaenoic acid; g = gram(s); IG = intervention group; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; TG = triglycerides; wks = weeks

For Familial hypercholesterolemia, this figure show the mean difference in change in triglycerides compared with controls (k=7) for non-statin intervention trials (Key Question 4)

Table 32 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Results for Mean Difference in Change in Total Cholesterol (mg/dL), by Intervention (Key Question 4)

Intervention type | Author, Year | Drug Name | Daily Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 3.75 g | 8 | 63 | 65 | −17.90 (−29.92 to −5.88) | 4.20 (−6.30 to 14.70) | −22.10 (−38.03 to −6.17), 0.001^*^
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 1.875 g | 8 | 63 | 65 | −6.40 (−16.77 to 3.97) | 4.20 (−6.30 to 14.70) | −10.60 (−25.37 to 4.17), NSD^*^
Bile acid sequestrant | Tonstad, 1996^126^ | Cholestyramine | 8 mg | 52 | 36 | 36 | Mean % Chg: −11.50 (−16.85 to −6.15) | Mean % Chg: 3.00 (−1.88 to 7.88) | MD in % Chg: −14.50 (−21.74 to −7.26), <0.001
Bile acid sequestrant | Tonstad, 1996b^127^ | Colestipol | 10 g | 8 | 29 | 30 | −45.20 (−65.80 to −24.60) | −4.60 (−22.57 to 13.37) | −40.60 (−67.88 to −13.32), ≤0.01
Ezetimibe | Kusters, 2015^128^ | Ezetimibe | 10 mg | 12 | 85 | 42 | −59.00 (−68.40 to −49.60) | 5.00 (−10.25 to 20.25) | −64.00 (−81.12 to −46.88), <0.001
Fibrate | Wheeler, 1985^129^ | Bezafibrate | 10-20 mg | 13 | 14 | 14 | −57.90 (−84.65 to −31.15) | 27.00 (−4.40 to 58.40) | −84.90 (−126.15 to −43.65), <0.0001
Combination drug therapy | van der Graaf, 2008^131^ | Simvastatin +ezetimibe | 10-40 mg | 33 | 126 | 120 | −125.41 (−133.07 to −117.75) | −85.27 (−93.08 to −77.46) | −40.14 (−51.08 to −29.20), <0.01

* P-value is based on study’s reported ANCOVA of least square mean % change with LOCF to handle missing data. The imputed MD in change (95% CI) as shown was not adjusted.

Abbreviations: ANCOVA = analysis of covariance; BL = baseline; CG = control group; Chg = change; CI = confidence interval; FU = follow up; IG = intervention group; LOCF = last observation carried forward; MD = mean difference; NSD = no significant difference; wks = weeks

Table 33 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Results for Mean Difference in Change in Low-Density Lipoprotein Cholesterol (mg/dL), by Intervention (Key Question 4)

Intervention | Author, Year | Drug Name | Daily Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 3.75 g | 8 | 63 | 65 | −24.10 (−35.94 to −12.26) | 2.00 (−7.80 to 11.80) | −26.10 (−41.43 to −10.77), <0.001^*^
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 1.875 g | 8 | 63 | 65 | −11.20 (−21.30 to −1.10) | 2.00 (−7.80 to 11.80) | −13.20 (−27.27 to 0.87), <0.05^*^
Bile acid sequestrant | Tonstad, 1996^126^ | Cholestyramine | 8 mg | 52 | 22 | 26 | Mean % Chg: −16.90 (−22.90 to −10.80) | Mean % Chg: 1.40 (−4.40 to 7.20) | MD in % Chg: −18.30 (−26.71 to −9.89), 0.0001
Bile acid sequestrant | Tonstad, 1996b^127^ | Colestipol | 10 g | 8 | 29 | 30 | −50.60 (−68.87 to −32.33) | −4.70 (−22.06 to 12.66) | −45.90 (−71.09 to −20.71), ≤0.01
Ezetimibe | Kusters, 2015^128^ | Ezetimibe | 10 mg | 12 | 85 | 42 | −60.00 (−68.98 to −51.02) | 3.00 (−11.97 to 17.97) | −63.00 (−79.54 to −46.46), <0.001
PCSK9 inhibitor | Santos, 2020^130^ | Evolocumab | 420 mg (monthly injections) | 24 | 104 | 53 | −77.50 (−86.10 to −68.90) | −9.00 (−21.10 to 3.20) | −68.60 (−83.10 to −54.00), <0.001
Combination drug therapy | van der Graaf, 2008^131^ | Simvastatin +ezetimibe | 10-40 mg | 33 | 126 | 120 | −122.16 (−129.53 to −114.79) | −84.67 (−92.17 to −77.17) | −37.49 (−48.01 to −26.97), <0.01

* P-value is based on study’s reported ANCOVA of LSM % change with LOCF to handle missing data. The imputed MD in change (95% CI) as shown was not adjusted.

Abbreviations: BL = baseline; CG = control group; Chg = change; CI = confidence interval; FU = follow up; IG = intervention group; MD = mean difference; NSD = no significant difference; PCSK9 = proprotein convertase subtilisin/kexin type 9; wks = weeks

Table 34 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Results for Mean Difference in Change in High-Density Lipoprotein Cholesterol (mg/dL), by Intervention (Key Question 4)

Intervention | Author, Year | Drug | Daily Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 3.75 g | 8 | 63 | 65 | 3.60 (1.02 to 6.18) | 0.70 (−1.52 to 2.92) | 2.90 (−0.49 to 6.29), 0.008^*^
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 1.875 g | 8 | 63 | 65 | 1.80 (−1.36 to 4.96) | 0.70 (−1.52 to 2.92) | 1.10 (−2.75 to 4.95), NSD^*^
Bile acid sequestrant | Tonstad, 1996^126^ | Cholestyramine | 8 mg | 52 | 36 | 36 | Mean % Chg: 13.40 (5.25 to 21.55) | Mean % Chg: 8.80 (0.15 to 17.45) | MD in % Chg: 4.60 (−7.43 to 16.63), NSD
Bile acid sequestrant | Tonstad, 1996b^127^ | Colestipol | 10 g | 8 | 29 | 30 | 2.70 (−1.69 to 7.09) | 2.40 (−0.59 to 5.39) | 0.30 (−4.98 to 5.58),
Ezetimibe | Kusters, 2015^128^ | Ezetimibe | 10 mg | 12 | 85 | 42 | 1.00 (−1.16 to 3.16) | 1.00 (−2.63 to 4.63) | 0.00 (−3.99 to 3.99), 0.807
Fibrate | Wheeler, 1985^129^ | Bezafibrate | 10-20 mg | 13 | 14 | 14 | 10.00 (3.68 to 16.32) | 3.40 (−1.65 to 8.45) | 6.60 (−1.49 to 14.69), NR^†^
Combination drug therapy | van der Graaf, 2008^131^ | Simvastatin +ezetimibe | 10-40 mg | 33 | 126 | 120 | 1.39 (−0.26 to 3.04) | 1.51 (−0.17 to 3.19) | −0.12 (−2.47 to 2.23), 0.58

* P-value is based on study’s reported ANCOVA of LSM % change with LOCF to handle missing data. The imputed MD in change (95% CI) as shown was not adjusted.

† Study reported statistical significance between treatment and placebo periods (p<0.001) based on absolute values and not for MD in change from BL. The overall HDL-C was not significant during placebo period than in the period before the trial.

Abbreviations: BL = baseline; CG = control group; Chg = change; CI = confidence interval; FU = follow up; IG = intervention group; MD = mean difference; NR = not reported; NSD = no significant difference; wks = weeks

Table 35 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Results for Mean Difference in Change in Triglyceride Levels (mg/dL), by Intervention (Key Question 4)

Intervention | Author, Year | Drug Name | Daily Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 3.75 g | 8 | 63 | 65 | Mean % Chg: 17.40 (NR) | Mean % Chg: 12.30 (NR) | MD in % Chg: 5.10 (NR), 0.466
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 1.875 g | 8 | 63 | 65 | 18.50 (NR) | 12.30 (NR) | 6.40 (NR), NSD
Bile acid sequestrant | Tonstad, 1996^126^ | Cholestyramine | 8 mg | 52 | 36 | 36 | NR | NR | NR, NSD^*^
Bile acid sequestrant | Tonstad, 1996b^127^ | Colestipol | 10 g | 8 | 29 | 30 | 14.20 (−11.42 to 39.82) | −10.70 (−28.82 to 7.42) | 24.90 (−6.31 to 56.11),
Ezetimibe | Kusters, 2015^128^ | Ezetimibe | 10 mg | 12 | 85 | 42 | −2.00 (−9.67 to 5.67) | 8.00 (−10.92 to 26.92) | −10.00 (−27.17 to 7.17), NSD^†^
Fibrate | Wheeler, 1985^129^ | Bezafibrate | 10-20 mg | 13 | 14 | 14 | −29.20 (−44.44 to −13.96) | −11.50 (−26.10 to 3.10) | −17.70 (−38.80 to 3.40), NSD
Combination drug therapy | van der Graaf, 2008^131^ | Simvastatin +ezetimibe | 10-40 mg | 33 | 126 | 120 | Med % Chg (SD): −20.0 (23.8) | Med % Chg (SD): −13.0 (39.0) | Med diff in Chg: −9.50 (NR), <0.01^‡^

* Mean triglyceride levels remained unchanged in both groups (mean, 80 to 89 mg/dL; SD, 35 to 53 mg/dL).

† Geometric mean % change based on log-transformed data using a constrained longitudinal data analysis model was statistically significant (p=0.021), but the p-value was NS based on prespecified multiplicity adjustment.

‡ SD of median was derived by IQR/1.075.

Abbreviations: BL = baseline; CG = control group; Chg = change; CI = confidence interval; FU = follow up; g = gram; IG = intervention group; MD = mean difference; Med = median; mg = milligram; NR = not reported; NSD = no significant difference; SD = standard deviation

Table 36 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Results for Mean Difference in Change in Non-High-Density Lipoprotein Cholesterol (mg/dL), by Intervention (Key Question 4)

Intervention | Author, Year | Statin | Daily Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 3.75 g | 8 | 63 | 65 | −21.40 (−33.72 to −9.08) | 3.50 (−7.03 to 14.03) | −24.90 (−41.07 to −8.73), 0.0001^*^
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 1.875 g | 8 | 63 | 65 | −7.70 (−17.88 to 2.48) | 3.50 (−7.03 to 14.03) | −11.20 (−25.86 to 3.46), NSD^*^
Ezetimibe | Kusters, 2015^128^ | Ezetimibe | 10 mg | 12 | 85 | 42 | −60.00 (−69.19 to −50.81) | 5.00 (−11.05 to 21.05) | −65.00 (−82.25 to −47.75), <0.001
PCSK9 inhibitor | Wheeler, 1985^129^ | Evolocumab | 420 mg (monthly injections) | 24 | 104 | 53 | Mean % Chg: −41.20 (−45.20 to −37.20) | Mean % Chg: −6.10 (−11.80 to −0.50) | MD in % Chg: −35.10 (−42.00 to −28.20), <0.001
Combination drug therapy | van der Graaf, 2008^131^ | Simvastatin +ezetimibe | 10-40 mg | 33 | 126 | 120 | −126.78 (−134.52 to −119.04) | −86.84 (−94.76 to −78.92) | −39.94 (−51.01 to −28.87), <0.01

* P-value is based on study’s reported ANCOVA of LSM % change with LOCF to handle missing data. The imputed MD in change (95% CI) as shown was not adjusted.

Abbreviations: BL = baseline; CG = control group; Chg = change; CI = confidence interval; FU = follow up; g = gram; IG = intervention group; MD = mean difference; Med = median; mg = milligram; NR = not reported; NSD = no significant difference; PCSK9 = proprotein convertase subtilisin/kexin type 9

Table 37 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Results for Proportion Achieving Low-Density Lipoprotein Cholesterol Goal (Absolute Risk Difference, %), by Intervention (Key Question 4)

Drug Category | Author, Year | Drug | Daily Dose | LDL-C Goal (mg/dL) | IG | IG N | CG N | IG n/N (%) | CG n/N (%) | % ARD (95% CI)
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 3.75 g | <110 | 8 | 63 | 65 | 5/63 (7.9) | 0/65 (0.0) | 7.94 (1.26 to 14.61)
Bile acid sequestrant | Stein, 2010^125^ | Colesevelam | 1.875 g | <110 | 8 | 63 | 65 | 2/63 (3.2) | 0/65 (0.0) | 3.17 (−1.15 to 7.50)
PCSK9 inhibitor | Santos, 2020^130^ | Evolocumab | 420 mg (monthly injections) | <130 | 24 | 96 | 44 | 71/96 (74.0) | 10/44 (22.7) | 51.23 (36.05 to 66.41)
PCSK9 inhibitor | Santos, 2020^130^ | Evolocumab | 420 mg (monthly injections) | >50% reduction | 24 | 96 | 44 | 43/96 (44.8) | 1/44 (2.3) | 42.52 (31.64 to 53.40)
PCSK9 inhibitor | Santos, 2020^130^ | Evolocumab | 420 mg (monthly injections) | <100 | 24 | 96 | 44 | 60/96 (62.5) | 1/44 (2.3) | 60.23 (49.59 to 70.87)
Combination drug therapy | van der Graaf, 2008^131^ | Simvastatin and ezetimibe | 10-40 mg | <110 | 33 | 126 | 120 | 79/126 (62.7) | 32/120 (26.7) | 36.03 (24.46 to 47.60)
Combination drug therapy | van der Graaf, 2008^131^ | Simvastatin and ezetimibe | 10-40 mg | <130 | 33 | 126 | 120 | 97/126 (77.0) | 64/120 (53.3) | 23.65 (12.09 to 35.21)

Abbreviations: AAP = American Academy of Pediatrics; ARD = absolute risk difference; CG = control group; CI = confidence interval; g = gram; IG = intervention group; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; PCSK9 = proprotein convertase subtilisin/kexin type 9

#### Drug Therapy Intervention: Ezetimibe

##### Trial and Participant Characteristics

We identified one good-quality trial (n=138), examining the effectiveness of the cholesterol absorption inhibitor, ezetimibe, to improve lipid levels in children with FH (Tables 29 and 30).^128^ This trial was included in the previous review. The trial collected data between 2009 and 2012 and recruited from 29 sites across nine countries including the US, Canada, Colombia, France, Greece, Italy, Norway, the Netherlands, and Israel. Participants were aged 6-10 years with heterozygous FH diagnosed by genotype or clinical criteria or clinically important non-FH defined as LDL >159 to <400 mg/dL while on lipid lowering diet for ≥3 months. Ninety-one percent of participants had FH and, thus, this trial was considered an FH trial; stratified results are reported by type of hyperlipidemia. Mean age was 8 years and 57 percent of participants were female. Most participants were White (80%), with 15 percent reporting multiracial heritage, 1 percent Black, and 3 percent Asian. Mean baseline fasting TC was 293 mg/dL, LDL-C was 227 mg/dL, HDL-C was 50 mg/dL and TG was 85 mg/dL (Figure 21).

##### Intervention Characteristics

After a drug washout period of up to 13 weeks, there was a 5-week placebo run-in with diet stabilization period in all participants (Table 31). The intervention group (n=93) then received oral ezetimibe 10 mg daily and the control group (n=45) received placebo tablets for 12 weeks. Overall adherence in the trial was high with a mean of 95 percent medication compliance at each visit in both the placebo and control groups.

##### Outcomes (Results)

At 12 weeks, ezetimibe was associated with a statistically significant reduction in TC (MD in change-64.0 mg/dL [95% CI, −81.1 to −46.9]), LDL-C (MD in change-63.0 mg/dL [95% CI, −79.5 to −46.5]), and non-HDL-C (MD in change −65.0 mg/dL [95% CI, −82.2 to −47.8]) (Figures 22–25; Tables 32–36).^128^ Changes in HDL and TG were not significant. The outcome of percent change in LDL-C from baseline was reported for subgroups of participants with FH and clinically important non-FH. LDL reductions appeared smaller in participants with non-FH but only 12 participants were analyzed in this subgroup, so confidence intervals were wide and overlapped those for participants with FH.

#### Drug Therapy Intervention: Fibrate

##### Trial and Participant Characteristics

We identified one very small fair-quality randomized crossover trial (n=14) examining the effectiveness of fibrates to improve lipid levels in children with FH (Tables 29 and 30).^129^ The drug, bezafibrate, is not available in the U.S and not FDA-approved in children; currently, there are no fibrates that are FDA-approved in children. This trial was not included in the previous review. The study was conducted in the UK. Participants were aged 4-15 years with FH diagnosed by serum lipid levels and family history who previously failed dietary treatment and refused to continue taking cholestyramine. Mean age was 11 years and 57 percent of participants were female. Race and ethnicity were not reported. Mean baseline fasting TC was 359 mg/dL, HDL-C 39 mg/dL, TG 89 mg/dL, and baseline LDL-C was not reported (Figure 21).

##### Intervention Characteristics

In a randomized crossover design, participants were allocated to receive bezafibrate 10-20 mg/kg/day twice per day or placebo for three months and were then crossed over to receive the other treatment for three additional months (Table 31). Prior to the trial, all children were treated with dietary modification (low saturated fat and increased polyunsaturated fat diet) which did not reduce lipid levels adequately and were then placed on a bile acid sequestrant which was eventually refused in all subjects. Participants had a washout period from any cholesterol medications for at least three months prior to randomization. Adherence was high with 93 percent of participants having bezafibrate detected in the urine during the active treatment period. All children reported a preference for bezafibrate compared with prior cholestyramine resin treatment.

##### Outcomes (Results)

At 13 weeks, bezafibrate was associated with statistically significant improvement in TC but not HDL-C or TG (Figures 22, 24–25; Tables 32, 34–35). Active treatment with bezafibrate was associated with an 84.9 mg/dL greater reduction in TC compared to the control group (95% CI, −126.2 to −43.6).

#### Drug Therapy Intervention: PCSK9 Inhibitors

##### Trial and Participant Characteristics

We identified one new good-quality trial (n=158), examining the effectiveness of a PSCK9 inhibitor, evolocumab, to improve lipid levels in children and adolescents with heterozygous FH (Tables 29 and 30).^130^ The trial collected data between 2016 and 2019 and recruited from 47 sites across 23 countries in North America, Latin America, Europe and the Asia-Pacific region. Participants were ages 10-17 years with heterozygous FH diagnosed either by genetic testing or clinical diagnostic criteria. Lipid inclusion criteria were LDL-C ≥130 mg/dL and ≤400 mg/dL while on a low-fat diet and stable lipid-lowering therapy for at least 4 weeks prior to screening. Mean age was 14 years and 56 percent of participants were female. Most participants self-identified as White (86%) and representation from other races or ethnicities was not reported, however, 16 percent of participants were recruited from Latin America and 4 percent were recruited from the Asia-Pacific region. Approximately one-third of participants had overweight or obesity. At baseline, 79 percent were taking a moderate or high intensity statin medication and 13 percent were additionally taking ezetimibe. Mean fasting TC was 250 mg/dL, mean LDL-C was 184 mg/dL, mean HDL-C was 47 mg/dL, and mean TGs were 84 mg/dL (Figure 21).

##### Intervention Characteristics

The intervention group (n=104) received evolocumab 420 mg via monthly subcutaneous injection for 24 weeks (Table 31). The injections could be self-administered or administered by a designee or health professional. The control group (n=53) received monthly placebo subcutaneous injections. Adherence was high in the intervention group with 96 percent of participants competing the trial.

##### Outcomes (Results)

At 24 weeks, evolocumab was associated with a large and statistically significant reduction in LDL-C as measured by percent change (−38.3% [95% CI, −45.5% to −31.1%]) and absolute mean change (−68.6 mg/dL [95% CI, −83.1 to −54.0]) (Figure 23; Tables 33, 36, and 37). Likewise, evolocumab was associated with a statistically significant difference in non-HDL (−35.1% [95% CI, −42.0% to −28.2%]). More participants in the PCSK9 intervention group reached LDL goals, either as defined by LDL-C <100 mg/dL (62.5% vs 2.3%, ARD 60.2 [95% CI, 49.6 to 70.9]) or by >50% reduction in LDL (44.8% vs 2.3%, ARD 42.5% [95% CI, 31.6 to 53.4]). Evolocumab was not associated with statistically significant changes in cIMT over 24 weeks as assessed from several measures of cIMT thickness. For example, the mean change in difference between the intervention and placebo groups in the average of largest left and right common carotid artery was −0.01 mm (95% CI, −0.03 to 0.01).

#### Drug Therapy Intervention: Combination Therapy

##### Trial and Participant Characteristics

One fair-quality RCT (n=248) examined the effectiveness of a two-drug intervention (simvastatin and ezetimibe) compared to single drug therapy (simvastatin alone) to lower lipids in adolescents with FH (Tables 29 and 30).^131^ This multinational RCT included male and post-menarchal female adolescents ages 10-17 years with Tanner stage ≥2 and FH. Mean age was 14 years with 43 percent female participants. Participants were mostly White (82%), with few Black (2%) or Asian (4%) participants, and 13 percent reported as ‘other’ race/ethnicity. Mean baseline fasting LDL-C was 222 mg/dL (Figure 21).

##### Intervention Characteristics

The intervention group was randomized to receive simvastatin 10, 20 or 40 mg per day plus ezetimibe 10 mg/d for 6 weeks; then all intervention arms received the same dose of simvastatin (40 mg/d) and ezetimibe (10 mg/d) for 27 weeks (Table 31).^131^ The control groups were randomized to receive simvastatin 10, 20 or 40 mg plus one placebo tablet.

##### Outcomes (Results)

At 33 weeks, the two-drug intervention was associated with a significant improvement in all lipid parameters compared with the single-drug intervention, except for HDL-C, which showed no statistically significant difference (Figures 22–24; Tables 32–37). The two-drug intervention showed a greater reduction in TC (MD in change −40.1 mg/dL [95% CI, −51.1 to −29.2]), LDL-C (MD in change −37.5 mg/dL [95% CI, −48.0 to −27.0]), TG (−9.5 median difference in percent change, p<0.01), and non-HDL-C (MD in change −40.0 mg/dL [95% CI, −51.0 to −28.9]) compared to the single-drug intervention control group. The intervention group was more likely to reach the LDL-C goal of <110 mg/dl than the control group (62.7% v 26.7%, ARD 36.0% [95% CI, 24.5 to 47.6]).

#### Behavioral Counseling Interventions

##### Trial and Participant Characteristics

We identified one new fair-quality trial (n=21) that examined the effectiveness of behavioral counseling interventions to improve lipid levels and dietary and physical activity habits in children and adolescents with FH (Table 38–39).^132^ This U.S. trial recruited children and adolescents ages 10-18 years with FH from outpatient lipid clinics. Data were collected in 2018-2019. Mean age was 14 years; half of participants were female; 82 percent were White and 18 percent Asian. Eighteen percent had an overweight weight status and 9 percent had an obese weight status. At baseline, approximately one-quarter (23%) were on behavioral treatment only and most (77%) were on statin medications. Mean fasting TC was 193 mg/dL, LDL 127 mg/dL, and HDL 50 mg/dL.

Table 38 Familial Hypercholesterolemia: Behavioral Intervention Trials—Study Characteristics (Key Question 4)

Author, Year | Brief Population Desc | Condition criteria | Country | Yrs of data collection | N Rand
Kinnear, 2020^132^ | Children and adolescents aged 10-18 years with FH | Genetic diagnosis of FH | US | 2018-2019 | 21

Abbreviations: Desc = description; FH= familial hypercholesterolemia; Rand = randomized; US = United states; Yrs = years

Table 39 Familial Hypercholesterolemia: Behavioral Intervention Trials—Population Characteristics (Key Question 4)

Author, Year | Age, Mean (Range) | Female, % | Race/Ethnicity, % | BMI | Smoking, % | Other BL Characteristic | Mean Fasting TC (mg/dL) | Mean Fasting LDL-C (mg/dL) | Mean Fasting HDL-C (mg/dL) | Mean Fasting TG (mg/dL)
Kinnear, 2020^132^ | 14 (10-18) | 50 | White: 82; Black: 0; Asian: 18; Native American: 0; Latino: 0; Other: 0 | Overweight: ≥91st percentile: 18; Obese: ≥98th percentile: 9 | 0 | On lifestyle treatment only, n (%): 5 (23); On statin medication, n (%): 17 (77) | 193 | 127 | 50 | NR

Abbreviations: BL = baseline; BMI = body mass index; CVD = cardiovascular disease; FH= familial hypercholesterolemia; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; NR = not reported; SES = socioeconomic status; TC = total cholesterol; TG = triglycerides

##### Intervention Characteristics

This RCT tested a low-intensity intervention of one in-person 60-minute individual session with a dietician and four followup sessions via email or phone over a 12-week period (Table 40). The intervention consisted of 26 behavioral change techniques aimed to reduce total and saturated fat and cholesterol; increase intake of unsaturated fat, fiber, fruits and vegetables, and plant stanol or sterol fortified foods; reduce sedentary behavior and increase PA. The control group participants received usual care (annual outpatient lipid clinic visit) and were placed on a waitlist to receive the intervention after the trial. Adherence to the initial session and first three followup sessions was complete (100%) and the majority (60%) completed the fourth follow-up sessions.

Table 40 Familial Hypercholesterolemia: Behavioral Intervention Trials—Intervention Characteristics (Key Question 4)

Author, Year | IG n | IG Brief Description | Behavioral Intv Approach | Intv Setting Provider | CG Category | CG n | CG Description
Kinnear, 2020^132^ | 10 | 1 in-person 60-min individual session with dietitian and 4 email or telephone follow-up sessions over 12 weeks | Behavioral change techniques | Lipid clinic, home; Dietitian | Waitlist | 12 | Waitlist to receive the intervention at the end of the 12-week study period and received usual care, which comprised an annual outpatient lipid clinic appointment.

Abbreviations: CG = control group; FH= familial hypercholesterolemia; IG = intervention group; Intv = intervention; min = minute

##### Outcomes (Results)

At 12 weeks, results were mixed across lipid, physical activity, and dietary outcomes. There were no statistically significant differences between the intervention and control groups for changes in any serum lipid outcomes (TC, LDL-C, HDL-C) (Figures 22–24; Table 41). No statistical testing was done for adiposity and activity outcomes, including median changes in BMI, body fat percentage, moderate and vigorous physical activity, and sedentary time (Appendix E Table 3). General trends for these outcomes were more favorable for the intervention group compared to the control group, with overlapping ranges in both groups. The intervention was associated with statistically significant improvement in some but not all dietary measures. For example, more participants in the intervention group met dietary goals of consuming 2 g/d of plant stanols or sterols (90% v 0%) and the intervention group ate 2 additional portions of fruits/vegetables per day compared with the control group (adjusted difference, 2.2 portions [95% CI 1.2 to 3.2]) There was a statistically significant 5 percent difference between the intervention and control groups in fat intake as measured by percent of total energy intake (−5.3% [95% CI −8.9 to −1.5]), but the reduction in saturated fat intake was not statistically significant and intake of recommended fats—monounsaturated fatty acids (MUFA) and polyunsaturated fatty acids (PUFA)—either showed a statistically significant reduction (MUFA: −3.2% of total energy [95% CI −5.3 to −1.01]) or no difference (PUFA). No statistical differences were seen in cholesterol or fiber intake.

Table 41 Familial Hypercholesterolemia: Behavioral Intervention Trials—Results for Mean Difference in Change in Serum Lipid Levels (mg/dL) (Key Question 4)

Author, Year | Serum Lipid Outcome | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Kinnear, 2020^132^ | TC | 12 | 8 | 10 | −7.70 (−56.09 to 40.69) | 3.90 (−17.51 to 25.31) | −11.58 (−34.75 to 15.44)
Kinnear, 2020^132^ | LDL-C | 12 | 8 | 10 | −11.50 (−48.59 to 25.59) | 3.80 (−16.40 to 24.00) | −13.90 (−31.66 to 4.63)
Kinnear, 2020^132^ | HDL-C | 12 | 8 | 10 | 0.00 (−8.04 to 8.04) | 3.90 (−3.18 to 10.98) | 0.39 (−3.86 to 7.72)

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; FH= familial hypercholesterolemia; FU = follow up; HDL-C = high-density lipoprotein cholesterol; IG = intervention group; LDL-C = low-density lipoprotein cholesterol; TC = total cholesterol

#### Supplement Interventions

##### Trial and Participant Characteristics

We identified four new fair-quality randomized crossover trials (n=116) that examined the effectiveness of supplements to improve lipid levels in children and adolescents with FH (Tables 42 and 43).^133–136^ Trials were set in the Netherlands,^133^ Finland,^134^ Norway,^135^ and the US.^136^ Trial sizes were generally small, ranging from 14 to 41 participants. The trials recruited children and adolescents ranging in age from 2 to 21 years of age with heterozygous FH based on varied criteria using serum lipids, genetic mutation confirmation, or family history (Figure 9). Mean ages ranged from age 9 to 10 years; the trial with older participants—ranging from 9 to 19 years—did not report mean age.^136^ The trials included approximately half female participants. Race and ethnicity were not reported. Mean baseline fasting lipids in the trials were: TC 271-297 mg/dL, LDL-C 208-219 mg/dL, HDL-C 42-53 mg/dL; mean TG varied substantially in the trials from 50-133 mg/dL (Figure 21).

Table 42 Familial Hypercholesterolemia: Supplement Intervention Trials—Study Characteristics (Key Questions 4 and 5)

Author, Year; Quality | Study design | Condition criteria | Brief Population Desc | Country | N Rand
de Jongh, 2003^133^; Fair | Randomized crossover | Plasma LDL-C >95th percentile for age and gender; documented family history of hyperlipidemia with LDL-C >95th percentile for age and gender before treatment or a personal diagnosis of FH by detection of a mutation in the LDL-C receptor gene | Prepubertal heterozygous FH children between 5 and 12 years of age | The Netherlands | 41
Gylling, 1995^134^; Fair | Randomized crossover | Primarily by DNA technique; no other details reported | Children and adolescents 2-15 years with heterozygous FH | Finland | 14
Amundsen, 2002^135^; Fair | Randomized crossover | All subjects had a mother or father with hypercholesterolemia and were diagnosed with “definite” or “possible” heterozygous FH. The diagnosis was confirmed by documentation of the presence of an FH mutation in 25 (of 41) of the children. | Children and adolescents aged 7-12 years with FH | Norway | 41
Engler, 2005^136^; Fair | Randomized crossover | LDL-C >130 mg/dL and a parent diagnosed with FH or familial combined hyperlipidemia (LDL-C >130 mg/dL and/or TG >150 mg/dL, and a parent with 1 of these phenotypes) | Children 8-21 years with FH or familial combined hypercholesterolemia | US | 20

Abbreviations: DNA = deoxyribonucleic acid; FH= familial hypercholesterolemia; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; Rand = randomized; TG = triglycerides; US = United States

Table 43 Familial Hypercholesterolemia: Supplement Intervention Trials—Population Characteristics (Key Questions 4 and 5)

Author, Year | Age, Mean (Range) | Female, % | Race/Ethnicity, % | BMI | Smoking, % | Other BL Characteristic | Mean Fasting TC (mg/dL) | Mean Fasting LDL-C (mg/dL) | Mean Fasting HDL-C (mg/dL) | Mean Fasting TG (mg/dL)
de Jongh, 2003^133^ | 9; (5-12) | 51 | NR | NR | 0 | NR | 282 | 219 | 48 | 65^*^
Gylling, 1995^134^ | 9; (2-15) | 50 | NR | NR | NR | NR | 297 | NR | NR | 77
Amundsen, 2002^135^ | 10 (NR) | NR | NR | NR | NR | Reached menarche: 7.3% | 271 | 208 | 53 | 50
Engler, 2005^136^ | NR; (9-19) | 45 | NR | NR | 0 | NR | 275 | 214 | 42 | 133

* Median.

Abbreviations: BL = baseline; BMI = body mass index; CVD = cardiovascular disease; FH= familial hypercholesterolemia; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; NR = not reported; SES = socioeconomic status; TC = total cholesterol; TG = triglycerides

##### Intervention Characteristics

The supplements included plant sterols,^133,^ ^135^ the omega-3 fatty acid docosahexaenoic acid (DHA),^136^ and a combination of plant sterol/stanol and omega fatty acids administered as rapeseed margarine plus sitostanol ester (Table 44).^134^ Supplements were administered as food spreads or capsules, and interventions were short term, ranging from 4 to 8 weeks (Figure 12). The intervention groups received 15 g spread containing 2.3 g/d of plant sterols (sitosterol and campesterol) over 4 weeks,^133^ 20 g spread of 1.76 g/d plant sterol esters over 8 weeks,^135^ 24 g/d rapeseed margarine containing 3g/d sitostanol ester over 6 weeks,^134^ or 6 capsules per day containing 1.2 g DHA over 6 weeks.^136^ The control groups received control spreads^133–135^ or corn/soy oil capsules.^136^ Adherence was high in all trials as measured by returned spread tubs (>90% of spread consumed)^133–135^ and pill counts (reported as “excellent compliance”).^136^

Table 44 Familial Hypercholesterolemia: Supplement Intervention Trials—Intervention Characteristics (Key Questions 4 and 5)

Author, Year | IG n | Intervention | Daily Dose | IG Brief Description | Run-In; Background Diet | CG Category | CG N | CG Description
de Jongh, 2003^133^ | 41 | plant sterols | 15 g over 4 wks | Spreads containing 2.3 g of plant sterols (mainly sitosterol and campesterol) per 15 g spread for 4 wks | 2 mo compliance with dietary instruction from trained nutritionist; Low-saturated-fat, low-cholesterol diet (Step I) | Placebo | 41 | Control spread containing 5.4 g of fat (composed of 23.2% SFA, 25.5% MUFA and 50.8% PUFA) per 15 g of spread.
Gylling, 1995^134^ | 14 | rapeseed margarine + sistostanol ester | 3 g over 6 wks | Rapeseed oil-rich margarine with sitostanol ester (3 g sitostanol) for 6 weeks | None; all families had been on low animal-fat, low cholesterol diet for years prior; Low animal fat, low cholesterol diet rich in monoenic fatty acids | Placebo | 14 | Replacement of 24 g of normal daily fat intake by the same amount of a rapeseed oil-rich margarine without sitostanol ester.
Amundsen, 2002^135^ | 41 | plant sterols | 20 g of spread (1.76 g plant sterol) over 8 wks | 20 g of plant sterol esters-enriched spread per day (containing 1.76 g plant sterols) for 8 weeks. Spread contained 8.8% free plant sterols, of which 50% was sitosterol. | 3 wk run-in of control spread in small tubs of 20 g. A compliance rate of 50% was required for the subjects to continue in the study.; AHA Step I diet | Placebo | 41 | Control spread in small tubs of 20 g.
Engler, 2005^136^ | 20 | DHA | 1.2 g over 6 wks | Six capsules/day of DHA (1.2 g) for 6 weeks | Washout and run-in before 2nd intervention periods; Nutrition counseling based on NCEP II diet and food guide pyramid | Placebo | 20 | 6 capsules/day of corn/soy oil for 6 weeks.

Abbreviations: AHA = American Heart Association; CG = control group; DHA = docosahexaenoic acid; FH= familial hypercholesterolemia; g = gram; IG = intervention group; MUFA = monounsaturated fatty acid; NCEP = National Cholesterol Education Program; PUFA = polyunsaturated fatty acids; SAFA = saturated fatty acid; SE = standard error; wk/wks = week(s)

##### Outcomes (Results)

Two of four supplement trials showed statistically significant TC and LDL-C reductions favoring the intervention groups; these were trials evaluating 1.76 g/d or 2.3 g/d plant sterols (Figures 22–25; Tables 45–48).^133,^ ^135^ De Jongh and colleagues reported that the 4 week plant sterol intervention was associated with a 30 mg greater reduction in TC (−30.5 mg/dL [95% CI, −39.4 to −23.2]) and LDL-C (−30.1 mg/dL [95% CI, −38.6 to −23.2]) compared to the control group.^133^ The 8 week trial by Amundsen and colleagues similarly reported significant reductions in TC (−20.5 mg/dL [95% CI, −36.1 to −8.6]) and LDL-C (−22.4 mg/dL [95% CI, −34.5 to −6.5]) compared to the control group.^135^ The trial evaluating the supplement combination of plant sterol/stanol and omega fatty acids administered as rapeseed margarine plus sitostanol ester found a similar magnitude of TC and LDL-C reduction, but failed to reach statistical significance compared to the control group (TC: MD −31.3 mg/dL [95% CI, −67.7 to 5.1]; LDL-C −31.7 mg/dL [95% CI, −67.2 to 3.8]).^134^ In the trial evaluating the omega-3 fatty acid DHA, TC and LDL-C increased in the intervention group compared to the control group but differences were not statistically significant and confidence intervals were wide (TC: MD 9.0 mg/dL [95% CI, −45.7 to 63.7]; LDL-C 10.0 mg/dL [95% CI, −45.2 to 65.2]).^136^ There were no statistically significant differences between the intervention and control groups for HDL-C or TG.

Table 45 Familial Hypercholesterolemia: Supplement Intervention Trials—Results for Mean Difference in Change in Total Cholesterol (mg/dL) (Key Question 4)

Author, Year | Supplement | Daily Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Amundsen, 2002^135^ | Plant sterols | 20 g of spread (1.76 g plant sterol) | 8 | 38 | 38 | −19.60 (−38.25 to −0.95) | 0.80 (−20.32 to 21.92) | −20.46 (−36.14 to −8.64), 0.007
de Jongh, 2003^133^ | Plant sterols | 15 g | 4^*^ | 41 | 41 | −39.80 (−55.84 to −23.76) | −9.30 (−26.28 to 7.68) | −30.50 (−39.38 to −23.17), <0.001
Engler, 2005^136^ | DHA | 1.2 g | 6 | 20 | 20 | 10.00 (−28.16 to 48.16) | 1.00 (−38.23 to 40.23) | 9.00 (−45.72 to 63.72)
Gylling, 1995^134^ | Rapeseed margarine + sistostanol ester | 3 g | 6 | 14 | 14 | −33.60 (−59.68 to −7.52) | −2.30 (−27.75 to 23.15) | −31.30 (−67.74 to 5.14), NR

* Capillary lipid profile.

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; DHA = docosahexaenoic acid; FH= familial hypercholesterolemia; FU = follow up; g = gram; IG = intervention group; MD = mean difference; NR = not reported; wks = weeks

Table 46 Familial Hypercholesterolemia: Supplement Intervention Trials—Results for Mean Difference in Change in Low-Density Lipoprotein Cholesterol (mg/dL) (Key Question 4)

Author, Year | Supplement | Daily Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Amundsen, 2002^135^ | Plant sterols | 20 g of spread (1.76 g plant sterol) | 8 | 38 | 38 | −19.70 (−39.77 to 0.37) | 3.10 (−19.00 to 25.20) | −22.39 (−34.46 to −6.47), 0.003
de Jongh, 2003^133^ | Plant sterols | 15 g | 4^*^ | 41 | 41 | −42.50 (−58.75 to −26.25) | −10.80 (−28.02 to 6.42) | −30.12 (−38.61 to −23.17), <0.001
Engler, 2005^136^ | DHA | 1.2 g | 6 | 20 | 20 | 12.00 (−26.37 to 50.37) | 2.00 (−37.68 to 41.68) | 10.00 (−45.19 to 65.19)
Gylling, 1995^134^ | Rapeseed margarine + sistostanol ester | 3 g | 6 | 14 | 14 | −38.30 (−63.75 to −12.85) | −6.60 (−31.41 to 18.21) | −31.70 (−67.24 to 3.84)

* Capillary lipid profile.

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; DHA = docosahexaenoic acid; FH= familial hypercholesterolemia; FU = follow up; g = gram; IG = intervention group; MD = mean difference; NR = not reported; wks = weeks

Table 47 Familial Hypercholesterolemia: Supplement Intervention Trials—Results for Mean Difference in Change in High-Density Lipoprotein Cholesterol (mg/dL)

Author, Year | Supplement | Daily Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Amundsen, 2002^135^ | Plant sterols | 20 g of spread (1.76 g plant sterol) | 8 | 38 | 38 | 1.10 (−2.92 to 5.12) | 0.00 (−4.07 to 4.07) | 1.31 (−2.00 to 4.63), NSD
de Jongh, 2003^133^ | Plant sterols | 15 g | 4^*^ | 41 | 41 | 2.30 (−11.03 to 15.63) | 1.50 (−11.90 to 14.90) | 0.77 (−2.32 to 3.86), 0.594
Engler, 2005^136^ | DHA | 1.2 g | 6 | 20 | 20 | 1.00 (−3.02 to 5.02) | 2.00 (−1.51 to 5.51) | −1.00 (−6.33 to 4.33)
Gylling, 1995^134^ | Rapeseed margarine + sistostanol ester | 3 g | 6 | 14 | 14 | 3.10 (−2.62 to 8.82) | 1.10 (−4.19 to 6.39) | 2.00 (−5.80 to 9.80)

* Capillary lipid profile.

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; DHA = docosahexaenoic acid; FH= familial hypercholesterolemia; FU = follow up; g = gram; IG = intervention group; MD = mean difference; NR = not reported; NSD = no significant difference; wks = weeks

Table 48 Familial Hypercholesterolemia: Supplement Intervention Trials—Results for Mean Difference in Change in Triglyceride Levels (mg/dL) (Key Question 4)

Author, Year | Supplement | Daily Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Amundsen, 2002^135^ | plant sterols | 20 g of spread (1.76 g plant sterol) | 8 | 38 | 38 | −3.50 (−14.85 to 7.85) | −11.50 (−29.32 to 6.32) | 8.41 (−12.98 to 29.79), NSD
de Jongh, 2003^133^ | plant sterols | 15 g | 4^*^ | 41 | 41 | NR | NR | −4.43 (−17.70 to 7.97), 0.476
Engler, 2005^136^ | DHA | 1.2 g | 6 | 20 | 20 | −19.00 (−47.58 to 9.58) | −17.00 (−46.59 to 12.59) | −2.00 (−43.13 to 39.13)
Gylling, 1995^134^ | rapeseed margarine + sistostanol ester | 3 g | 6 | 14 | 14 | 4.40 (−14.93 to 23.73) | 14.20 (−6.27 to 34.67) | −9.80 (−37.95 to 18.35)

* Capillary lipid profile.

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; DHA = docosahexaenoic acid; FH= familial hypercholesterolemia; FU = follow up; g = gram; IG = intervention group; MD = mean difference; NR = not reported; wks = weeks

### Multifactorial Dyslipidemia

#### Drug Therapy Interventions

There were no included trials of drug interventions in child and adolescent populations with multifactorial dyslipidemia.

#### Behavioral Counseling Interventions

##### Trial and Participant Characteristics

We identified two behavioral counseling trials—one fair-quality^137^ and one good-^138^ quality—in children and adolescents with multifactorial dyslipidemia (N total=934) (Tables 49 and 50). One trial was included in the prior review, and one was newly included. The Dietary Intervention Study in Children (DISC) (n=663) was a 7-year U.S. study initiated in the 1980s that recruited prepubertal children aged 7 to 10 years with LDL-C ≥80^th^ and <98^th^ percentiles for age and sex.^138^ These participants were recruited from multiple settings including schools, pediatric practices, and HMO mailing lists. The Children’s Health Project (CHP) (n=271) was a 1-year UK study initiated in the early 1990s that recruited children ages 4 to 10 years from a cholesterol screening program at nine suburban pediatric practices.^137^ The children had initially elevated TC screening results (>176 mg/dL) and subsequently elevated mean fasting LDL-C and weighed ≥85% and <130% of ideal body weight.

Table 49 Multifactorial Dyslipidemia: Behavioral Intervention Trials—Study Characteristics (Key Question 4)

Author, Year; Study Name; Quality | Condition Criteria | Brief Population Description | Country | Yrs of Data Collection | N Rand
DISC Collaborative Research Group, 1995^138^; Dietary Intervention Study in Children (DISC); Good | LDL-C ≥80th and <98th percentiles for age and sex | Children aged 7-10 years, Tanner stage 1, with LDL-C between ≥80th (≥111.5 mg/dL for males and ≥117.5 mg/dL for females) and <98th (<164.5 mg/dL for males and females) for age and sex-specific percentiles | US | 1988-1990 | 663
Shannon, 1994^137^; Children’s Health Project (CHP); Fair | Initial screening TC > 176 mg/dL; subsequent mean fasting LDL-C for males between 107 to 164 mg/dL and for females between 112 to 164 mg/dL | Children aged 4-10 years with MFD | UK | 1990-1992 | 271

Abbreviations: DISC = The Dietary Intervention Study in Children; HDL-C = high-density lipoprotein cholesterol; HMO = Health Maintenance Organization; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; Rand = randomized; TC = total cholesterol; UK = United Kingdom; US = United States; Yrs = years

Table 50 Multifactorial Dyslipidemia: Behavioral Intervention Trials—Population Characteristics (Key Question 4)

Author, Year; Study Name | Age, Mean (Range) | Female, % | Race/Ethnicity, % | BMI | Smoking, % | Other BL Characteristic | Mean Fasting TC (mg/dL) | Mean Fasting LDL-C (mg/dL) | Mean Fasting HDL-C (mg/dL) | Mean Fasting TG (mg/dL)
DISC Collaborative Research Group, 1995^138^; Dietary Intervention Study in Children (DISC) | 9; (7-10) | 45 | White: 86; Black: 8; Asian: 0; Native American: 0; Latino: 0; Other^*^: 5 | NR | NR | Tanner stage 1: 100% | 200 | 131 | 57 | 80
Shannon, 1994^137^; Children’s Health Project | 6; (4-10) | 50 | White: 87; Black: 10; Asian: 0; Native American: 0; Latino: 0; Other: 3 | NR | NR | Weight z-score, mean: 0.14; Height z-score, mean: −0.06 | NR | 122 | NR | NR

* “Other” defined as other than Black or White race.

Abbreviations: DISC = The Dietary Intervention Study in Children; HDL-C = high-density lipoprotein cholesterol; HMO = Health Maintenance Organization; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; TC = total cholesterol; UK = United Kingdom; US = United States

The mean ages were 9 years^138^ and 6 years^137^ in the two trials (Figure 26). Approximately half of participants were female in both trials, and the majority were White (86% and 87%). Eight and 10 percent of participants were Black in DISC and CHP, respectively.^137,^ ^138^ In DISC, one-third to one-half of participants’ parents were college graduates and CHP participants were from middle to upper income families with parents with high educational attainment. Mean fasting LDL-C was similar in both trials (131 mg/dL^138^ and 122 mg/dL^137^) (Figure 27). The DISC trial additionally reported mean fasting TC (200 mg/dL), HDL-C (57 mg/dL) and TG (80 mg/dL).^138^

Figure 26 Multifactorial Dyslipidemia: All Treatment Intervention Trials—Mean Age and Age Ranges (Key Question 4)

For Multifactorial dyslipidemia, this figure show the mean age and age ranges for all intervention trials (Key Question 4)

Figure 27 Multifactorial Dyslipidemia: All Treatment Intervention Trials—Baseline Lipid Levels for Each Study, Grouped by Intervention Type (Key Question 4)

Abbreviations: HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; TC = total cholesterol; TG = triglycerides

For Multifactorial dyslipidemia, this figure shows the baseline lipid levels for each study, grouped by intervention type for all intervention trials (Key Question 4)

##### Intervention Characteristics

The two behavioral counseling intervention trials were heterogeneous with respect to intervention contact time and duration, but both exclusively focused on dietary change without including physical activity messages (Table 51; Appendix E Table 4). The DISC trial randomized the intervention group (n=334) to an intensive intervention over 7 years.^138^ The intervention group attended sessions focused on dietary interventions that included 19 case manager-led individual sessions and 31 group sessions led by dieticians, behaviorists, and health educators in an academic medical center. The primary goal of the intervention was adherence to a diet low in total and saturated fat, low in cholesterol, and high in fiber. There were no physical activity messages or goals in this intervention. The control group (n=329) received usual care that informed parents of their child’s high cholesterol and recommendations to see their physicians as well as publicly available educational publications on heart-healthy eating. At year 3, the participants with lipid levels exceeding thresholds for monitoring were reviewed and referred to physicians. The intervention group had high adherence: attendance was 89 percent or higher through the first 3 years and declined to 72 percent during year 5. Adherence further declined to 37 percent at the end of year 7 (defined as attending 2 or more individual or group visits per year).

Table 51 Multifactorial Dyslipidemia: Behavioral Intervention Trials—Intervention Characteristics (Key Question 4)

Author, year; Study name | IG | IG n | IG brief description | Behavioral intv approach | Intv setting | Intv provider(s) | CG category | CG N | CG description
DISC Collaborative Research Group, 1995^138^; Dietary Intervention Study in Children (DISC) | IG1 | 334 | 19 (min, NR) individual sessions with case manager; 31 (min, NR) group sessions with dietitian, behaviorists, and health educators for 7 years | Dietary | Academic medical center | Dietitian, Behaviorists, Health educators | Usual care | 329 | Parents or guardians informed that child’s blood cholesterol level was high; no specific recommendations to see their physician were given.
Shannon, 1994^137^; Children’s Health Project | IG1 | 92 | Ten audiotape storybooks (length NR), paper-pencil activities and manual with parent for 10 weeks | Dietary | Home | Parent | No intervention | 89 | Received no educational information or materials.
Shannon, 1994^137^; Children’s Health Project | IG2 | 90 | One 45- to 60-minute counseling sessions with dietitian | Dietary | Academic medical center | Dietician | No intervention | 89 | Received no educational information or materials

Abbreviations: CG = control group; DISC = The Dietary Intervention Study in Children; IG = intervention group; Intv = Intervention MFD = multifactorial dyslipidemia; min = minute; NR = not reported

The CHP trial randomized families to two intervention groups of low intensity and a control group.^137^ The first intervention group (n=92) was assigned to a home-based social cognitive theory-based intervention that included 10 audiotape story books with accompanying picture books, child activity books, and a parent manual to be reviewed over 10 weeks. The second intervention group (n=90) involved the child and at least one parent attending one in person 45-to-60-minute counseling session with a pediatric registered dietician and home print materials with access to the dietician by phone with any questions after the session. Both interventions consisted of dietary messages consistent with the NCEP Step 1 diet (Appendix A Table 4); no physical activity messages or goals were included. The control group (n=89) received no intervention. Adherence to the first intervention was moderate with 64 percent of children listening to all stories and 95 percent listening to at least half; 63 percent completed at least half of the activities. About half (46%) of the parents reported reading the entire manual and another 15 percent reported reading at least half of the manual. Adherence to the second intervention was presumably complete given that there was only one visit, but only 2 percent contacted the dietitian by phone for the 3-month period.

##### Outcomes (Results)

Lipid lowering results were mixed in the two studies of behavioral counseling interventions, with greater TC and LDL-C reduction seen in the intervention with more contact time (Figures 28–31; Table 52). Improvements for some dietary outcomes were seen in both interventions, with benefit diminishing at longer followup. The DISC intervention was associated with significantly greater reductions in TC and LDL-C at 3 years compared to the control group (TC: MD −3.3 mg/dL [95% CI, −6.4 to −0.2]; LDL-C: MD −3.3 mg/dL [95% CI, −6.0 to −0.6]) but not at 7.4 years (TC: MD −1.1 [95% CI −5.0 to 2.8]; LDL-C: MD −1.9 [95% CI −4.7 to 0.9)]). The intervention was not associated with significant differences in HDL-C or TG or at either timepoint. While 3-month results for the home-based CHP intervention showed statistically significant LDL-C reduction compared to the control group (MD in change −6.7 mg/dL (CIs not available), p<0.05), differences were no longer significant at 1 year. Change in LDL-C was not significantly different between the dietician counseling intervention and control at 3 months or 1 year. No other lipid outcomes were reported.

Figure 28 Multifactorial Dyslipidemia: All Intervention Trials—Mean Difference in Change in Total Cholesterol Compared With Controls (k=2) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DISC CRG = The Dietary Intervention Study in Children Collaborative Research Group; g = gram(s); IG = intervention group; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; NR = not reported; TC = total cholesterol; wks = weeks

For Multifactorial dyslipidemia, this figure shows the mean difference in change in total cholesterol compared with controls (k=2) for all intervention trials (Key Question 4)

Figure 29 Multifactorial Dyslipidemia: All Intervention Trials—Mean Difference in Change in Low-Density Lipoprotein Cholesterol Compared With Controls (k=2) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DISC CRG= The Dietary Intervention Study in Children Collaborative Research Group; g = gram(s); IG = intervention group; LDL-C = low-density lipoprotein cholesterol; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; NR = not reported; wks = weeks

For Multifactorial dyslipidemia, this figure shows the mean difference in change in low-density lipoprotein cholesterol compared with controls (k=2) for all intervention trials (Key Question 4)

Figure 30 Multifactorial Dyslipidemia: All Intervention Trials—Mean Difference in Change in High-Density Lipoprotein Cholesterol Compared With Controls (k=2) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DISC CRG= The Dietary Intervention Study in Children Collaborative Research Group; g = gram(s); HDL-C = high-density lipoprotein cholesterol; IG = intervention group; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; NR = not reported; wks = weeks

For Multifactorial dyslipidemia, this figure shows the mean difference in change in high-density lipoprotein cholesterol compared with controls (k=2) for all intervention trials (Key Question 4)

Figure 31 Multifactorial Dyslipidemia: All Intervention Trials—Mean Difference in Change in Triglycerides Compared With Controls (k=2) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DISC CRG= The Dietary Intervention Study in Children Collaborative Research Group; g = gram(s); IG = intervention group; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; NR = not reported; TG = triglycerides; wks = weeks

For Multifactorial dyslipidemia, this figure shows the mean difference in change in triglycerides compared with controls (k=2) for all intervention trials (Key Question 4)

Table 52 Multifactorial Dyslipidemia: Behavioral Intervention Trials—Results for Mean Difference in Change in Serum Lipid Levels (mg/dL) (Key Question 4)

Serum Lipid Outcome | Author, Year | Group | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD (95% CI), p-Value
TC | DISC Collaborative Research Group, 1995^138^ | IG1 | 156 | 334 | 329 | −16.70 (−18.78 to −14.62) | −13.60 (−15.81 to −11.39) | −3.30 (−6.40 to −0.2), 0.04
TC | DISC Collaborative Research Group, 1995^138^ | IG1 | 385 | 334 | 329 | −20.60 (−23.05 to −18.15) | −19.90 (−22.65 to −17.15) | −1.10 (−5.00 to 2.80), 0.59
LDL-C | DISC Collaborative Research Group, 1995^138^ | IG1 | 156 | 334 | 329 | −15.30 (−17.10 to −13.50) | −11.90 (−13.80 to −10.00) | −3.30 (−6.00 to −0.60), 0.02
LDL-C | DISC Collaborative Research Group, 1995^138^ | IG1 | 385 | 334 | 329 | −16.50 (−18.11 to −14.89) | −14.60 (−16.90 to −12.30) | −1.90 (−4.68 to 0.88), 0.25
LDL-C | Shannon, 1994^137^ | IG1 | 52 | 88 | 87 | −5.79 (NR) | −5.02 (NR) | NR, NSD^*^
LDL-C | Shannon, 1994^137^ | IG2 | 52 | 86 | 87 | −6.95 (NR) | −5.02 (NR) | NR, NSD^*^
HDL-C | DISC Collaborative Research Group, 1995^138^ | IG1 | 156 | 334 | 329 | −4.40 (−5.54 to −3.26) | −4.40 (−5.60 to −3.20) | −0.20 (−1.20 to 0.90), 0.75
HDL-C | DISC Collaborative Research Group, 1995^138^ | IG1 | 385 | 334 | 329 | −7.30 (−8.57 to −6.03) | −7.70 (−8.95 to −6.45) | 0.30 (−1.00 to 1.70), 0.62
TG | DISC Collaborative Research Group, 1995^138^ | IG1 | 156 | 334 | 329 | 19.40 (14.99 to 23.81) | 18.00 (13.59 to 22.41) | 1.50 (−4.50 to 7.50), 0.62
TG | DISC Collaborative Research Group, 1995^138^ | IG1 | 385 | 334 | 329 | 20.40 (15.22 to 25.58) | 16.10 (11.46 to 20.74) | 3.40 (−4.10 to 10.90), 0.3

* Significant within-group difference from baseline, (p<0.05).

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; DISC = The Dietary Intervention Study in Children; FU = follow up; HDL-C = high-density lipoprotein cholesterol; IG = intervention group; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; MD = mean difference; NR = not reported; NSD = no significant difference; TC = total cholesterol

Behavioral counseling interventions were associated with improvements in several dietary intake outcomes at shorter followup periods up to 3 years, but when longer followup was reported, improvements were attenuated (Appendix E Table 5). For example, cholesterol intake was statistically significantly lower in the intervention group in the DISC trial at 3 years (MD −18.1 mg/1000 kcal [95% CI −25.7 to −10.4]) but not at 7.4 years and results in the CHP trial showed no significant difference.^137,^ ^138^ In the DISC trial, percent calories from fat declined more in the intervention group at 3 years (MD −4.2% [95% CI, −5.1 to −3.4]) and 7.4 years (MD −1.5% [95% CI, −2.43 to −0.57]) compared to the control group. Similarly, mean change in percent calories from fat was lower in the CHP interventions at one year (home-based intervention: MD in change −1.3% [calculated 95% CI, −3.1 to 0.5]; p<0.05 in adjusted analyses; dietician-based intervention: MD in change −2.3% [95% CI, −4.1 to −0.5]). DISC reported a statistically significant improvement in saturated fat intake at 3 years (MD −2.1% [95% CI, −2.5 to −1.7]) and 7.4 years (MD −0.9% [95% CI, −1.4 to −0.4]). Similarly, at 3 months, both interventions in CHP showed a comparable reduction in grams of saturated fat intake that were significantly greater than the control group (home-based intervention: MD in change −3.8 g [95% CI, −6.15 to −1.45]; dietician-based intervention: MD in change −4.2 g [95% CI, −6.42 to −1.98]). The clinical importance of these small changes in dietary intake outcomes is uncertain.

#### Supplement Interventions

##### Trial And Participant Characteristics

We identified two small fair-quality trials examining the effectiveness of dietary supplements to reduce lipids in children and adolescents with multifactorial dyslipidemia (n=72) (Tables 53 and 54). One randomized controlled trial (n=32)^139^ evaluated a flaxseed supplement and the other was a randomized crossover trial (n=42)^140^ examining the omega-3 fatty acid supplement of fish oil; the latter trial was newly identified in this update. The trials were conducted in Canada^139^ and the US.^140^ One trial included children and adolescents ages 8 to 18 years with elevated LDL-C (135-193 mg/dL), a family history of hypercholesterolemia or premature CVD, and were on the Step II diet (Appendix A Table 4),^139^ while the crossover trial included adolescents ages 10 to 17 years with elevated fasting TG (≥150 mg/dL and <750 mg/dL) but LDL-C <160 mg/dL.^140^ Both trials recruited participants from lipid referral clinics.

Table 53 Multifactorial Dyslipidemia: Supplement Intervention Trials—Study Characteristics (Key Questions 4 and 5)

Author, Year; Quality | Study Design | Condition Criteria | Brief Population Description | Country | Yrs of Data Collection | N Rand
Wong, 2013^139^; Fair | RCT | Fasting serum LDL-C 135-193 mg/dL | Children and adolescents aged 8-18 years with elevated fasting serum LDL-C levels (135-193 mg/dL) and a positive first-degree family history of hypercholesterolemia or premature atherosclerotic cardiovascular disease | Canada | 2009-2010 | 32
Gidding, 2014^140^; Fair | Randomized crossover | Fasting TG ≥150 mg/dL and <750 mg/dL on 2 separate occasions, and LDL-C <160 mg/dL | Adolescents 10-17 years with elevated TG (≥150 mg/dL and <750 mg/dL) and LDL-C <160 mg/dL | US | NR | 42

Abbreviations: LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NR = not reported; Rand = randomized; RCT = randomized controlled trial; TG = triglycerides; US = United States; Yrs = years

Table 54 Multifactorial Dyslipidemia: Supplement Intervention Trials—Population Characteristics (Key Questions 4 and 5)

Author, Year | Age, Mean (Range) | Female, % | Race/Ethnicity, % | BMI | Smoking, % | % With Family History of CVD and Definition | Other BL Character-istic | Mean Fasting TC (mg/dL) | Mean Fasting LDL-C (mg/dL) | Mean Fasting HDL-C (mg/dL) | Mean Fasting TG (mg/dL)
Wong, 2013^139^ | 13; (8-18) | 47 | NR | NR | NR | 100% with positive family history of 1st-degree relatives with hypercholesterolemia or premature atherosclerotic CVD | HTN: 0%; Compliant with STEP II diet): 100% | 208 | 138 | 49 | 112
Gidding, 2014^140^ | 14; (10-17) | 31 | White: 86; Black: 5; Asian: 0; Native American: 0; Latino: 7; Other: 2 | Mean: 31 kg/m^2^ | 0 | NR | Tanner 4 or greater: 100% | 194 | 112 | 39 | 272

Abbreviations: BL = baseline; BMI = body mass index; CVD = cardiovascular disease; FH= familial hypercholesterolemia; HDL-C = high-density lipoprotein cholesterol; HTN = hypertension; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NR = not reported; TG = triglycerides

The mean ages were 13^139^ and 14^140^ years in the two trials (Figure 26). Approximately one-third to one-half of participants were female in the two trials, and in the one trial reporting race, the majority were White (86% White participants, 5% Black participants, 7% Latino participants, 2% reported as ‘other’ race/ethnicity).^140^ Mean fasting lipid values in the two trials were: TC, 194 mg/dL^140^ and 208 mg/dL^139^; LDL-C, 112 mg/dL^140^ and 138 mg/dL^139^; HDL-C 39 mg/dL^140^ and 49 mg/dL;^139^ and TG 112 mg/dL^139^ and 272 mg/dL^140^ (Figure 27).

##### Intervention Characteristics

The intervention group in the RCT received 30 g/d of flaxseed baked into muffins and breads for 4 weeks and the control group received identical muffins and breads containing whole wheat flour in place of the flaxseed (Table 55).^139^ Both groups complied with an NCEP Step 2 diet (Appendix A Table 4) for a minimum of 6 months prior to trial enrollment. The intervention group in the randomized crossover trial received 4 g/d of fish oil for 8 weeks while the control group received a corn oil placebo.^140^ Adherence in the flaxseed trial was high based on self-reported intake logs (IG: 85%, CG: 80%)^139^ and adherence was not reported in the fish oil trial.

Table 55 Multifactorial Dyslipidemia: Supplement Intervention Trials—Intervention Characteristics (Key Questions 4 and 5)

Author, Year | IG n | Intervention | IG Brief Description | Run-In; Background Diet | CG Category | CG n | CG Description
Wong, 2013^139^ | 16 | Flaxseed | 30 g/day flaxseed supplement in muffins and breads baked with ground flaxseed for 4 weeks | None; None, but compliance with the NCEP Step II diet for a minimum of 6 months prior to study enrollment was required. NR if this was enforced during study period. | Placebo | 16 | Identical muffins and bread, containing whole-wheat flour in place of flaxseed.
Gidding, 2014^140^ | NR | Fish oil | Fish oil 4 g/day for 8 weeks | NR; Patients were advised to maintain a stable diet and not alter baseline fish consumption. Any fish oil supplements were discontinued. Advice on a heart-healthy diet was provided. | Placebo | NR | Corn oil placebo

Abbreviations: CG = control group; g = gram; IG = intervention group; MFD = multifactorial dyslipidemia; NR = not reported; SD = standard deviation

##### Outcomes (Results)

There were no statistically significant differences in TC or LDL-C in either trial (Figures 28–31; Table 56). Results for TG were mixed, with the fish oil intervention associated with significant improvement (−36 mg/dL [CIs not available], p=0.04),^140^ and the flaxseed intervention associated with a significant increase in TG (MD in change 29.2 mg/dL [95% CI, 4.4-53.2]).^139^ The flaxseed trial similarly reported significant worsening of HDL-C in the control group (MD in change −7.4 mg/dL [95% CI −11.6 to −3.1]).^139^ There was no difference in BMI or total caloric intake between the groups in the flaxseed trial (Appendix E Table 6).^139^

Table 56 Multifactorial Dyslipidemia: Supplement Intervention Trials—Results for Mean Difference in Change in Serum Lipid Levels (mg/dL) (Key Question 4)

Serum Lipid Outcome | Author, Year | Supplement | Dose | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | Mean Diff in Change (95% CI), p-Value
TC | Gidding, 2014^140^ | Fish oil | 4 g | 8 | NR | NR | −1.70 (−10.72 to 7.32) | −3.00 (−12.02 to 6.02) | NR, 0.83
TC | Wong, 2013^139^ | Flaxseed | 30 g | 4 | 16 | 16 | NR | NR | −8.51 (−21.66 to 4.25), 0.20
LDL-C | Gidding, 2014^140^ | Fish oil | 4 g | 8 | NR | NR | 8.00 (1.53 to 14.47) | −0.02 (−6.49 to 6.45) | NR, 0.14
LDL-C | Wong, 2013^139^ | Flaxseed | 30 g | 4 | 16 | 16 | NR | NR | −6.96 (−16.63 to 2.71), 0.15
HDL-C | Gidding, 2014^140^ | Fish oil | 4 g | 8 | NR | NR | 2.00 (0.24 to 3.76) | 1.70 (−0.06 to 3.46) | NR, 0.84
HDL-C | Wong, 2013^139^ | Flaxseed | 30 g | 4 | 16 | 16 | NR | NR | −7.35 (−11.60 to −3.09), 0.001
TG | Gidding, 2014^140^ | Fish oil | 4 g | 8 | NR | NR | −52.00 (−83.36 to −20.64) | −16.00 (−45.40 to 13.40) | NR, 0.04^*^
TG | Wong, 2013^139^ | Flaxseed | 30 g | 4 | 16 | 16 | NR | NR | 29.23 (4.43 to 53.24), 0.02

* IG significantly different as compared to BL (p <0.05).

Abbreviations: BL = baseline; CG = control group; CI = confidence interval; FU = follow up; g = gram; HDL-C = high-density lipoprotein cholesterol; IG = intervention group; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; NR = not reported; TC = total cholesterol

### Multifactorial Dyslipidemia/FH

#### Supplement Interventions

##### Trial and Participant Characteristics

We identified six fair-quality^141–146^ and one good-quality^147^ trials (n=288) examining the effectiveness of various supplements that included children and adolescents with either FH or multifactorial hyperlipidemia (Tables 57–59). The supplements included: omega-3 fatty acids,^142,^ ^147^ fiber,^141,^ ^144,^ ^146^ hazelnuts,^143^ and probiotics.^145^ One trial was conducted in the US,^144^ and the other six were conducted in Italy.^141–143,^ ^145–147^ The trials included children and adolescents ranging from 5 to 18 years with FH and multifactorial dyslipidemia (Figure 32). Inclusion criteria varied and comprised various serum lipid thresholds and/or family history of hyperlipidemia or CVD. Children were recruited from outpatient hospital-based pediatric clinics or lipid clinics. Mean ages were 8 to 12 years. The proportion of participants with FH varied widely, from 5 percent to 69 percent^141,^ ^142,^ ^145–147^; one study reported “most” had FH^144^ and another study did not specify participants’ diagnoses.^143^ Four of the trials explicitly described participants meeting criteria for familial combined hyperlipidemia, sometimes comprising a substantial proportion of participants (8% to 60%).^141,^ ^142,^ ^145,^ ^146^ Between 20^141^ and 58^145^ percent of participants were female among trials. No trials reported race or ethnicity. Reporting of weight status in the trials was inconsistent; 4 trials reported no participants with BMI ≥85th percentile^141,^ ^142,^ ^145,^ ^147^ and 2 trials reported between 8 and 22 percent of participants had mild or borderline overweight.^142,^ ^143^ Ranges of mean fasting lipid values were: TC 201 mg/dL^144^ to 252 mg/dL,^147^ LDL-C 136 mg/dL^142^ to 175 mg/dL,^147^ HDL-C 46 mg/dL^144^ to 60 mg/dL,^143,^ ^147^ TG 68 mg/dL (median)^143^ to 196 mg/dL,^144^ and non-HDL-C 154 mg/dL^142^ to 192 mg/dL^147^ (Figure 33).

Table 57 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Supplement Intervention Trials—Study Characteristics (Key Questions 4 and 5)

Author, Year; Study name; Quality | Study Design | Brief Population Description | Country | Yrs of Data Collection | n Rand
Guardamagna, 2013^141^; Fair | Randomized crossover | Hypercholesterolemic children and adolescents aged 6-15 years | Italy | 2011-NR | 36
Martino, 2005^146^; Fair | RCT | Children and adolescents age ≤14 years with hypercholesterolemia | Italy | NR | 51
Verduci, 2014^147^; Good | RCT | Children 8-13 years with primary hyperlipidemia (defined as TC ≥200 mg/dL and LDL-C ≥130 mg/dL) | Italy | NR | 36
Del Bo, 2019^142^; Fair | RCT | Children and adolescents 6-16 years with primary hyperlipidemia (according to international standards) | Italy | 2015 | 36
Deon, 2018^143^; Fair | RCT | Children and adolescents with primary hyperlipidemia | Italy | 2015 | 66
Dennison, 1993^144^; Fair | Randomized crossover | Children 5-17 years with LDL-C levels >110 mg/dL after 3 months of dietary intervention | US | NR | 25
Guardamagna, 2014^145^; Fair | Randomized crossover | Hypercholesterolemic children ages 6-18 years with serum TC >90th percentile for age and sex | Italy | NR | 38

Abbreviations: BMI = body mass index; CHD = coronary heart disease; CVD = cardiovascular disease; LDL-C = low-density lipoprotein cholesterol; TC = total cholesterol; mg/dL = milligrams per deciliter; NR = not reported; Rand = randomized; RCT = randomized control trial; TC = total cholesterol; TG = triglycerides; US = United States

Table 58 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Supplement Intervention Trials—Proportion of MFD and FH Participants in Included Trials (Key Questions 4 and 5)

Author, Year | FH, % | FH criteria | MFD, % | MFD criteria
Guardamagna, 2013^141^ | FH: 13.9; FCH: 52.8 | FH: Criteria included children with LDL-C ≥135 mg/dL, parental hypercholesterolemia with LDL-C ≥190 mg/dL, tendon xanthomas and/or CVD (phenotype IIA); FCH: Familial combined hyperlipidemia, defined as children showing TC and/or TG >90th age- and sex-specific percentile, at least one parent affected by isolated hypercholesterolemia, hypertriglyceridemia, or both (IIA, IV, or IIB phenotype, respectively) with concomitant individual and familial lipid phenotype variability | 33.3 | Undefined hypercholesterolemia: Children with LDL-C >90th percentile and a family history of hypercholesterolemia, but who did not fulfil the biochemical international criteria for inclusion in FH or FCH
Martino, 2005^146^ | FH: 47.5; FCH: 7.5 | TC >95th percentile for age and sex, in two different determinations before enrollment; FCH: 1^st^-degree relative with high TG and/or TC >95th percentile for age and sex | 45 | PHC: TC >95th percentile for age and sex without clear family transmission
Verduci, 2014^147^ | FH: 69.4 | “Suspected FH”: according to the definition of the US National Lipid Association | 30.6 | NR, estimated based on suspected FH participants
Del Bo, 2019^142^ | FH: 5.6; FCH: 25 | FH: criteria not specified; FCH: criteria not specified | 69.4 | PHC: criteria not specified
Deon, 2018^143^ | FH: NR | FH: diagnosed in presence of LDL-C ≥95th percentile, parental LDL-C ≥190 mg/dL, tendon xanthomas and/or cardiovascular disease (phenotype IIA); FCH: diagnosed in children with TC and/or TG >90th age- and sex-specific percentile, with at least one parent affected by hypercholesterolemia, hypertriglyceridemia, or both (IIA, IV, or IIB phenotype, respectively), with concomitant individual and familial lipid phenotype variability | NR | PHC: Children with LDL-C >90th percentile and a family history of dominant inherited hypercholesterolemia, but not fulfilling the biochemical international diagnostic criteria of FH or FCH
Dennison, 1993^144^ | FH: “Most” | FH: “familial form of hyperlipidemia,” not otherwise specified | NR | Criteria not specified
Guardamagna, 2014^145^ | FH: 5.3; FCH: 60.5 | FH: Children with LDL-C >95th percentile, parental hypercholesterolemia with LDL-C ≥190 mg/dL, tendon xanthomas, and/or cardiovascular disease (phenotype IIA); FCH: Children showing TC or triglycerides (TG), or both above the 90th age- and sex-specific percentile, at least one parent affected by isolated hypercholesterolemia, hypertriglyceridemia, or both (IIA, IV, or IIB phenotype, respectively) with concomitant individual and familial lipid phenotype variability | 34.2 | Undefined hypercholesterolemia: LDL-C >90th percentile and a family history of hypercholesterolemia, but who did not fulfill the biochemical international criteria for inclusion in FH or FCH

Abbreviations: BMI = body mass index; BP = blood pressure; CVD = cardiovascular disease; FCH = familial combined hypercholesterolemia; FH= familial hypercholesterolemia; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; mg/dL = milligrams per deciliter; PHC = Polygenic hypercholesterolemia; TC = total cholesterol; TX = treatment; US = United States

Table 59 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Supplement Intervention Trials—Population Characteristics (Key Questions 4 and 5)

Author, Year | Age, Mean (Range) | Female, % | Race/Ethnicity, % | BMI | Smoking, % | % w Family Hx of CVD | Other BL Characteristic | Mean Fasting TC (mg/dL) | Mean Fasting LDL-C (mg/dL) | Mean Fasting HDL-C (mg/dL) | Mean Fasting TG (mg/dL) | Non-HDL-C (mg/dL)
Guardamagna, 2013^141^ | 11 (6-15) | 20 | NR | >85^th^ percentile: 0% | 0 | NR | On lipid-lowering tx (including functional foods) 3 mo before trial: 0% | 222 | 148 | 56 | 80 | 166
Martino, 2005^146^ | 8 (≤14) | 50 | NR | NR | NR | 100^*^ | NR | NR | NR | NR | NR | NR
Verduci, 2014^147^ | 10 (8-13) | 47 | NR | Normal weight according to IOBT: 100 | NR | NR | Mean dietary saturated fats higher than recommended upper limit. | 252 | 175 | 60 | 82 | 192
Del Bo, 2019^142^ | 12 (6-15) | 36 | NR | >85^th^ percentile: 0%; “Borderline overweight” 22% | 0 | NR | Normal BP: 100% | 209^†^ | 136^†^ | 57 | 88^†^ | 154^†^
Deon, 2018^143^ | 12 (7-18) | 47 | NR | “Mild overweight” 8% | 0 | NR | Normal BP: 100% | 216^†^ | 140^†^ | 60 | Med: 68 | 157^†^
Dennison, 1993^144^ | 11 (5-17) | 45 | NR | NR | NR | NR | NR | 201 | 139 | 46 | 196 | NR
Guardamagna, 2014^145^ | 11 (6-15) | 58 | NR | >85^th^ percentile: 0% | 0 | NR | On lipid-lowering tx (including functional foods) 3 mo before trial: 0% | 223 | 147 | 56 | 99 | NR

* Reporting familial history of premature CHD or at least one parent with TC ≥240 mg/dL.

† Mean serum lipid levels exceeded the 90^th^ age and sex related percentiles, with the exclusion of HDL-C values, which were in the normal range.

Abbreviations: BL = baseline; BMI = body mass index; BP = blood pressure; CVD = cardiovascular disease; HDL-C = high-density lipoprotein cholesterol; Hx = history; IOTF: International Obesity Task Force; LDL-C = low-density lipoprotein cholesterol; Med = median; mg/dL = milligrams per deciliter; Mo = months; NR = not reported; TC = total cholesterol; TG = triglycerides; tx = treatment

Figure 32 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: All Intervention Trials—Mean Age and Age Ranges, by Intervention (Key Question 4)

Abbreviations: DHA = Docosahexaenoic acid; EPA = Eicosapentaenoic acid; w/ = with; w/o = without

For Multifactorial dyslipidemia/Familial hypercholesterolemia conditions, this figure shows the mean age and age ranges, by intervention for all intervention trials (Key Question 4)

Figure 33 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: All Intervention Trials—Baseline Lipid Levels, by Intervention (Key Question 4)

Abbreviations: DHA = Docosahexaenoic acid; EPA = Eicosapentaenoic acid; HDL-C = high-density lipoprotein cholesterol; LDL-C = lowdensity lipoprotein cholesterol; mg/dL = milligrams per deciliter; TC = total cholesterol; TG = triglycerides; w/ = with; w/o = without

For Multifactorial dyslipidemia/Familial hypercholesterolemia, this figure shows the baseline lipid levels, by intervention for all intervention trials (Key Question 4)

##### Intervention Characteristics

The intervention groups in the two omega-3/6 fatty acid trials received one 500 mg gel capsule of DHA+EPA or 500 mg gel capsule of DHA alone over 16 weeks in one trial^147^ and 3 g/d of hempseed oil in capsules for 8 weeks in the other trial (Figure 12; Table 60).^142^ Intervention groups in the fiber trials received 500 mg glucomannan gel caps for 8 weeks,^141^ age dependent dosing of glucomannan capsules twice per day with lunch and dinner (2-3 g/d),^146^ and ready to eat cereals with 6 g/d of psyllium fiber for 4-5 weeks.^144^ The intervention group in the hazelnut trial received one daily weight-based portion (15-30 g) of hazelnuts with or without skin for 8 weeks.^143^ The intervention group in the probiotic trial received one daily probiotic capsule one hour before dinner of B. animalis subspecies lactis MB 109, B. bifidum MB 109, and B. longum subspecies longum BL04 (1x10^9^ CFU each species) for 12 weeks.^145^ Run-ins included 4 weeks^141,^ ^145^ to 3-month dietary counseling^142–144^ on some form of low total fat, low saturated fat, low cholesterol diet. The control groups received placebo^141,^ ^144,^ ^145,^ ^147^ or usual care.^142,^ ^143,^ ^146^ Adherence was high when measured ranging from 89 percent^145^ to 97 percent^147^ based on capsule counts and 82 percent for cereal consumption in one trial.^144^ Three trials did not report adherence.^142,^ ^143,^ ^146^

Table 60 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Supplement Intervention Trials—Intervention Characteristics (Key Questions 4 and 5)

Author, Year | IG | IG n | Intervention | IG Brief Description | Run-In | Background Diet | CG Category | CG n | CG Description
Guardamagna, 2013^141^ | IG1 | 36 | Glucomannan | 8 week intervention of dietary supplement, oral gelatin capsules containing 500 mg glucomannan | 4 wk run-in with dietary counseling | Continuation of run-in diet | Placebo | 36 | Placebo
Martino, 2005^146^ | IG1 | NR | Glucomannan | Glucomannan 2-3 g/day for 8 weeks | 8-week run in with Step 1 diet period | Step I diet | Usual care | NR | Step 1 diet
Verduci, 2014^147^ | IG1 | 12 | DHA+EPA | One 500 mg gel-capsule of DHA plus EPA alone per day over 16 weeks | 8-wk | Step I guidance given to parent | Placebo | 12 | Wheat germ oil (58.5% linoleic acid, 7.1% linolenic acid and 12.8% oleic acid).
Verduci, 2014^147^ | IG2 | 12 | DHA | One 500 mg gel-capsule of DHA alone per day over 16 weeks | 8-wk | Step I guidance given to parent | Placebo | 12 | Wheat germ oil (58.5% linoleic acid, 7.1% linolenic acid and 12.8% oleic acid).
Del Bo, 2019^142^ | IG1 | 18 | Hempseed oil | Four hempseed oil gel capsules/day (3 g total) for 8 weeks | 2 mo compliance with dietary instructions, provided by trained nutritionist | Subjects and family trained by nutritionist to adhere to diet based on CHILD1 guidelines | Usual care | 18 | Maintained usual diet based on CHILD1 guidelines throughout entire study period.
Deon, 2018^143^ | IG1 | 22 | Hazelnut w skin | One daily 15-30 g portion of hazelnuts with skin for 8 weeks | 3 mo run-in where patients should demonstrate a good dietary compliance | Recommendations given based on CHILD1 guidelines. Participants encouraged to maintain same dietary and lifestyle habits | Usual care | 22 | Advised to follow a nut-free diet for 8 wks
Deon, 2018^143^ | IG2 | 22 | Hazelnut w/o skin | One daily 15-30 g portion of hazelnuts without skin for 8 weeks | 3 mo run-in where pts should demonstrate a good dietary compliance | Recommendations given based on CHILD1 guidelines. Participants encouraged to maintain same dietary and lifestyle habits | Usual care | 22 | Advised to follow a nut-free diet for 8 wks
Dennison, 1993^144^ | IG1 | 25 | Psyllium fiber | Ready-to-eat cereals with water-soluble psyllium fiber (6 g/day) for 4-5 weeks | At least 3 mo of a low total fat, low saturated fat, low cholesterol diet | Continuation of low total fat, low saturated fat, low cholesterol diet. | Placebo | 25 | Two 28 g servings (1 ounce or 2/3 cup each) of control cereal which contained 5 g water-insoluble wheat fiber per serving; to be eaten for 4-5 weeks.
Guardamagna, 2014^145^ | IG1 | 38 | Probiotic | One daily probiotic capsule for 12 weeks | 4-wk diet run-in | Instructed by a trained dietitian not to change their standard low-saturated fat, low-cholesterol diet (Step I diet). Children and their families were instructed not to modify children’s physical activity. | Placebo | 38 | Placebo

Abbreviations: CG = control group; CHILD1 = cardiovascular health integrated lifestyle diet; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; FH= familial hypercholesterolemia; g = gram; IG = intervention group; MFD = multifactorial dyslipidemia; mo = month; w/ = with; wks = weeks; w/o = without

##### Outcomes (Results)

Of the 7 supplement trials conducted in populations with multifactorial dyslipidemia or FH, only one, which evaluated the fiber glucomannan, showed a statistically significant reduction in multiple lipid values (Figures 34–37; Tables 61–65): TC (−10.8 mg/dL [−18.5 to −3.1]), LDL-C (−10.1 mg/dL [−17.4 to −2.9]), and non-HDL-C (−11.2 mg/dL [−18.0 to −4.5]).^141^ However, this is in the context of two other fiber trials showing no statistically significant reduction in TC or LDL-C (the other 2 fiber studies did not report non-HDL-C).^144,^ ^146^ The remaining trials showed no difference in TC. None of the studies reported a statistically significant change in HDL-C.^141–144,^ ^146,^ ^147^ Only one trial, evaluating psyllium fiber, reported a statistically significant reduction in TG (−60.2 mg/dL [−115.9 to −92.0]) while the other trials showed no statistically significant difference between groups for this outcome.^141–143,^ ^146,^ ^147^ The trials evaluating omega-3/6 (DHA, EPA^147^ and hempseed oil^142^), probiotics,^145^ and hazelnuts^143^ showed no statistically significant reductions in any lipid parameter.

Figure 34 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: All Intervention Trials—Mean Difference in Change in Total Cholesterol Compared With Controls (k=7) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DHA = Docosahexaenoic acid; EPA = Eicosapentaenoic acid; g = gram(s); IG = intervention group; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; NR = not reported; TC = total cholesterol; w/ = with; wks = weeks; w/o = without

For Multifactorial dyslipidemia/Familial hypercholesterolemia, this figure shows the mean difference in change in total cholesterol compared with controls (k=7) for all intervention trials (Key Question 4)

Figure 35 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: All Intervention Trials—Mean Difference in Change in Low-Density Lipoprotein Cholesterol Compared With Controls (k=7) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DHA = Docosahexaenoic acid; EPA = Eicosapentaenoic acid; g = gram(s); IG = intervention group; LDL-C = low-density lipoprotein cholesterol; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; NR = not reported; w/ = with; wks = weeks; w/o = without

For Multifactorial dyslipidemia/Familial hypercholesterolemia, this figure shows the mean difference in change in low-density lipoprotein cholesterol compared with controls (k=7) for all intervention trials (Key Question 4)

Figure 36 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: All Intervention Trials—Mean Difference in Change in High-Density Lipoprotein Cholesterol Compared With Controls (k=7) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DHA = Docosahexaenoic acid; EPA = Eicosapentaenoic acid; g = gram(s); HDL-C = high-density lipoprotein cholesterol; IG = intervention group; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; NR = not reported; w/ = with; wks = weeks; w/o = without

For Multifactorial dyslipidemia/Familial hypercholesterolemia, this figure shows the mean difference in change in high-density lipoprotein cholesterol compared with controls (k=7) for all intervention trials (Key Question 4)

Figure 37 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: All Intervention Trials—Mean Difference in Change in Triglycerides Compared With Controls (k=6) (Key Question 4)

Abbreviations: CG = control group; CI = confidence interval; DHA = Docosahexaenoic acid; EPA = Eicosapentaenoic acid; g = gram(s); IG = intervention group; MD = mean difference; mg/dL = milligrams per deciliter; MnChg = mean change; NR = not reported; TG = triglycerides; w/ = with; wks = weeks; w/o = without

For Multifactorial dyslipidemia/Familial hypercholesterolemia, this figure shows the mean difference in change in triglycerides compared with controls (k=6) for all intervention trials (Key Question 4)

Table 61 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Supplement Intervention Trials—Results for Mean Difference in Change in Total Cholesterol (mg/dL) (Key Question 4)

Author, Year | Supplement | Dose | Group | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Del Bo, 2019^142^ | Hempseed oil | 3 g | IG1 | 8 | 18 | 18 | −4.50 (−13.60 to 4.60) | −6.20 (−19.70 to 7.20) | 1.70 (−13.39 to 16.79), 0.824
Dennison, 1993^144^ | Psyllium fiber | 6 g | IG1 | 5 | 20 | 20 | 2.70 (−4.86 to 10.27) | 3.09 (−2.97 to 9.14) | −0.39 (−7.72 to 7.34), NSD
Deon, 2018^143^ | Hazelnut w skin | Varied (15-30 g) | IG1 | 8 | 22 | 18 | −5.30 (−22.81 to 12.21) | −6.20 (−28.22 to 15.82) | 0.90 (−26.86 to 28.66),
Deon, 2018^143^ | Hazelnut w/o skin | Varied (15-30 g) | IG2 | 8 | 20 | 18 | −9.30 (−32.98 to 14.38) | −6.20 (−28.22 to 15.82) | −3.10 (−35.65 to 29.45)
Guardamagna, 2013^141^ | Glucomannan | 2 or 3 capsules BID | IG1 | 8 | 36 | 36 | NR | NR | −10.80 (−18.50 to −3.10), 0.008
Guardamagna, 2014^145^ | Probiotic | NR | IG1 | 12 | 38 | 38 | −10.90 (−19.06 to −2.74) | −7.50 (−15.89 to 0.89) | −3.40 (−15.10 to 8.30), NR^*^
Martino, 2005^146^ | Glucomannan | 2-3 g (depending on age) | IG1 | 8 | 20 | 20 | −44.10 (−60.73 to −27.47) | −28.20 (−44.24 to −12.16) | −15.90 (−39.00 to 7.20), 0.042^†^
Verduci, 2014^147^ | DHA+EPA | 500 mg | IG1 | 16 | 12 | 12 | −10.20 (−54.50 to 34.10) | −14.60 (−39.65 to 10.45) | 4.40 (−46.50 to 55.30)
Verduci, 2014^147^ | DHA | 500 mg | IG2 | 16 | 12 | 12 | −12.10 (−45.22 to 21.02) | −14.60 (−39.65 to 10.45) | 2.50 (−39.03 to 44.03)

* Study reported statistical significance between treatments (IG vs. CG, p=0.0263) based on analysis of variance for repeated measures and the Greenhouse-Geisser correction on actual absolute values, not accounting for MD in change from BL.

† Study reported statistical significance between treatments (IG vs. CG, p=0.042) based on analysis of variance, testing equality of means and not accounting for mean differences from BL.

Abbreviations: BL = baseline; BID = twice per day (latin); CG = control group; CI = confidence interval; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; FU = follow up; g = gram; IG = intervention group; MD = mean difference; NR = not reported; NSD = no significant difference; w/ = with; wks = weeks; w/o = without

Table 62 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Supplement Intervention Trials—Results for Mean Difference in Change in Low-Density Lipoprotein Cholesterol (mg/dL) (Key Question 4)

Author, Year | Supplement | Dose | Group | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Del Bo, 2019^142^ | Hempseed oil | 3 g | IG1 | 8 | 18 | 18 | −14.20 (−15.20 to −13.20) | −4.94 (−13.70 to 3.81) | NR, 0.156^*^
Dennison, 1993^144^ | Psyllium fiber | 6 g | IG1 | 5 | 20 | 20 | 1.54 (−4.51 to 7.60) | −2.32 (−8.37 to 3.74) | 3.86 (−4.63 to 12.36), NSD
Deon, 2018^143^ | Hazelnut w skin | Varied (15-30 g) | IG1 | 8 | 22 | 18 | −9.20 (−28.22 to 9.82) | −4.80 (−25.73 to 16.13) | −4.40 (−32.69 to 23.89), NR^†^
Deon, 2018^143^ | Hazelnut w/o skin | Varied (15-30 g) | IG2 | 8 | 20 | 18 | −8.80 (−33.49 to 15.89) | −4.80 (−25.73 to 16.13) | −4.00 (−36.74 to 28.74), NR^†^
Guardamagna, 2013^141^ | Glucomannan | 2 or 3 capsules BID | IG1 | 8 | 36 | 36 | NR | NR | −10.10 (−17.40 to −2.90), 0.008
Guardamagna, 2014^145^ | Probiotic | NR | IG1 | 12 | 38 | 38 | −11.90 (−19.35 to −4.45) | −8.10 (−16.34 to 0.14) | −3.80 (−14.90 to 7.30), NR^‡^
Martino, 2005^146^ | Glucomannan | 2-3 g (depending on age) | IG1 | 8 | 20 | 20 | −40.90 (−60.64 to −21.16) | −21.20 (−40.69 to −1.71) | −19.70 (−47.44 to 8.04), 0.026^§^
Verduci, 2014^147^ | DHA+EPA | 500 mg | IG1 | 16 | 12 | 12 | −9.70 (−53.74 to 34.34) | −9.10 (−36.37 to 18.17) | −0.60 (−52.40 to 51.20)
Verduci, 2014^147^ | DHA | 500 mg | IG2 | 16 | 12 | 12 | −9.30 (−43.90 to 25.30) | −9.10 (−36.37 to 18.17) | −0.20 (−44.25 to 43.85)

* Imputed CI of MD of change was based on imbalanced variances between the control (SD= 17.6) and the treatment (SD=2.0) and not accounting for the crossover trial design with small sample size (N=36).

† IG significantly different as compared to BL (p <0.05).

‡ Study reported statistical significance between treatments (IG vs. CG, p=0.0017) based on analysis of variance for repeated measures and the Greenhouse-Geisser correction on actual absolute values, not accounting for MD in change from BL.

§ Study reported statistical significance between treatments (IG vs. CG, p=0.026) based on analysis of variance, testing equality of means and not accounting for mean differences from BL.

Abbreviations: BL = baseline; BID = twice per day (latin); CG = control group; CI = confidence interval; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; FU = follow up; g = gram; IG = intervention group; MD = mean difference; NR = not reported; NSD = no significant difference; w/ = with; wks = weeks; w/o = without

Table 63 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Supplement Intervention Trials—Results for Mean Difference in Change in High-Density Lipoprotein Cholesterol (mg/dL) (Key Question 4)

Author, Year | Supplement | Dose | Group | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Del Bo, 2019^142^ | Hempseed oil | 3 g | IG1 | 8 | 18 | 18 | −1.94 (−5.34 to 1.46) | −2.56 (−6.49 to 1.37) | 0.62 (−4.21 to 5.45), 0.806
Dennison, 1993^144^ | Psyllium fiber | 6 g | IG1 | 5 | 20 | 20 | −0.77 (−4.56 to 3.01) | −1.54 (−3.81 to 0.73) | 1.16 (−1.93 to 3.86), NSD
Deon, 2018^143^ | Hazelnut w skin | Varied (15-30 g) | IG1 | 8 | 22 | 18 | 1.20 (−4.63 to 7.03) | 0.10 (−6.25 to 6.45) | 1.10 (−7.54 to 9.74)
Deon, 2018^143^ | Hazelnut w/o skin | Varied (15-30 g) | IG2 | 8 | 20 | 18 | 1.40 (−5.86 to 8.66) | 0.10 (−6.25 to 6.45) | 1.30 (−8.44 to 11.04)
Guardamagna, 2013^141^ | Glucomannan | 2-3 cap BID | IG1 | 8 | 36 | 36 | NR | NR | 0.40 (−2.10 to 2.90), 0.739
Guardamagna, 2014^145^ | Probiotic | NR | IG1 | 12 | 38 | 38 | 4.90 (0.61 to 9.19) | 3.20 (−1.01 to 7.41) | 1.70 (−4.32 to 7.72), NR^*^
Martino, 2005^146^ | Glucomannan | 2-3 g (depending on age) | IG1 | 8 | 20 | 20 | −5.80 (−12.35 to 0.75) | −3.90 (−10.43 to 2.63) | −1.90 (−11.15 to 7.35), NSD
Verduci, 2014^147^ | DHA+EPA | 500 mg | IG1 | 16 | 12 | 12 | 1.30 (−3.13 to 5.73) | 2.60 (−2.61 to 7.81) | −1.30 (−8.14 to 5.54)
Verduci, 2014^147^ | DHA | 500 mg | IG2 | 16 | 12 | 12 | 4.80 (0.81 to 8.79) | 2.60 (−2.61 to 7.81) | 2.20 (−4.36 to 8.76)

* Study reported statistical significance between treatments (IG vs. CG, p=0.0352) based on analysis of variance for repeated measures and the Greenhouse-Geisser correction on actual absolute values, not accounting for MD in change from BL.

Abbreviations: BL = baseline; BID = twice per day (latin); CG = control group; CI = confidence interval; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; FU = follow up; g = gram; IG = intervention group; MD = mean difference; NR = not reported; NSD = no significant difference; w/ = with; wks = weeks; w/o = without

Table 64 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Supplement Intervention Trials—Results for Mean Difference in Change in Triglyceride Levels (mg/dL) (Key Question 4)

Author, Year | Supplement | Dose | Group | FU, wks | IG n | CG n | IG Mean Change From BL (95% CI) | CG Mean Change From BL (95% CI) | MD in Change (95% CI), p-Value
Del Bo, 2019^142^ | Hempseed oil | 3 g | IG1 | 8 | 18 | 18 | 16.00 (−3.60 to 35.60) | −6.30 (−24.10 to 11.60) | 22.30 (−2.33 to 46.93), 0.085
Dennison, 1993^144^ | Psyllium fiber | 6 g | IG1 | 5 | 20 | 20 | 21.24 (−9.98 to 52.46) | 81.42 (36.32 to 126.52) | MD Chg: −60.18 (−115.93 to −3.54), <0.05
Deon, 2018^143^ | Hazelnut w skin | Varied (15-30 g) | IG1 | 8 | 22 | 18 | NR | NR | NR, NR
Deon, 2018^143^ | Hazelnut w/o skin | Varied (15-30 g) | IG2 | 8 | 20 | 18 | NR | NR | NR, NR
Guardamagna, 2013^141^ | Glucomannan | 2-3 cap BID | IG1 | 8 | 36 | 36 | NR | NR | MD Chg: −3.80 (−17.40 to 9.80), 0.399
Guardamagna, 2014^145^ | Probiotic | NR | IG1 | 12 | 38 | 38 | −19.50 (−36.76 to −2.24) | −17.60 (−35.06 to −0.14) | −1.90 (−26.45 to 22.65), NR^*^
Martino, 2005^146^ | Glucomannan | 2-3 g (depending on age) | IG1 | 8 | 20 | 20 | −9.80 (−31.81 to 12.21) | −15.10 (−30.72 to 0.52) | 5.30 (−21.69 to 32.29)
Verduci, 2014^147^ | DHA+EPA | 500 mg | IG1 | 16 | 12 | 12 | −9.60 (−24.21 to 5.01) | −5.30 (−23.17 to 12.57) | −4.30 (−27.39 to 18.79)
Verduci, 2014^147^ | DHA | 500 mg | IG2 | 16 | 12 | 12 | −12.60 (−28.92 to 3.72) | −5.30 (−23.17 to 12.57) | −7.30 (−31.50 to 16.90)

* Study reported statistical significance between treatments (IG vs. CG, p=0.0384) based on analysis of variance for repeated measures and the Greenhouse-Geisser correction on actual absolute values, not accounting for MD in change from BL.

Abbreviations: BL = baseline; BID = twice per day (latin); cap = capsule; CG = control group; Chg: change; CI = confidence interval; DHA = docosahexaenoic acid; EPA = eicosapentaenoic acid; FU = follow up; g = gram; IG = intervention group; MD = mean difference; NR = not reported; NSD = no significant difference; w/ = with; wks = weeks; w/o = without

Table 65 Multifactorial Dyslipidemia/Familial Hypercholesterolemia: Supplement Intervention Trials—Results for Mean Difference in Change in Non-High-Density Lipoprotein Cholesterol (mg/dL) (Key Question 4)

Author, Year | Supplement | Dose | Group | FU, wks | IG n | CG n | IG Mean Change from BL (95% CI) | CG Mean Change from BL (95% CI) | MD in Change (95% CI), p-value
Del Bo, 2019^142^ | Hempseed oil | 3 g | IG1 | 8 | 18 | 18 | 3.40 (−31.20 to 37.90) | −6.30 (−17.60 to 4.90) | 9.70 (−24.05 to 43.45), 0.577
Deon, 2018^143^ | Hazelnut w skin | Varied (15-30 g) | IG1 | 8 | 22 | 18 | −6.50 (−25.97 to 12.97) | −6.30 (−28.11 to 15.51) | −0.20 (−29.40 to 29.00)
Deon, 2018^143^ | Hazelnut w/o skin | Varied (15-30 g) | IG2 | 8 | 20 | 18 | −10.70 (−36.04 to 14.64) | −6.30 (−28.11 to 15.51) | −4.40 (−38.20 to 29.40), NR^*^
Guardamagna, 2013^141^ | Glucomannan | 2 −3 cap BID | IG1 | 8 | 36 | 36 | NR | NR | −11.20 (−18.00 to −4.50), 0.002

* IG significantly different as compared to BL (p <0.05).

Abbreviations: BL = baseline; BID = twice per day (latin); cap = capsule; CG = control group; Chg: change; CI = confidence interval; FU = follow up; g = gram; IG = intervention group; MD = mean difference; NR = not reported; w/ = with; wks = weeks; w/o = without

One trial of omega-3/6 (hempseed oil) in participants with multifactorial dyslipidemia or FH also reported non-lipid outcomes and showed no difference in BMI between the groups (Appendix E Table 7).^142^

## KQ5 What Are the Harms of Treatment of FH or Multifactorial Dyslipidemia in Children and Adolescents?

### Summary of Findings

#### FH

Overall, harms reported in pharmacotherapy trials were similar in the intervention and control groups, however, most studies were relatively short term and small with few events leading to imprecise estimates. Further, the clinical importance of transient elevations in lab values was unknown.

In the statin trials, transaminitis of 3 times or more the upper limit of normal occurred in 0 to 4.5 percent in intervention groups and 0 to 1.9 percent in control groups. The largest trial (n=214) with 2-year followup reported no cases in the statin group and only 2 cases of AST more than 3 times the upper limit of normal in the control group. In the 10-year observational followup of this trial, transaminitis at this threshold was similarly rare (ALT: 1 case of >3 times elevation in the statin group; AST: 1 case of >3 each in the statin and control group). Abnormal creatine kinase of 10 times or greater the upper limit of normal was reported as zero in two trials, and up to 4.5 percent in the statin groups and up to 1.7 percent in the control groups. One trial’s 10-year observational followup reported no instances of elevated creatine kinase in participants on statins and in 2 non-FH siblings not taking statins. Two observational studies evaluated statin harms in populations with dyslipidemia without specification of type of dyslipidemia. One fair-quality observational study evaluated the association of statins and new onset diabetes (n=9,393) showing no difference in new diabetes diagnoses over up to 9 years followup in those taking statins compared to controls. One fair-quality observational study (n=943) reported ALT more than 3 times the upper limit of normal with a frequency of 4.4 percent in the statin group and 1.5 percent in the control group over 3.5 years of observation.

No significant differences between Tanner stages or other hormonal adverse events were reported in the RCTs or longer observational followup. Harms in the three bile acid sequestrant trials (n=332) were similar in the intervention and control groups, however, the trials were generally small with few events and significance testing was not reported. Harms in the ezetimibe trial (n=138), PCSK9 inhibitor trial (n=158), and combination statin plus ezetimibe versus statin trial (n=248) showed similar rates of total adverse events in the intervention and control groups. The small fibrate trial (n=14) reported one instance of transient ALT elevation and one instance of alkaline phosphatase elevation in the intervention group. The diet and physical activity counseling intervention did not mention harms and three supplement trials in FH reported that there were no adverse events.

#### Multifactorial Dyslipidemia

Overall, behavioral counseling interventions do not appear to be associated with important harms and there is inadequate evidence to make conclusions about harms of supplements in this population.

The two behavioral counseling trials in children with multifactorial dyslipidemia (n=934) reported no adverse effects in terms of growth and development, nutrient adequacy, and psychosocial outcomes in the dietary intervention group compared to the control group. The flaxseed trial (n=32) reported no adverse events and the fish oil trial (n=42) reported gastrointestinal symptoms, fishy taste, and frequent nose bleeds.

#### Multifactorial Dyslipidemia/FH

Overall, fiber supplements appear to be associated with GI side effects and there is inadequate evidence to make conclusions about harms of other supplements in these populations. Evidence is limited by few studies and short trial durations of 5 to 16 weeks.

Five of the seven supplement trials in populations with FH or multifactorial dyslipidemia reported harms, with two trials reporting no adverse events, however the fiber trials reported various gastrointestinal side effects of 0 to 22.2 percent in intervention groups and 0 to 5.0 percent in control groups, and the probiotic trial reported three cases of abdominal pain (5.4% v 2.8%).

### FH

#### Drug Therapy Intervention: Statins

##### Trial and Participant Characteristics

All 10 RCTs of statin interventions in children and adolescents with FH included for KQ4 also reported harms (Table 19).^115–124^ These harms were dermatologic,^116,^ ^117,^ ^121^ gastrointestinal,^116–119,^ ^121,^ ^124^ hormonal,^116–118,^ ^121,^ ^123,^ ^124^ hepatic,^115–119,^ ^121,^ ^123,^ ^124^ and musculoskeletal.^115–117,^ ^119,^ ^121,^ ^123,^ ^124^ Overall total adverse events and withdrawals were reported in all but one trial.^120^ Most trials were generally short-term, ranging from 6 to 28 weeks.^115–120,^ ^122,^ ^124^ Two longer trials were 48 weeks^121^ and 2 years.^123^ Thus, much of the evidence reflects short-term harms only.

Three NRSI were also included for harms of statins (Table 66). Longer-term harms in children and adolescents with FH are available from one good-quality NRSI study (n=309) which was a 10-year observational followup of the included Wiegman et al 2-year RCT.^123,^ ^148^ Inclusion criteria were children 8-18 years with FH diagnosis based on genetic confirmation or serum LDL-C threshold who previously participated in the 2 year statin trial; at the end of the trial, all participants with FH received the statin. The control group was non-FH siblings of the participants, none of whom were taking statins. This study was conducted in the Netherlands and collected data between 1997 and 2011.

Table 66 Familial Hypercholesterolemia: Characteristics of Statin Nonrandomized Studies of Interventions in Children and Adolescents With Familial Hypercholesterolemia or Multifactorial Dyslipidemia (Key Question 5)

Previous Include | Author, Year Study Name; Quality | Study Aim | Lipid Criteria | Brief Population Description | Country | Years of Data Collection | Recruitment Setting and Methods | N
| Desai, 2019^149^; Fair | To evaluate the hepatoxicity of statins | FH/MFD not part of inclusion criteria; participants evaluated in lipid clinic | Patients age ≤21 years evaluated in lipid clinic from September 1, 2010 to March 1, 2014 with ≥1 serum ALT measurement | US | 2010-2014 | Lipid clinic; Patients ≤21 years evaluated in Preventive Cardiology Program | 943
| Joyce, 2017^150^; Fair | To evaluate the association between statin use and the risk of type 2 diabetes | FH/MFD not part of inclusion criteria; patients with a claim for “pure-hypercholesterolemia” (ICD-9 272.0) which includes heFH were part of a subgroup analysis | Youth aged 8-20 years with dyslipidemia and without type 2 diabetes | US | 2003-2014 | Commercial health insurance claims database | 9393
X | Kusters, 2014^148^; AfterTen; Good | 10-year observational followup after participation in an RCT of statin therapy in children and adolescents with FH | 100% FH; 1 parent with definite clinical or molecular diagnosis of FH; 2 fasting samples with LDL-C levels ≥155 mg/dL and TG levels <350 mg/dL after 3 months on fat-restricted diet | Children aged 8-18 years with FH who previously participated in 2-yr statin trial and non-FH siblings | The Netherlands | 1997-2011 | Academic; Participants of a statin RCT and their non-FH siblings | 309

Abbreviations: FH/MFD = familial hypercholesterolemia/multifactorial dyslipidemia; heFH = heterozygous familial hypercholesterolemia; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; NRSI = non-randomized studies of interventions; RCT = randomized controlled trial; TG = triglycerides

Two fair-quality NRSIs from the United States included participants with hyperlipidemia without specifying whether the hyperlipidemia was FH or multifactorial.^149,^ ^150^ One study (n=9,393) had the aim of evaluating whether statin use was associated with the risk of type 2 diabetes^149^ and included children and adolescents 8 to 20 years from an insurance database with data collected between 2003 and 2014.^149^ The other smaller study (n=943) aimed to evaluate the hepatoxicity of statins in individuals 21 years or younger from a lipid clinic with one or more serum ALT measurements available; data were collected for 3.5 years between 2010 and 2014.^149^

##### Outcomes (Results)

The harms reported in the statin intervention groups and control groups were similar, however, most studies were small with few events leading to imprecise estimates (Figures 38–40; Appendix E Tables 8–18). Total adverse events were reported in seven trials and were similar in the intervention and control groups, ranging between 0 to 70.1 percent in statin groups and 0 to 73.8 percent in control groups.^116–119,^ ^122–124^ Total adverse event reporting was broad in the trials reporting high total adverse event rates and often included minor transient symptoms such as diarrhea or respiratory tract infections, which are unlikely to be intervention-related. For example, in the study reporting the highest rates of total adverse events (IG: 70.1%, CG: 73.8%), more than half of these events were respiratory tract infections. Gastrointestinal^116–118,^ ^121,^ ^124^ and dermatologic^116,^ ^117,^ ^121^ side effects were similar in the intervention and control groups. Transaminitis (elevated ALT or AST) of any severity ranged from 0 to 22.2 percent in the statin groups and 0 to 5.5 percent in the control groups.^115–118,^ ^121,^ ^123,^ ^148^ However, transaminitis of 3 times or more the upper limit of normal, which is a typical threshold in clinical practice for discontinuation and rechallenge with another statin, occurred in 0 to 4.5 percent in the intervention groups and 0 to 1.9 percent in the control groups. The largest trial (n=214) of longest duration (2 years) by Wiegman and colleagues reported no cases of transaminitis greater than 3-fold elevation in the statin group and two cases in the control group.^123^ One NRSI^148^ (n=309) which was a 10 year observational followup of the 2 year trial by Wiegman and colleagues and used non-FH siblings not taking statins as the control group, reported similar rates of transaminitis in the statin and control groups; 1 treated FH individual and no untreated non-FH siblings had ALT >3 times normal and 1 treated FH individual and 1 untreated non-FH siblings had AST >3 times normal. Abnormal creatine kinase of any severity occurred in 0 to 15.4 in the intervention groups and 0 to 1.7 percent in control groups.^115,^ ^117,^ ^119,^ ^121,^ ^123,^ ^124,^ ^148^ Abnormal creatine kinase of at least 10 or more times the upper limit of normal was reported as zero in two trials^117,^ ^124^ and up to 4.5 percent in the intervention groups and up to 1.7 percent in the control groups in two other trials reporting this threshold.^119,^ ^121^ In the NRSI (n=309) which was a 10-year observational followup of the Wiegman et al 2-year RCT, elevated creatine kinase was diagnosed in no participants on statins and two non-FH siblings not taking statins.^148^ No significant differences between Tanner stages or other hormonal adverse events were reported.^116–118,^ ^121,^ ^123,^ ^124,^ ^148^

Figure 38 Familial Hypercholesterolemia: Statin Intervention Trials—Total Adverse Events (Key Question 5)

NOTE: Blue and orange colors indicate intervention (blue) or control (orange). Darker shading corresponds to higher percentages.

* Number of events, not people.

Abbreviations: CG = control group; IG = intervention group

For Familial hypercholesterolemia, this figure shows total adverse events for statin intervention trials (Key Question 5)

Figure 39 Familial Hypercholesterolemia: Statin Intervention Trials—Liver Enzyme Adverse Events (Key Question 5)

NOTE: Blue and orange colors indicate intervention (blue) or control (orange). Darker shading corresponds to higher percentages.

* Number of individual tests, not people.

Abbreviations: ALT = alanine aminotransferase; AST = aspartate transaminase; CG = control group; IG = intervention group; mg/d = milligrams per day; n = number; NRSI = nonrandomized studies of interventions; RCT = randomized controlled trial; ULN = upper limit of normal.

For Familial hypercholesterolemia, this figure shows liver enzyme adverse events for statin intervention trials (Key Question 5)

Figure 40 Familial Hypercholesterolemia: Statin Intervention Trials—Abnormal Creatinine Kinase Level Results (Key Question 5)

NOTE: Blue and orange colors indicate intervention (blue) or control (orange). Darker shading corresponds to higher percentages.

Abbreviations: CG = control group; IG = intervention group; mg/d = milligrams per day; n = number; NRSI = nonrandomized studies of interventions; RCT = randomized controlled trial; ULN = upper limit of normal.

For Familial hypercholesterolemia, this figure shows abnormal creatinine kinase level results for statin intervention trials (Key Question 5)

The NRSI reporting on hepatoxicity measures reported slightly higher rates of elevated ALT in participants on statins compared to those not on statins, but statistical testing was not performed due to the rarity of events (Appendix E Table 11).^149^ Desai et al reported ALT elevations of greater than 3 times the upper limit of normal with a frequency of 4.4 percent in the statin group and 1.5 percent in the control group over 3.5 years of observation.

The NRSI reporting on the association of statin use with new onset diabetes found no statistically significant association (Appendix E Table 18).^150^ Joyce et al reported that 17 of 869 (2.0%) of participants taking statins developed new onset diabetes compared to 146 of 8524 (1.7%) in the control group (HR 1.11 [95% CI, 0.65 to 1.90]) over up to 9 years followup. This nonsignificant difference was similar when the analysis was limited to participants with pure hypercholesterolemia which is a surrogate for FH (HR 1.11 (95% CI, 0.58 to 2.12]).

#### Drug Therapy Intervention: Bile Acid Sequestrants

##### Outcomes (Results)

The harms reported in the three bile acid sequestrant trials appeared similar, however the trials were generally small with few events and significance testing was not reported (Table 29; Appendix E Tables 19–23).^125–127^ Total adverse events, reported in one trial, were similar between the groups (3.75 g dose: 6.3%, 1.875 g dose: 10.8%, control: 10.8%).^125^ Withdrawals due to adverse events were low in two of three trials, ranging from 0 to 4.6 percent in intervention groups and were 0 percent in control groups.^125,^ ^127^ However, there was one outlier trial with a high withdrawal rate due to adverse events in both the intervention and control groups, largely due to lack of palatability of the drug or placebo (38.9% v 27.8%).^126^ Individual gastrointestinal side effects such as diarrhea, intestinal obstruction, abdominal pain, and vomiting were reported in 0 to 13.6 percent of participants taking bile acid sequestrants and 0 to 11.5 percent taking placebo.^125,^ ^126^ Elevations in creatine phosphokinase (with no specified threshold) were reported in 1.6 percent of the high dose group, 3.1 percent of the low dose groups, and none in the control group.^125^ In the one trial reporting nutritional deficiencies, folate deficiency and vitamin D deficiency were 4.5 percent and 13.6 percent, respectively, in the intervention group and 0 percent in the control group.

#### Drug Therapy Intervention: Ezetimibe

##### Outcomes (Results)

In the one trial of ezetimibe compared to placebo, harms generally occurred in the same rates in both groups (Table 29; Appendix E Tables 19–23).^128^ There were no reported serious drug-related adverse events in either group. There were few withdrawals due to drug-related adverse events (IG: 2/92 [2.2%], CG: 0/45 [0%]). There were three total withdrawals in the intervention group due to ALT elevation, prurigo, and an epileptic event in a patient with congenital epilepsy. One case of transaminitis (ALT ≥3 times ULN) occurred in an intervention group participant (1.1% [1/92]) and no cases occurred in the control group. There were no reported elevations in CK (defined as ≥10 times ULN with or without muscle symptoms or ≥5 times ULN with symptoms), rhabdomyolysis, pancreatitis, or cholecystitis. The one adverse event with a statistically significant difference between groups was diarrhea, occurring more frequently in the control group (−7.8% difference [95% CI, −19.8 to −1.1]).

#### Drug Therapy Intervention: Fibrate

##### Outcomes (Results)

Two adverse events were reported in the small trial of fibrate compared to placebo (Table 29; Appendix E Tables 21 and 22).^129^ There was one participant in the intervention group with a transiently elevated abnormal alkaline phosphatase (7.1% [1/14]) and one participant with a transient elevation in ALT that normalized by the end of the third month of treatment (7.1% [1/14]). No drug-related clinical adverse events were reported.

#### Drug Therapy Intervention: PCSK9 Inhibitors

##### Outcomes (Results)

In the one trial of PCSK9 inhibitors, there were similar rates of total adverse events in the intervention and control groups (62% v 64%) (Table 29; Appendix E Tables 19–23).^130^ Total adverse event reporting, however, was broad and included minor and transient events which are unlikely to be intervention-related, such as nasopharyngitis and headache. There were no serious adverse events related to the drug. There was one withdrawal due to adverse events in the intervention group where drug-related arthropathy led to discontinuation (1.0% [1/104]). One intervention group participant experienced an injection site reaction (1.0% [1/104]).

#### Drug Therapy Intervention: Combination Therapy

##### Outcomes (Results)

In the one combination drug therapy trial comparing treatment with ezetimibe and a statin to a statin alone, there were similar rates of total adverse events in both groups (83% v 84%) (Table 29; Appendix E Tables 19–23).^131^ As with other drug interventions, adverse event reporting was broad and included minor or transient symptoms which are unlikely to be intervention-related, such as diarrhea, headache, or sinusitis. Two participants in the combination drug therapy group withdrew due to adverse events (2/122 [1.6%]) and one participant in the control group withdrew due to a laboratory adverse event (1/118 [0.8%]). Six participants in the combination drug therapy group (5%) and three participants in the single drug therapy group (2%) experienced ALT elevations, however, varied thresholds were used by individual investigators and did not always reach 3 times the upper limit of normal. There were no clinically significant adverse effects on growth, sexual maturation, or hormones. Gastrointestinal, dermatologic, and musculoskeletal outcomes appeared similar in both groups; however, significance testing was not reported.

#### Behavioral Counseling Interventions

##### Outcomes (Results)

The one behavioral counseling trial included for the FH population did not address harms.^132^

#### Supplement Interventions

##### Outcomes (Results)

In three of the four supplement trials conducted in FH populations (Table 42), authors explicitly reported that there were no adverse events.^133,^ ^135,^ ^136^ The other trial did not address harms.^134^

### Multifactorial Dyslipidemia

#### Behavioral Counseling Interventions

##### Outcomes (Results)

The two behavioral counseling trials in children with multifactorial dyslipidemia reported that growth and development, nutrient adequacy, and psychosocial outcomes were similar between the intervention and control groups (Table 49; Appendix E Tables 24 and 25).^137,^ ^138^ In the DISC trial, there was no difference in growth and development measures including BMI (3 y: MD −0.04 kg/m^2^ [95% CI, −0.3 to 0.2]; 7 y: MD −0.1 kg/m^2^ [95% CI, −0.5 to 0.4]), height (MD 0.6 cm [95% CI, −0.02 to 1.2]; 7 y: −0.3 cm [−1.0 to 0.4]), weight (3 y: MD 0.3kg [−0.5 to 1.0]), and Tanner staging (6 y: reported as not statistically different) between the dietary intervention and control groups. Likewise, CHP reported similar height and weight z-score changes in the intervention and control groups at 1 year.^137^ Serum ferritin, red cell folate, serum retinol, serum zinc and albumin were similar in the dietary intervention and control groups in the DISC trial.^138^ Psychosocial outcomes were similar for anxiety, behavioral issues, and suicidality in the DISC trial. Depression scores, however, as assessed using the Child Depression Inventory (CDI) were better in the intervention group at 3 years (OR for CDI ≥14 score: 0.24 [95% CI, 0.09 to 0.65]).^138^ In the CHP trial, behavior problems, as assessed in 4 to 6 year-olds using the Conners Parent Rating Scale, and health beliefs and self-perceived competence, as assessed in 6- to 10-year-olds using the Perceived Competence Scale, were similar in the intervention and control groups.^137^

#### Supplement Interventions

##### Outcomes (Results)

In the flaxseed supplement trial, authors explicitly reported that there were no adverse events or withdrawals due to adverse events (Table 53; Appendix E Table 26).^139^ In the fish oil supplement trial, intervention-related adverse events included gastrointestinal symptoms, fishy taste and frequent nose bleeds resulting in dose reductions in two participants; authors did not report prevalence of adverse events by group.^140^ There were no withdrawals due to adverse events in the fish oil supplement trial.

### Multifactorial Dyslipidemia/FH

#### Supplement Interventions

##### Outcomes (Results)

Five of the seven supplement trials reported a harm outcome, and reporting was varied among studies (Table 57; Appendix E Table 27). One trial each reported withdrawals due to adverse events^141^ or serious drug related adverse events,^145^ and there were no events in any group. Two trials explicitly stated that there were no adverse events.^146,^ ^147^ In the glucomannan study by Guardamagna and colleagues, the intervention group reported frequent gastrointestinal effects (4/18 [22.2%] vs 0/18) and increased satiety (2/18 [11.1%] vs 0/18 [0%]) but the study size was small and number of events was low.^141^ There were a few reported cases of abdominal pain in the probiotic trial intervention group (2/37 [5.4%] vs 1/36 [2.8%]) but again study size was small and the number of events was low.^145^ The small psyllium fiber trial reported diarrhea more frequently in the control group with (IG: 0%, CG: 5%).^144^