# Chapter 2 Methods

## Scope and Purpose

This systematic review is a combined update of two prior reports^2,^ ^3^ to support the 2016 USPSTF recommendation on screening for lipid disorders in children and adolescents.^1^ Previously, separate reports were issued for familial hypercholesterolemia (FH) and multifactorial dyslipidemia, defined as lipid elevations from causes other than FH. Our update includes studies published since the previous reviews and studies from the previous reviews that met updated inclusion criteria.

## Analytic Framework and Key Questions

We followed USPSTF procedures and methods to define study inclusion and exclusion criteria (Appendix A Table 1) and developed an analytic framework (Figure 1) with five Key Questions (KQs).

Figure 1 Analytic Framework

*Multifactorial dyslipidemia is defined as dyslipidemia not due to familial hypercholesterolemia.

^†^CVD events are defined as myocardial infarction or ischemic stroke.

Abbreviations: BMI = body mass index; CVD = cardiovascular disease.

Figure 1 is the analytic framework that depicts the five Key Questions to be addressed in the systematic review. The figure illustrates how screening for familial hypercholesterolemia (FH) or multifactorial dyslipidemia in asymptomatic children and adolescents may result in delayed or reduced incidence of health outcomes (CVD events,*CVD mortality, or all-cause mortality) or improve intermediate outcomes (serum lipid levels, atherosclerotic markers, BMI, physical activity, sedentary behavior, dietary intake) in children, adults, or both (KQ1). There is also a question related to the diagnostic yield of serum lipid screening for FH or multifactorial dyslipidemia (KQ2) and the harms of screening for these conditions in children and adolescents (KQ3). Additionally, the figure illustrates how treatment of FH or multifactorial dyslipidemia with lifestyle modifications, lipid-lowering medications, or both in children and adolescents may delay or reduce the incidence of health outcomes (CVD events,*CVD mortality, or all-cause mortality) or improve intermediate outcomes (serum lipid levels, atherosclerotic markers, BMI, physical activity, sedentary behavior, dietary intake) in children, adults, or both (KQ4) and what harms are associated with these treatments (KQ5).

KQ1 Does screening for familial hypercholesterolemia (FH) or multifactorial dyslipidemia in asymptomatic children and adolescents delay or reduce the incidence of health outcomes (e.g., CVD events^*^ or mortality) or improve intermediate outcomes (e.g., serum lipid levels and atherosclerotic markers) in children, adolescents, or adults?
KQ2 What is the diagnostic yield of serum lipid screening for FH or multifactorial dyslipidemia in children and adolescents?
KQ3 What are the harms of screening for FH or multifactorial dyslipidemia in children and adolescents?
KQ4 Does treatment of FH or multifactorial dyslipidemia with behavioral interventions, lipid-lowering medications, or both in children and adolescents delay or reduce the incidence of health outcomes (e.g., CVD events^*^ or mortality) or improve intermediate outcomes (e.g., serum lipid levels and atherosclerotic markers) in children, adolescents, or adults?
KQ5 What are the harms of treatment of FH or multifactorial dyslipidemia in children and adolescents?

* CVD events are defined as MI or ischemic stroke.

## Data Sources and Searches

We considered all studies from the previous reviews on this topic for inclusion in the current review and performed a comprehensive search for new literature. We searched MEDLINE, and the Cochrane Central Register of Controlled Clinical Trials for relevant studies published between January 2015 and May 16, 2022. Studies included in the previous USPSTF reviews were evaluated for inclusion against the eligibility criteria for the current review. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian (Appendix A). Additionally, due to an expansion in the scope of the current review to broaden eligible thresholds for defining multifactorial dyslipidemia, we performed a targeted review of previously excluded studies.

We also examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. We supplemented our searches with suggestions from experts and articles identified through news and table-of-contents alerts. We conducted ongoing surveillance for relevant literature through March 24, 2023. One new study was identified;^96^ however, it did not substantively change the review’s interpretation of findings or conclusions and is not addressed further. We also searched ClinicalTrials.gov (https://ClinicalTrials.gov/) for ongoing trials. We managed all literature search results in EndNote® X9 (Thomson Reuters, New York, NY).

## Study Selection

Detailed inclusion and exclusion criteria were developed to guide study selection (Appendix A Table 1). Two reviewers independently reviewed the titles and abstracts of all identified articles to determine whether studies met these criteria. Two reviewers then independently evaluated the full text of potentially relevant studies. Disagreements regarding the abstract and/or full text review were resolved by discussion and consultation with a third reviewer if necessary. We used DistillerSR (Evidence Partners, Ottawa, Canada) to conduct abstract and full-text review, where records were kept of all included and excluded studies.

Study selection details specific to each KQ are provided below. For all KQs, we required that studies be conducted among children and adolescents 20 years of age or younger and in countries categorized as “Very High” on the 2019 Human Development Index (as defined by the United Nations Development Programme).^97^ Studies needed to be conducted in primary care or a setting referrable from primary care. We required that studies be published in the English language.

### KQ1 and KQ3 (Benefits and Harms of Screening)

For studies evaluating the benefits and harms of lipid screening, we included RCTs or controlled clinical trials (CCTs) of universal or selective screening using a serum lipid panel compared to no screening or usual care. Populations with homozygous FH, those already being followed for dyslipidemia, or with diagnoses associated with secondary dyslipidemia were excluded, as were populations with an established family history of FH. Screening could have been performed with a fasting or nonfasting lipid measurement, which included one or more of the following lipid components: TC, LDL-C, HDL-C, non-HDL-C, or TG. Interventions consisting solely of apolipoprotein screening were excluded as were studies of genetic screening alone or cascade screening for FH. Screening based exclusively on apolipoproteins or genetic screening were excluded because these are not common screening practices in U.S. primary care. Cascade screening was excluded because this represents a case finding approach as opposed to population screening. Further, rigorous cascade screening is not currently implementable in the United States due to HIPAA and lack of current infrastructure.^98^

KQ1 studies evaluating benefits needed to report a health outcome, intermediate outcome, or intermediate behavioral health outcome for inclusion. Eligible health outcomes were MI, ischemic stroke, CVD mortality, or all-cause mortality. Intermediate outcomes were serum lipid concentrations (TC, LDL-C, HDL-C, TG, or non–HDL- C), atherosclerosis markers (carotid intima-media thickness, calcium score, or pathological findings), or BMI, and intermediate behavioral outcomes were physical activity, sedentary behavior, or dietary intake.

KQ3 studies evaluating harms needed to report psychosocial effects of screening, overdiagnosis, or false positives or false negatives if there was a confirmatory test. We excluded studies reporting the psychosocial functioning of children with elevated lipids versus normal lipids, as these studies address questions of association between lipids and psychosocial variables but not screening. We did not include studies evaluating the accuracy of calculated Friedwald or novel approaches versus direct measurement for LDL because we were not focused on a comparative question of lab assays. Further, we did not include studies evaluating the accuracy of fasting versus nonfasting lipid measurements as we sought to identify the harms of screening compared to no screening or usual care. Finally, we did not include studies that addressed the diagnostic accuracy of serum lipids or clinical FH criteria against a genetic test for FH.

### KQ2 (Diagnostic Yield)

For studies evaluating the diagnostic yield of serum lipid screening, we included recent, large cohort studies that conducted universal or selective lipid screening and reported screen positivity for any stated threshold of elevated lipids. We initially looked for studies reporting positive predictive value of a first elevated screening lipid result for a second confirmatory test. No studies used a confirmatory test, so we accepted studies reporting screen positivity based on a single lipid test. As for KQ1, screening could have been performed with a fasting or nonfasting lipid measurement, which included one or more of the following lipid components: TC, LDL-C, HDL-C, TG, or non-HDL-C. Lipid screening needed to be population-based or conducted in a community setting, in primary care, or in a setting referrable from primary care.

Because of a very large body of potentially included studies, we limited the evidence base to large, recent, US-based cohorts to ensure greatest applicability. Specifically, we required samples to be larger than 1,000 participants and to have data collected after the year 2000. The minimum study size of 1,000 participants represents relatively broad criteria selected to increase geographic representation in the United States as well as inclusive representation of racial and ethnic groups. For cohorts with multiple publications and multiple measurements over time, we identified the largest or most recent publication for each specific population strata as follows: age, sex, race and ethnicity, BMI status, and family history. Publications focusing on other participant characteristics (e.g., vitamin D status, grip strength, stature) were excluded.

### KQ4 and KQ5 (Benefits and Harms of Treatment)

For KQ4 and KQ5 studies evaluating the benefits and harms of treatment, we included RCTs of lipid-lowering medications, behavioral interventions to promote healthy diet or physical activity, and dietary supplements. Apheresis and revascularization interventions were excluded. We required a comparator group of no treatment or usual care. For children and adolescents with FH, usual care was defined by contemporary treatment recommendations,^4^ including therapeutic lifestyle change and a statin if LDL-C remained above goal after lifestyle intervention. Thus, a study in an FH population that included a statin as a control and a statin plus another agent in the intervention group (IG) would be acceptable. Studies in FH populations that used outdated usual care pharmacotherapy interventions were excluded. In populations without FH, brief diet advice was an acceptable control group (CG), but more intensive lifestyle counseling was considered too intensive as a comparator. Comparative effectiveness studies, such as studies of low-dose versus higher-dose agents, were not included for efficacy or harms.

For KQ5 studies evaluating the harms of treatment, we included nonrandomized studies of interventions (NRSIs) in addition to RCTs.^99^ As for RCTs, a comparator group of no treatment or usual care was required in NRSIs. Pre-post study designs were excluded.

Treatment studies could have populations that were identified in any manner, including cascade screening, but children and adolescents with homozygous FH or a dyslipidemia diagnosis associated with secondary dyslipidemia were excluded.

KQ4 studies needed to report a health outcome, intermediate outcome, or intermediate behavioral health outcome for inclusion. Eligible health outcomes were MI, ischemic stroke, CVD mortality, or all-cause mortality. Intermediate outcomes were serum lipid concentrations (TC, LDL-C, HDL-C, TG, or non–HDL- C), atherosclerosis markers (carotid intima-media thickness, calcium score, or pathological findings), or BMI, and intermediate behavioral outcomes were physical activity, sedentary behavior, or dietary intake. KQ5 studies evaluating harms needed to report a harm outcome related to lipid-lowering medications (e.g., adverse events, long-term safety) or lifestyle modification (e.g., nutritional harms, psychosocial measures).

## Quality Assessment

Two reviewers applied USPSTF design-specific criteria^100^ to assess the methodological quality of all eligible studies (Appendix A Table 2). Previously included studies were re-rated for consistency with newly included studies. We assigned each study a quality rating of “good,” “fair,” or “poor.” Discordant quality ratings were resolved by discussion or adjudicated by a third reviewer as needed. Studies rated as poor-quality were not eligible for the review.

For cohort studies evaluating yield of screening tests for elevated lipids (KQ2), we developed a brief set of critical appraisal questions tailored to this type of study and outcome. These questions addressed bias in sample selection, differences in those participating and not participating in the study, the extent of missing data, consistent and appropriate outcome measurement, and selective reporting bias. Specifically, we evaluated whether the screening test was the same for every participant in a study, for example whether lipid tests were universally fasting or nonfasting. Studies in which both modalities were used but reporting was not stratified could at best be rated as fair. Further, evidence of sampling bias was considered a fatal flaw and studies with sampling bias were rated as poor—for example, yield studies with the aim of describing screening practices where screening was rare and those screened had different characteristics than those not screened. For a yield study to be rated as good, we required information about whether nonrespondents were different from respondents and whether those with missing data were different from those with complete data.

Good-quality RCTs were those that met all or nearly all the specified quality criteria. Specifically, comparable groups were assembled initially and maintained throughout the study, followup was 90 percent or higher, assessment procedures were described and blinded if they involved direct interviews, randomization methods were described, and allocation was concealed. Fair-quality studies did not meet all criteria but did not have serious threats to their internal validity related to design, execution, or reporting. To be rated as poor-quality, intervention studies generally had several important limitations, including at least one of the following risks of bias: very high attrition (generally >40%); differential attrition between intervention arms (generally >20%); lack of baseline comparability between groups without adjustment; or problematic issues in trial conduct, analysis, or reporting of results (e.g., possible selective reporting; inappropriate exclusion of participants from analyses; questionable validity of allocation or assessment procedures).

For nonrandomized studies of interventions evaluated for harms outcomes only (KQ5), good quality studies had to have a low risk of bias in all of the following domains: baseline and time-varying confounding, participant selection, intervention classification, departure from intended interventions, missing data, outcome measurement, and selective reporting.^101^ Fair-quality studies did not meet all criteria but did not have serious threats to their internal validity related to design, execution, or reporting. To be rated as poor-quality, intervention studies generally had several important limitations, including lack of an appropriate control group, unclear or biased participant selection, problematic categorization of treatment status, differential followup in treated and untreated groups, or outcome measurement that was poorly described or did not use standardized procedures.

## Data Abstraction

For all included studies, one reviewer extracted key elements into standardized abstraction forms in DistillerSR (Evidence Partners, Ottawa, Canada). A second reviewer checked the data for accuracy. Extracted data elements included general characteristics of the study (e.g., author, year, study design, country), clinical and demographic characteristics of the sample and setting (e.g., age, sex, race and ethnicity, baseline lipid values), intervention details (e.g., screening intervention and threshold for KQ2 studies of yield or treatment details for KQ4 and KQ5 studies), analytic methods (e.g., adjustments), and outcomes of interest as prespecified in the inclusion criteria. For KQ2 studies of screening yield, we abstracted results for the prevalence of abnormal lipids in the overall study population and in population strata defined by age, sex, race and ethnicity, BMI status, and family history. We abstracted prevalence for thresholds for elevated lipids as defined by study authors. For treatment studies (KQ4 and KQ5), we abstracted only the longest followup for outcomes if multiple timepoints were reported. For harms outcomes (KQ5), we abstracted dichotomous versions of lab outcomes (e.g., the proportion of individuals with elevated values above a stated threshold), as the clinical meaning of small changes in continuous measures for these lab outcomes is unknown. For KQ4 and KQ5 studies, we audited the availability of subgroup analyses.

## Data Synthesis and Analysis

All results were synthesized separately for FH and multifactorial dyslipidemia populations. Results for the evidence related to the prevalence of FH and elevated lipids (KQ2) were synthesized narratively and summarized in tables. For KQ2 studies, numerators and denominators were back-calculated as appropriate and confidence intervals were computed if not reported for the prevalence rate. For treatment studies (KQ4 and KQ5), we synthesized results by intervention type (e.g., statins, bile acid sequestrant, ezetimibe, fibrate, PCSK9 inhibitor, combination drug therapy, and lifestyle counseling). Except for statins, which had the largest body of evidence, these interventions did not allow for quantitative pooling due to the limited number of contributing studies; these data are summarized narratively and in tables. For continuous lipid measures, the body of evidence for statins allowed for meta-analysis of TC, LDL-C, and HDL-C. Due to either high statistical heterogeneity (commonly I^2^>50) or to small number of trials to be pooled, the random effects restricted maximum likelihood method with the Knapp-Hartung correction was applied in meta-analyses.^102,^ ^103^ We used change from baseline in each group as the measure for analysis and crude effect estimates were calculated if between group results were not reported; we favored adjusted over unadjusted effect estimates. For pooling statin studies with multiple randomized groups with differing statin intensity, we selected the highest intensity dose group. Statin intensity categorizations were based on 2018 guidelines for the management of cholesterol in adults,^31^ as intensity categorizations are not established for pediatric populations. Studies with multiple randomized groups of differing intensity were evaluated qualitatively to assess dose-response relationships.

Statistical heterogeneity among pooled studies was evaluated using standard χ2 tests and the magnitude of heterogeneity was estimated using the I^2^ statistic. Due to the limited number of trials for pooled analyses of statins (k <10), assessment of small study effects and publication bias were not performed.^104,^ ^105^

For the dichotomous measure of the proportion of individuals meeting LDL-C goals, we computed the crude absolute risk difference (ARD) between treatment and control groups. Due to the limited number of studies and differing LDL-C thresholds in studies, we used visual displays and tables to describe the results and did not pool.

All quantitative analyses were performed using Stata 16.1 (StataCorp, College Station, TX).

## Grading the Strength of the Body of Evidence

The strength of evidence for each outcome was graded using an adaptation of the Evidence-based Practice Center approach,^106^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^107^This adaptation explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations, risk of bias). We do not evaluate the fifth domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there was insufficient evidence for a particular outcome). Study quality summarizes the quality ratings of the individual trials included for an outcome and indicates the degree to which the results are likely to have adequately low risk of bias. The limitations domain highlighted important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients or nonreporting of outcomes in some trials).

The overall strength of evidence was graded as “high,” “moderate,” “low,” or “insufficient.” “High” indicates high confidence that the evidence reflects the true effect, and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect, and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect, and that further research is likely to change our confidence in the estimate of effect and to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. At least two independent reviewers rated the overall strength of evidence for each intervention type. We resolved discrepancies through consensus discussion involving more reviewers.

## Contextual Questions

In addition to the systematically reviewed questions (KQs 1–5), we also addressed contextual questions (CQs) to aid with the broader interpretation of the evidence. Contextual questions are important considerations that may not be readily answerable from the available RCT literature. Two CQs were prespecified in our research plan:

CQ1 What is the association between lipid-related childhood and adolescent intermediate outcomes and adult health outcomes?
CQ2 What is the optimal timing of statin treatment initiation in FH?

CQs are not systematically reviewed. Evidence for CQs was identified based on literature retrieved for the systematic search for KQs as well as targeted searches and scanning bibliographies of relevant articles. A best evidence approach was used to identify most recent, applicable, and robust evidence. CQs are addressed in the Discussion.

## Expert Review and Public Comment

The draft Research Plan was posted for public comment on the USPSTF website from May 13 June 9, 2021. The USPSTF received comments regarding the selection of outcomes, expansion of the screening population to the family, and the inclusion of adult health outcomes in the Analytic Framework. In response, the USPSTF added BMI, physical activity, sedentary behavior, and dietary intake as intermediate outcomes. The USPSTF retained the focus of the screening population on children for this review because of other available lipid-related USPSTF recommendations in adults, and because of the current prevalence of lipid screening in the general adult population. Adult health outcomes were retained in the Analytic Framework in accordance with USPSTF methods. A final Research Plan was posted on the USPSTF website on August 19, 2021. The draft version of this report was reviewed by three invited experts and five individuals at USPSTF Federal Partner agencies. Experts were selected based on their expertise with both methodologic and content aspects of the review and were selected to obtain diverse informed perspectives. All expert comments were considered, and the report was updated to improve clarity, ensure accuracy, and address scientifically relevant concerns.

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis. AHRQ staff provided oversight for the project, coordinated the systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.