# Chapter 1 Introduction

## Purpose

This report will be used by the United States Preventive Services Task Force (USPSTF) to update its 2016 recommendation on screening for lipid disorders in children and adolescents.^1^ The 2016 recommendation was based on two separate systematic review reports: screening for familial hypercholesterolemia,^2^ and screening for multifactorial dyslipidemia.^3^ This systematic review presents updated evidence in a single report with special attention to clearly delineating the evidence specific to familial hypercholesterolemia and multifactorial dyslipidemia.

## Condition Background

### Condition Definition

Familial hypercholesterolemia (FH) is an autosomal codominant genetic disorder of lipid metabolism associated with elevated levels of low-density lipoprotein-cholesterol (LDL-C) which causes premature atherosclerosis and early cardiovascular mortality and morbidity.^4^ There are both heterozygous and homozygous forms of FH, with the latter being characterized by much higher total and LDL-C levels.^5^ In addition to premature CVD experienced in homozygous and heterozygous FH patients, LDL-C deposits can cause tendon xanthomas and corneal arcus; these manifestations are more severe and occur earlier in homozygous FH compared to heterozygous FH.^6,^ ^7^ This report specifically addresses heterozygous FH as it is the most common monogenic cause of dyslipidemia.^8^

FH is genetically heterogeneous and is caused most frequently by pathogenic variants in the low-density lipoprotein receptor (LDLR), APOB or proprotein convertase subtilisin/kexin type 9 (PCSK9) genes; there are additionally other pathogenic variants with very low frequency which manifest as a FH-like phenotype.^9^ However, the relationship between the FH genotype arising from these variants and the FH phenotype characterized by elevated LDL-C is not straightforward.^10^ For example, analyses in adults have shown that among those with LDL-C ≥190 mg/dL, less than 2 percent carried a FH mutation.^11^The rate of detection of pathogenic variants among those meeting clinical criteria for FH has been shown to be as low as 52 percent, suggesting deficiencies in genetic testing strategies or that there may be a more complex polygenic basis for the FH phenotype.^10^ Further, while a very high percentage of FH pathogenic variant carriers show elevated lipid levels, not all individuals with a confirmed genetic variation will have a severe dyslipidemia phenotype.^12–14^ For example, one analysis reported that the penetrance for 59 pathogenic/loss of function variants for LDLR ranged from 0 to100 percent.^15^ This complex relationship between FH genotype and phenotype may give rise to controversy over whether clinical criteria or a molecular definition of FH is more appropriate. Some have suggested a new classification paradigm for FH whereby the presence or absence of the pathogenic variant and severe hypercholesterolemia are specified.^16^

There are no globally accepted diagnostic criteria for FH.^7,^ ^17^ The US-based Make Early Diagnosis Prevent Early Death (MEDPED) criteria are genetically validated thresholds that use lipid levels in conjunction with age and family history of known FH.^18^ The UK-based Simon Broome criteria^19^ and the Dutch Lipid Clinic Network criteria (DLCNC)^7,^ ^20^ involve personal and family history, physical signs, and DNA analysis in addition to lipid levels. These criteria are summarized in Tables 1–3.

Table 1 MEDPED Criteria to Diagnose FH (United States)^18,*^

Age (years) | Total cholesterol (LDL-C) levels, mg/dL
Age (years) | First-degree relative ^†^ | Second-degree relative ^†^ | Third-degree relative ^†^ | General population
<20 | 220 (155) | 230 (165) | 240 (170) | 270 (200)
20-29 | 240 (170) | 250 (180) | 260 (185) | 290 (220)
30-39 | 270 (190) | 280 (200) | 290 (210) | 340 (240)
≥40 | 290 (205) | 300 (215) | 310 (225) | 360 (260)

* Expected to diagnose FH with 98% specificity and sensitivity ranging from 54% in the general population to 88% in first-degree relatives.

† First: parents, offspring, brother, and sister. Second: aunts, uncles, grandparents, nieces, nephews. Third: first cousins, siblings of grandparents.

Abbreviations: FH= familial hypercholesterolemia LDL-C = low-density lipoprotein cholesterol; MEDPED = Make Early Diagnosis to Prevent Early Death Program; mg/dL = milligrams per deciliter

Table 2 Simon Broome Criteria to Diagnose FH (United Kingdom)

Diagnosis | Requirements | Criteria
Definite FH | (a) + (b); OR; (a) + (c) | (a) Total cholesterol levels, mg/dL; Age ≥16 years: >290; Age <16 years: >260; Or; LDL-C levels, mg/dL; Adults: >190; Children: >155
Definite FH | (a) + (b); OR; (a) + (c) | (b) Tendon xanthomas in patient or in 1st or 2nd-degree^†^ relative
Definite FH | (a) + (b); OR; (a) + (c) | (c) DNA-based evidence of an LDL-C receptor mutation or familial defective apoB-100
Possible FH | (a) + (d); OR; (a) + (e) | (d) Family history of MI before age 50 in 2nd-degree relative or before age 60 in 1st-degree relative
Possible FH | (a) + (d); OR; (a) + (e) | (e) Family history of raised total cholesterol in 1st-degree relative or >290 mg/dL in 2nd-degree relative

* Table adapted from Marks, 2003.^192^

† First: parents, offspring, brother and sister. Second: aunts, uncles, grandparents, nieces, nephews.

Abbreviations: apoB = apolipoprotein type B; DNA = deoxyribonucleic acid; FH= familial hypercholesterolemia; LDL-C = low-density lipoprotein-cholesterol; mg/dL = milligrams per deciliter; MI = myocardial infarction

Table 3 Dutch Lipid Clinic Network Diagnostic Criteria for FH^193^

Criteria | | Points
Family history | 1st-degree^*^ relative with known premature (men aged <55 years; women <60 years) coronary or vascular disease or 1st-degree relative with known LDL-C >95th percentile | 1
Family history | 1st-degree relative with tendon xanthomata and/or corneal arcus, or child(ren) <18 years with LDL-C >95th percentile | 2
Clinical history | Patient with premature coronary artery disease (men aged <55 years; women <60 years) | 2
Clinical history | Patient with premature cerebral or peripheral vascular disease (men aged <55 years; women <60 years) | 1
Physical examination^†^ | Tendon xanthomas | 6
Physical examination^†^ | Corneal arcus at age <45 years | 4
LDL-C levels (without treatment) | ≥325 mg/dL^†^ | 8
LDL-C levels (without treatment) | 251 to 325 mg/dL | 5
LDL-C levels (without treatment) | 191 to 250 mg/dL | 3
LDL-C levels (without treatment) | 155 to 190 mg/dL | 1
DNA analysis | Functional mutation in the LDLR, apoB, or PCSK9 genes | 8
Choose only one score per group, the highest applicable; diagnosis is based on the total number of points obtained; A “definite” FH diagnosis requires >8 points; A “probable” FH diagnosis requires 6 to 8 points; A “possible” FH diagnosis requires 3 to 5 points

* 1st-degree: parents, offspring, brother, and sister.

† Exclusive of each other (i.e., maximum 6 points if both are present).

Abbreviations: apoB = apolipoprotein type B; DNA = deoxyribonucleic acid; FH = familial hypercholesterolemia; LDL-C = low-density lipoprotein cholesterol; LDLR = low-density lipoprotein receptor; mg/dL = milligrams per deciliter; PCSK9 = proprotein convertase subtilisin/kexin type 9.

For the purposes of this report, the term multifactorial dyslipidemia refers to dyslipidemias involving abnormal lipids that are not FH.^3^ Multifactorial dyslipidemia in children and adolescents may be associated with environmental factors, such as excessive intake of saturated fat, high carbohydrate diets containing principally simple sugars, and sedentary lifestyle, with or without an inherited component.^3,^ ^21–26^ Even apart from a monogenic condition with high penetrance, such as FH where there is a major variant in one gene, there are a number of single nucleotide variants with small individual effects that contribute to multifactorial dyslipidemia.^27^

Lipid disorders are defined according to population norms.^28,^ ^29^ Cutpoints for abnormal lipid values defining multifactorial dyslipidemia correspond to approximately the 95^th^ percentile from population-based cohorts.^30^ Table 4 shows thresholds for multifactorial dyslipidemia that are used in clinical guidelines and widely accepted in practice.^30,^ ^31^ These thresholds have not been validated as predictors for CVD events and they are not age- and sex-specific.^21,^ ^32^

Table 4 Acceptable, Borderline-High, and High Plasma Lipid, Lipoprotein, and Apolipoprotein Concentrations (mg/dL^*^) to Define Multifactorial Dyslipidemia in Children and Adolescents^30^,^†^

Category | Acceptable | Borderline | High^‡^
TC | < 170 | 170 to 199 | ≥ 200
LDL-C | < 110 | 110 to 129 | ≥ 130
Non-HDL-C | < 120 | 120 to 144 | ≥ 145
ApoB | < 90 | 90 to 109 | ≥ 110
TG (0 to 9 years) | < 75 | 75 to 99 | ≥ 100
TG (10 to 19 years) | < 90 | 90 to 129 | ≥ 130
Category | Acceptable | Borderline | Low^‡^
HDL-C | > 45 | 40 to 45 | < 40
ApoA-1 | > 120 | 115 to 120 | < 115

* To convert to SI units, divide the results for total cholesterol (TC), low-density lipoprotein cholesterol (LDL-C), high-density lipoprotein cholesterol (HDL-C), and non-HDL-C by 38.6; for triglycerides (TG), divide by 88.6.

† Values for plasma lipid and lipoprotein levels are from the National Cholesterol Education Program (NCEP) Expert Panel on Cholesterol Levels in Children (1992). Non-HDL-C values from the Bogalusa Heart Study are equivalent to the NCEP Pediatric Panel cut points for LDL-C. Values for plasma ApoB and ApoA-1 are from the National Health and Nutrition Examination Survey III.

‡ The cut points for high and borderline high represent approximately the 95th and 75th percentiles, respectively. Low cut points for HDL-C and ApoA-1 represent approximately the 10th percentile.

Abbreviations: ApoA-1 = apolipoprotein A-1; ApoB = apolipoprotein B; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter TC; total cholesterol; TG = triglycerides

Secondary dyslipidemia can occur in children and adolescents with a variety of renal, infectious, hepatic, inflammatory and storage disorders, type 1 and 2 diabetes, and several other syndromes.^30^ Secondary dyslipidemias will not be addressed in the review.

### Prevalence and Burden

#### Prevalence of FH

FH is far more rare than multifactorial dyslipidemia. A 2020 systematic review by Hu and colleagues which included 42 studies representing 7,297,363 participants estimates that the international prevalence of FH in the general population is 0.32 percent (95% CI, 0.25 to 0.40) or 1:311 (95% CI, 1:250 to 1:397).^33^ Stratified analyses by age suggest that FH prevalence point estimates were slightly lower in pediatric populations but with confidence intervals overlapping estimates in adults. In the review by Hu et al, the prevalence of FH in children was estimated to be 0.28 percent (95% CI, 0.11 to 0.51) compared to 0.33 percent (95% CI, 0.24 to 0.43) in adults.^33^ Given that FH is a genetic condition, it might be assumed that prevalence would be constant across age. It has been postulated that rising LDL-C levels in older age may increase the likelihood that older individuals meet clinical criteria.^34^ At the same time, prevalence estimates would be expected to decline in older ages because of CVD-related attrition, suggesting complex forces behind age-related prevalence trends. Investigators have found that underdiagnosis of FH is greatest among children and young adults.^35^

Another 2022 meta-analysis pooled international prevalence data from over 1.1 million individuals demonstrating variation across racial and ethnic groups ranging from 0.25% to 0.52%.^36^ Among US samples included in this analysis, the lowest point prevalence was in White populations (0.21%) and the highest point prevalence was in Black Americans (0.46%).

#### Prevalence of Multifactorial Dyslipidemia

Abnormal lipid levels are highly prevalent worldwide. The latest estimates from the World Health Organization (2008) estimate a global prevalence of elevated total cholesterol (TC) among adults of 39 percent.^37^ Work to update these prevalence estimates is currently underway.^38^ In 2017, high LDL-C was reported to be the fifth-leading cause of risk-attributable deaths, responsible for 4.3 million deaths worldwide in 2017.^39^

Recent prevalence estimates for FH and multifactorial dyslipidemia specific to pediatric populations in the U.S. are systematically reviewed in this report and presented in the results.

### Prognosis

#### Prognosis of FH

FH is associated with very high cardiovascular risk and accelerated vascular aging.^4^ Subclinical atherosclerotic changes appear early in children with FH, with evidence suggesting statistically significant differences in carotid intima-media thickness (cIMT) between children with and without FH as early as 8 years of age with FH children experiencing a far more rapid progression of cIMT.^40,^ ^41^ By adulthood, atherosclerotic burden in individuals with FH has increased substantially because of cumulative exposure to high LDL-C.

There is robust evidence showing the association of the FH phenotype in adulthood with substantially increased risk for cardiovascular events in adulthood. An individual patient data (IPD) meta-analysis of 68,565 adults from six U.S. cohorts found that the FH phenotype, defined by LDL-C ≥190 mg/dL, was associated with an adjusted hazard ratio of 4.1 (95% CI, 1.2 to 13.4) for CVD events over 30 years of followup, compared to a reference group defined by LDL-C <130 mg/dL.^42^ Results were similar when using alternate FH phenotype definitions. These investigators found that the FH phenotype accelerated coronary heart disease (CHD) risk by 10 to 20 years in men, and 20 to 30 years in women. However, these data were primarily collected before the widespread use of statins, with enrollment periods ranging from 1968 to 1990. Observational studies in adults with FH recruited from lipid clinics suggest that the prognosis of FH has improved substantially with the advent of statin treatment.^43,^ ^44^

Prognostic data for FH as determined by genotype is more scant. Data in adults from the Myocardial Infarction Genetic Consortium Studies shows that carriers of FH variants are at increased risk for coronary artery disease at any level of LDL-C.^11^ For example, the odds ratio for coronary artery disease was 5.2 (95% CI, 4.4 to 6.2) for an individual with LDL-C ≥190-220 mg/dL but without a genetic variant (compared to an individual with LDL-C <130 mg/dL and no genetic variant) but the odds ratio for CAD was 17.0 (95% CI, 5.3 to 77.9) among individuals with this level of LDL-C in the presence of an FH genetic variant.^11^

#### Prognosis of Multifactorial Dyslipidemia

Multifactorial dyslipidemia in adulthood is widely established as a risk factor for CVD based on robust evidence from IPD meta-analyses showing strong associations between cholesterol levels in adulthood and ischemic heart disease mortality.^45^ Total cholesterol (TC) and high-density lipoprotein cholesterol (HDL-C) are risk factors included in the Pooled Cohort Equations which are the standard of care risk calculator currently used to estimate 10-year CVD risk in adults and guide initiation of preventive therapies.^46–48^

To establish linkages between elevated lipids in childhood and adolescence with later CVD events, extremely long followup from prospective cohort studies beginning in childhood is required. A 2022 publication from the International Childhood Cardiovascular Cohorts (i3C) Consortium does suggest that elevated lipid levels in childhood (ages 3 to 19 years) are associated with fatal cardiovascular events in adulthood with 35 years of followup; however, the evidence is complicated by the role of adult lipid levels and lack of control for other risk factors.^49^ This evidence is explored more fully in the Discussion.

### Risk Factors

Familial hypercholesterolemia is an inherited genetic condition that can be passed down from one or both parents. Heterozygous FH occurs when a child inherits the gene from one parent. The more severe form of FH (homozygous FH) occurs when a child inherits the gene from both parents.

Multifactorial dyslipidemia in children and adolescents may be associated with environmental factors, such as lifestyle, with or without a genetic component.^30^ Abnormal lipid levels have consistently been shown to be associated with various measures of adiposity.^50–56^ Data from the National Health and Nutrition Examination Survey (NHANES) show that what while higher BMI (≥85^th^ percentile) roughly doubles the risk for elevated TC, that a substantial proportion of those with elevated TC have a BMI <85^th^ percentile (42% to 63%).^57^ Evidence in children and adolescents suggests that higher rates of physical activity and lower rates of sedentary time are associated with more favorable lipid profiles.^22–25^

A family history of dyslipidemia or premature cardiovascular disease is a risk factor for childhood dyslipidemia.^58^ Even apart from a monogenic condition with high penetrance, such as FH where there is a major variant in one gene, there are a number of single nucleotide variants with smaller additive effects that contribute to multifactorial dyslipidemia.^27^

### Rationale for Screening

FH is normally asymptomatic in childhood^4^ and is rarely associated with cardiovascular illness in the first two decades of life.^44,^ ^59^ However, early identification of elevated lipid levels, particularly in populations with FH whereby lipid levels are much higher than in multifactorial dyslipidemia, could aid in identifying populations for initiation of lipid control to reduce lifelong exposure to elevated lipids, and in turn reduce cardiovascular risk in adulthood. Some experts suggest that the primary purpose of lipid screening in pediatric populations is to identify those with FH (rather than those with multifactorial dyslipidemia).^60^

FH is underdiagnosed and undertreated. The extent of underdiagnosis is not known but likely varies by country. In countries with robust screening programs like the Netherlands, it is estimated that as many as 71% of cases are identified.^61^ Investigators in the UK have further found that underdiagnosis of FH is greatest among children and young adults.^35^ In the US, analyses of the CASCADE FH registry have found that FH patients tend to be diagnosed and treated late in life, with median treatment initiation of 39 years and median age of diagnosis of 47 years.^62^ Given that subclinical atherosclerotic changes appear early in children with FH and that CVD risk is increased by cumulative exposure to elevated lipid levels, missed diagnoses at earlier ages likely increase the burden of atherosclerotic CVD. However, the burden of atherosclerotic CVD associated with undiagnosed or undertreated FH in the general U.S. population has not been quantified.^42^

### Screening Strategies

#### Targeted vs. Universal Screening

Targeted and universal screening have been proposed as possible screening strategies for both FH and multifactorial dyslipidemia in children and adolescents (Table 5). There are some differences in current screening guidelines in the US. In 2016, the USPSTF issued an I Statement, stating that current evidence was insufficient to assess the balance of benefits and harms of screening for lipid disorders in children and adolescents aged 20 years or younger.^1^ In comparison, the American Academy of Pediatrics endorsed and adopted the 2012 recommendations from the National Heart, Lung, and Blood Institute (NHLBI) which have a positive recommendation to selectively screen children 2 to 8 years of age with family history of CVD or dyslipidemia, or in the presence of other risk factors, and universally screen children between 9 and 11 years and again between 17 and 21 years.^30,^ ^63^

Table 5 Lipid Screening Recommendations in Pediatric Populations From Other Organizations

Organization, Year | Year published | Universal screening recommendation | Selective screening recommendation
UK National Screening Committee^194^ | 2020 | Systematic population screening program for FH not recommended | -
National Institute for Health and Care Excellence (NICE)^195^ | 2019 | - | In children aged 0–10 years at risk of FH because of 1 affected parent, offer a DNA test at the earliest opportunity. If testing of a child at risk has not been undertaken by the age of 10 years, offer an additional opportunity for a DNA test.; In children at risk of homozygous FH because of two affected parents or because of the presence of clinical signs, for example, cutaneous lipid deposits (xanthomata), LDL-C concentration should be measured before the age of 5 years or at the earliest opportunity thereafter. If the LDL-C concentration is greater than 425 mg/dL then a clinical diagnosis of homozygous FH should be considered.
European Society of Cardiology/European Atherosclerosis Society^193^ | 2019 | - | A diagnosis of FH should be considered in people with relatives with premature CVD, in people with relatives who have tendon xanthomas, in people with severely elevated LDL-C (>150 mg/dL in children), and in first-degree relatives of FH patients.; FH should be diagnosed using clinical criteria and confirmed, when possible, via DNA analysis.; Once the index case is diagnosed, family cascade screening is recommended.; Testing for FH is recommended from the age of 5 years, or earlier if homozygous FH is suspected.
HEART UK^196^ | 2019 | - | Cascade testing of children should be undertaken by age 10 years in families where an FH mutation has been identified, by testing for the mutation identified in the index case. In FH families where the genetic basis is unknown, LDL-C concentrations can be used for cascade screening.
AHA/ACC/AACVPR/AAPA/ABC/ACPM/ADA/AGS/APhA/ASPC/NLA/PCNA Guideline on the Management of Blood Cholesterol^31^ | 2018 | In children and adolescents without cardiovascular risk factors or family history of early CVD, it may be reasonable to measure a fasting lipid profile or nonfasting non-HDL-C once between the ages of 9 and 11 years, and again between the ages of 17 and 21 years, to detect moderate to severe lipid abnormalities | In children and adolescents with a family history of either early CVD (MI, documented angina, or atherosclerosis by angiography in parents, siblings, grandparents, aunts, or uncles [<55 for men and <65 for women]) or significant hypercholesterolemia (≥240 mg/dL, LDL-C ≥190 mg/dL, non-HDL-C ≥220 mg/dL, or known primary hypercholesterolemia), it is reasonable to measure a fasting or nonfasting lipoprotein profile as early as age 2 years to detect FH or rare forms of hypercholesterolemia.
Canadian Cardiovascular Society^197^ | 2018 | Universal cholesterol level screening should be considered for detection of FH in children with reverse cascade screening of parents when warranted | Cascade screening protocols should be implemented at the local, provincial, and national level in Canada and offered to first-degree relatives of patients with FH.
American Academy of Pediatrics (AAP)^30,^ ^63,^ ^198^ | 2017 | Endorsement and adoption of NHLBI 2012 recommendation; Screen once (fasting or nonfasting) between 9 and 11 years of age, and once between 17 and 21 years of age. | Selective screening (fasting lipid profile) between 2 and 8 years of age if (a) parent, grandparent, aunt/uncle, or sibling with MI, angina, stroke, CABG/stent/angioplasty at <55 years in males and <65 years in females, (b) parent with TC ≥240 mg/dL or known dyslipidemia, (c) child has diabetes, hypertension, BMI ≥95^th^ percentile, or smokes cigarettes, or (d) child has a moderate or high-risk medical condition.; Selective screening (fasting lipid profile) between 12 and 16 years of age if there is new knowledge of one of the criteria above, but BMI cutpoint of ≥85^th^ percentile
American Association of Clinical Endocrinologists and American College of Endocrinology^199,^ ^200^ | 2017 | - | Screen children at risk for FH (e.g., family history of premature cardiovascular disease or elevated cholesterol) at 3 years of age, again between ages 9 and 11, and again at age 18. Adolescents >16 years should be screened every 5 years or more frequently if they have ASCVD risk factors, overweight or obesity, other elements of insulin resistance syndrome, or a family history of premature ASCVD.
American Academy of Family Physicians (AAFP)^201^ | 2016 | Endorsement of the USPSTF recommendation.; The current evidence is insufficient to assess the balance of benefits and harms of screening for lipid disorders in children and adolescents 20 years or younger | -
International FH Foundation^202^ | 2015 | Targeted, opportunistic, and universal screening strategies should be employed to detect index cases | Targeted, opportunistic, and universal screening strategies should be employed to detect index cases.; Children with xanthomata or other physical findings of homozygous FH, or at risk of homozygous FH should be screened as early as possible and definitely by 2 years of age.; Children with suspected heterozygous FH should be screened between the ages of five and 10 years; age at screening should be similar in males and females.; Secondary causes of hypercholesterolaemia should first be excluded.; Children should be genetically tested for FH only after a pathogenic variant (mutation) has been identified in a parent or first degree relative; Children may initially be genetically tested for FH when parents or first-degree relatives are unknown or deceased, or as an accepted screening practice in certain countries, such as the Netherlands.; Age-, gender- and country-specific plasma LDL-C concentration thresholds should be used to make the phenotypic diagnosis; because of biological variation, two fasting LDL-cholesterol values are recommended.; A plasma LDL-C of ≥190 mg/dL indicates high probability of FH in the absence of a positive parental history of hypercholesterolaemia or premature CHD; an LDL-C of 155 mg/dL or above indicates high probability of FH in the presence of a positive parental history of hypercholesterolaemia or premature CHD.
National Heart, Lung, and Blood Institute’s (NHLBI) Expert Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents^30^ | 2012 | Screen once (fasting or nonfasting) between 9 and 11 years of age, and once between 17 and 21 years of age. | Same as AAP (first row); Selective screening (fasting lipid profile) between 2 and 8 years of age if (a) parent, grandparent, aunt/uncle, or sibling with MI, angina, stroke, CABG/stent/angioplasty at <55 years in males and <65 years in females, (b) parent with TC ≥240 mg/dL or known dyslipidemia, (c) child has diabetes, hypertension, BMI ≥95th percentile, or smokes cigarettes, or (d) child has a moderate or high-risk medical condition.; Selective screening (fasting lipid profile) between 12 and 16 years of age if there is new knowledge of one of the criteria above, but BMI cutpoint of ≥85th percentile.

Abbreviations: AACVPR = American Association of Cardiovascular and Pulmonary Rehabilitation; AAPA = American Academy of Physician Assistants; ABC = Association of Black Cardiologists; ACC = American College of Cardiology; ACPM = American College of Preventive Medicine; ADA = American Diabetes Association; AGS = American Geriatrics Society; AHA = American Heart Association; APhA = American Pharmacists Association; ASPC = American Society for Preventive Cardiology; BMI = body mass index; CHD= coronary heart disease; CVD = cardiovascular disease; DNA = deoxyribonucleic acid; FH = familial hypercholesterolemia; HDL-C = high=density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; NHLBI = National Heart, Lung, and Blood Institute; NLA = National Lipid Association; PCNA = Preventive Cardiovascular Nurses Association; TC = total cholesterol; UK = United Kingdom; USPSTF = United States Preventive Services Task Force

##### FH

Several models for FH screening have been studied and/or implemented internationally including cascade screening, universal screening, and precision screening.^64–67^ Several guidelines have suggested targeted serum lipid screening in children who have a positive family history of premature CVD or relatives with known familial hyperlipidemia. However, studies have shown that patient reports of family history have poor accuracy,^68^ potentially limiting the usefulness of this strategy. A large ongoing population-based screening study of children in one U.S. state has found that use of family history alone is not a strong indicator of LDL-C values warranting pharmacological treatment.^69^ Targeted screening for FH based on other risk factors like elevated BMI is also not ideal because the mechanisms of FH are independent of obesity. Estimates of FH in U.S. youth by obesity status are not available, but estimates are available in adults. While adults with obesity are more likely to meet FH criteria, there are a nontrivial number of nonobese individuals with FH (0.58% [1:172] in adults with obesity compared to 0.31% [1:325] in adults without obesity).^70^

Universal serum lipid testing would lead to greater identification of FH but would also lead to more testing compared to targeted screening. Identification of youth with FH may also offer the additional benefit of identifying adults in the family through reverse cascade screening.^71,^ ^72^

##### Multifactorial Dyslipidemia

Targeted serum lipid screening for those identified as overweight or obese has been proposed based on the high prevalence of multifactorial dyslipidemia in overweight and obese youth. Epidemiologic data confirms higher prevalence of abnormal lipids in higher BMI populations;^52^ however, screening guided by weight status alone would miss a nontrivial number of individuals with multifactorial dyslipidemia who are not in overweight or obese BMI categories.

#### Serum Lipid Components for Screening

Clinical questions arise about which components of the lipid panel are needed for screening in all ages. In children, data are limited regarding which components of the lipid panel are predictive of CVD events and mortality later in life. Analyses from the i3C Consortium show that both TC and TG are associated with mortality in adulthood, but data for LDL-C and HDL-C are not reported.^49^ Some evidence suggests that non-HDL-C in childhood is equivalent to LDL-C for predicting adult cIMT.^73^ Thus, non-HDL-C may have clinical utility for nonfasting samples or in those with TG >400 mg/dL. Data in adults are somewhat conflicting about the lipid component with the best predictive power for CVD events, with conclusions being limited by the fact that not all lipid components are available in each analysis. In 2019, the Multinational Cardiovascular Risk Consortium reported that that non-HDL-C and LDL-C have comparable prognostic relevance for atherosclerotic CVD.^74^ The Pooled Cohort Equations, currently used for multivariate CVD risk assessment in adults, use TC and HDL-C.^75^

#### Fasting vs. Nonfasting Tests

There are dynamic effects of eating on some lipid components, particularly TG.^76^ Because LDL-C is often estimated using the Friedewald formula (LDL-C=[TC – HDL-C] – [TG/5]),^77^ this calculated LDL-C value is also affected by fasting status. Other methods of calculating LDL-C, however, have been validated in nonfasting samples.^78^

Nonfasting tests are recommended as a method for improving the feasibility and acceptability of screening, where fasting may be particularly burdensome for pediatric populations.^30,^ ^76^ Nonfasting tests are accepted as a first screening step in youth ages 9 to 11 years in prominent U.S. guidelines.^30^ However, it is recommended that initially abnormal lipid levels be confirmed by an additional test in the fasting state. Nonfasting lipid tests have become standard in some European countries for screening in adults.^76^ Large analyses in both children and adults have shown that differences in lipid values between fasting and nonfasting samples may be small and may not be clinically important.^79^

### Treatment Approaches

The treatment pathway is different in FH and multifactorial dyslipidemia because of the substantially higher lipid levels seen in FH (Appendix A Table 3). Various treatment modalities have been recommended for lipid-lowering, including lifestyle modification (Appendix A Table 4), pharmacotherapy, and dietary supplements. Several drugs are approved by the FDA for use in pediatric populations with heterozygous FH (Appendix A Table 5).^80–83^ Seven statins are approved in pediatric populations with heterozygous FH in ages as young as 8 years old. Other agents, including bile acid sequestrants, ezetimibe, and PCSK9 inhibitors are FDA-approved in pediatric populations with heterozygous FH in ages as young as 10 years old.

#### FH

Youth with heterozygous FH are considered “moderate risk” in the AHA Scientific Statement on CVD Risk Reduction in High-Risk Pediatric Patients.^4^ Treatment algorithms in this guidance differ based on risk stratification. For “moderate risk” youth, therapeutic lifestyle change is recommended for 3 months, with the addition of a statin if LDL-C remains above goal (LDL-C <130 mg/dL). General lifestyle advice is a diet high in fiber from fruits and vegetables, whole grains, high in polyunsaturated and monounsaturated fats, low in saturated fat, and devoid of trans fats; five or more hours of moderate to vigorous physical activity per week; and consideration of phytosterol supplements.

#### Multifactorial Dyslipidemia

Youth with multifactorial dyslipidemia with an LDL-C ≥160 mg/dL may fall in the “at risk” stratification in the AHA Scientific Statement if obesity, insulin resistance, or other risk factors are present.^4^ In “at risk” individuals, treatment recommendations are to initiate therapeutic lifestyle change for 6 months and if LDL-C remains above goal (LDL-C <130 mg/dL), to add a statin. Lifestyle advice is the same as that for the “moderate risk” individuals described above.

### Current Clinical Practice in the United States

Lipid screening in the United States is inconsistent in pediatric populations and this may be due to conflicting screening guidelines, perceived low yield or impact of universal screening, and uncertainty about dyslipidemia treatment.^84^ Recent studies investigating screening practices in large U.S. health care organizations have found universal screening rates of 2 to 9 percent in children between 9 and 11 years of age.^85–89^ Higher weight status, non-white race or ethnicity, and the presence of comorbid conditions were associated with higher screening rates in these studies.

Data from the CASCADE FH Registry provide information about FH detection and treatment in the U.S. pediatric population in the context of referral populations from lipid clinics.^90^ In a sample of 493 children and adolescents <18 years old from the FH Registry, covering data from 2014-2018, the mean age of FH diagnosis was 9.4 years of age. This is in the context of AAP recommendations to selectively screen children 2 to 8 years of age with family history of CVD or dyslipidemia, or in the presence of other risk factors, and universal screening between 9 and 11 years and again between 17 and 21 years. Of those eligible for lipid-lowering therapy based on age, LDL-C level, and family history, 72 percent were taking a statin and 7 percent a supplement (phytosterols, omega-3 fatty acids, psyllium), yet only 28 percent achieved their LDL-C goal. Genetic testing appeared to be rare, with just 2 percent having a confirmed FH genetic mutation.

### Previous USPSTF Recommendation

In 2016, the USPSTF concluded that the evidence was insufficient to assess the balance of benefits and harms of screening for lipid disorders in children and adolescents 20 years or younger (Grade: I statement).^1^ This was consistent with the previous 2007 USPSTF recommendation.^91^

The USPSTF has two other recommendations related to cardiovascular disease prevention in children and adolescents. The USPSTF recommends that clinicians screen for obesity in children and adolescents 6 years and older and offer or refer them to comprehensive, intensive behavioral interventions to promote improvements in weight status (2017 B recommendation).^92^ Additionally, the USPSTF found insufficient evidence on screening for high blood pressure in children and adolescents to prevent subsequent cardiovascular disease in childhood or adulthood (2020 I statement).^93^

In 2022, the USPSTF recommended that clinicians prescribe a statin in adults aged 40 to 75 years without a history of CVD who have 1 or more CVD risk factors (dyslipidemia, diabetes, hypertension, or smoking) and a calculated 10-year CVD event risk of 10 percent or greater (B recommendation).^94^ The Task Force also recommends clinicians selectively offer a statin to adults aged 40 to 75 years without a history of CVD who have 1 or more CVD risk factors and a calculated 10-year CVD event risk of 7.5 to 10 percent (C recommendation). Additionally, the USPSTF concluded that the current evidence is insufficient to assess the balance of benefits and harms of initiating statin use in adults 76 years and older (I statement).^94^ However, the USPSTF recommendation is not intended for individuals with known FH or with LDL-C ≥190 mg/dL who are considered to be at very high CVD risk.

A 2016 systematic evidence review was conducted on screening for dyslipidemia in younger adults ages 21-39 years; however, the authors identified no studies meeting inclusion criteria, and the USPSTF did not make recommendations for this population.^95^